# Appendix A Search Strategies and Detailed Methods

## Osteoporosis Search April 16, 2015

### Pubmed

| Search String | Results
#1 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh] | 197432
#5 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh] Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 19932
#7 | Search “Mass Screening”[Mesh] OR “Risk Assessment”[Mesh] | 281086
#8 | Search (#5 AND #7) | 1279
#9 | Search (#5 AND #7) Filters: Systematic Reviews | 85
#11 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2263475
#12 | Search (#8 AND #11) | 818
#13 | Search (#9 OR #12) | 859
#14 | Search (“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh]) | 74931
#18 | Search (“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh])Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 8672
#20 | Search ((“Ultrasonography”[Mesh]) OR “Tomography, X-Ray Computed”[Mesh]) OR (“Densitometry”[Mesh] OR “Absorptiometry, Photon”[Mesh]) | 573915
#21 | Search (#18 AND #20) | 2718
#22 | Search (#18 AND #20) Filters: Systematic Reviews | 33
#23 | Search (#21 AND #11) | 1336
#24 | Search (#22 OR #23) | 1354
#25 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh])) | 70305
#29 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh])) Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 8207
#31 | Search (((((“Diphosphonates”[Mesh]) OR “Alendronate”[Mesh] OR “risedronic acid”[Supplementary Concept]) OR “Etidronic Acid”[Mesh]) OR “ibandronic acid”[Supplementary Concept]) OR “pamidronate”[Supplementary Concept]) OR “zoledronic acid”[Supplementary Concept] OR Bone Density Conservation Agents[mesh] “Calcium Carbonate”[Mesh] OR “Estrogen Receptor Modulators”[Mesh] OR “Selective Estrogen Receptor Modulators”[Mesh] | 5166
#32 | Search ((“Calcitonin”[Mesh]) OR ((“Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh]) OR “Estradiol Congeners”[Mesh])) OR ((((“Parathyroid Hormone”[Mesh]) oR “Tamoxifen”[Mesh]) OR “Teriparatide”[Mesh] OR “Raloxifene”[Mesh]) OR “Testosterone”[Mesh]) OR “RANK ligand inhibitor” OR “estropipate” [Supplementary Concept] OR “bazedoxifene” [Supplementary Concept] | 206284
#33 | Search (#31 OR #32) | 207691
#34 | Search (#29 AND #33) | 977
#35 | Search (#34 and #11) | 534
#36 | Search (#29 AND #33) Filters: Systematic Reviews | 27
#41 | Search #35 OR #36 | 552
#42 | Search (#41 OR #24 OR #13) | 2439

### Cochrane

Osteoporosis AND (screening OR treatment) = 40

### Embase

Osteoporosis AND (screening OR treatment) = 233

### ClinicalTrials.gov

Osteoporosis AND (screening OR treatment) = 285

### Drugs@FDA.gov

Osteoporosis AND (screening OR treatment)

### HSRProj

“osteoporosis” = 19

### Cochrane Clinical Trials Registry

Osteoporosis AND (screening OR treatment) = 1068

#### Who Ictrp

Osteoporosis AND (screening OR treatment) = 23

### Official “Risk Assessment” Add in for Earlier Work (October 16, 2015)

Official “Risk Assessment” Add In For Earlier Work (October 16, 2015)

| Search String | Results
#1 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh] | 202036
#2 | Search “Mass Screening”[Mesh] OR screen | 237370
#3 | Search “Risk Assessment”[Mesh] | 190623
#4 | Search (#3 NOT #2) | 183589
#5 | Search (#1 AND #4) | 3743
#6 | Search (#1 AND #4) Filters: Humans | 3719
#7 | Search (#1 AND #4) Filters: Humans; English | 3416
#8 | Search (#1 AND #4) Filters: Humans; English; Adult: 19+ years | 2450
#9 | Search (#1 AND #4) Filters: Publication date from 2001/01/01 to 2009/12/31; Humans; English; Adult: 19+ years | 1207

## Osteoporosis Update Search October 16, 2015

### Pubmed

Full Results For All Screening Or Risk Assessment (Not Narrowed By Study Type)

| Search String | Results
#1 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh] | 202036
#8 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]Filters: Humans | 176314
#9 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]Filters: Humans; English | 131410
#10 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]Filters: Humans; English; Adult: 19+ years | 83026
#11 | Search “Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 22192
#13 | Search “Mass Screening”[Mesh] OR “Risk Assessment”[Mesh] | 289991
#14 | Search (#11 AND #13) | 1388

### Updates for April Search

Updates For April Search

| Search String | Results
#15 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh])) | 76720
#18 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh]))Filters: Humans; English; Adult: 19+ years | 35637
#19 | Search (“2015”[Date -Entrez] : “3000”[Date -Entrez]) Filters: Humans; English; Adult: 19+ years | 32504
#21 | Search ((“Ultrasonography”[Mesh]) OR “Tomography, X-Ray Computed”[Mesh]) OR (“Densitometry”[Mesh] OR “Absorptiometry, Photon”[Mesh]) | 590335
#22 | Search (#18 AND #19 AND #21) | 58
#23 | Search (#18 AND #19 AND #21) Filters: Systematic Reviews | 0
#25 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2344296
#26 | Search (#18 AND #19 AND #25) | 111
#28 | Search (((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh]))) | 71994
#31 | Search (((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh]))) Filters: Humans; English; Adult: 19+ years | 33693
#32 | Search (#31 AND #19) Filters: Humans; English; Adult: 19+ years | 190
#34 | Search (((((((“Diphosphonates”[Mesh]) OR “Alendronate”[Mesh] OR “risedronic acid”[Supplementary Concept]) OR “Etidronic Acid”[Mesh]) OR “ibandronic acid”[Supplementary Concept]) OR “pamidronate”[Supplementary Concept]) OR “zoledronic acid”[Supplementary Concept] OR Bone Density Conservation Agents[mesh] “Calcium Carbonate”[Mesh] OR “Estrogen Receptor Modulators”[Mesh] OR “Selective Estrogen Receptor Modulators”[Mesh])) OR (((“Calcitonin”[Mesh]) OR ((“Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh]) OR “Estradiol Congeners”[Mesh])) OR ((((“Parathyroid Hormone”[Mesh]) OR “Tamoxifen”[Mesh]) OR “Teriparatide”[Mesh] OR “Raloxifene”[Mesh]) OR “Testosterone”[Mesh]) OR “RANK ligand inhibitor” OR “estropipate” [Supplementary Concept] OR “bazedoxifene” [Supplementary Concept] OR “denosumab” [Supplementary Concept]) | 210994
#35 | Search (#32 AND #34) | 22
#36 | Search (#35 AND #25) | 15
#37 | Search (#32 AND #34) Filters: Systematic Reviews | 0

PubMed = 117 = 98 NEW

### Cochrane

Osteoporosis AND (screening OR treatment) = 0 NEW

### Embase

Osteoporosis AND (screening OR treatment) = 65 = 44 NEW

### ClinicalTrials.gov

Osteoporosis AND (screening OR treatment) = 3 = 0 NEW

(Citations provided separately — not part of database)

### Drugs@FDA.gov

Will do targeted searches for “harms” as indicated

### HSRProj

“osteoporosis” = 19

### Cochrane Clinical Trials Registry

Osteoporosis AND (screening OR treatment) = 48 = 44 New

#### WHO ICTRP

Osteoporosis AND (screening OR treatment) = 0

Total Unduplicated Database = 186

### TBS Add on (December 21, 2015)

TBS Add On (December 21, 2015)

| Search String | Results
#102 | Search “trabecular bone score ” | 113
#105 | Search (“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh]) | 293426
#106 | Search (#102 AND #105) | 17
#107 | Search (#102 AND #105) Filters: Systematic Reviews | 0
#108 | Search (#102 AND #105) Schema: all Filters: Systematic Reviews | 0
#109 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2376092
#110 | Search (#102 AND #109) | 32
#114 | Search (#102 AND #109) Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 28

7 new

### Supplemental Denosumab Search (July 29, 2016)

Supplemental Denosumab Search (July 29, 2016)

| Search String | Results
#1 | Search denosumab | 1631
#4 | Search “Osteoporosis”[Mesh] OR “Bone Density”[Mesh] | 74955
#5 | Search (#1 AND #4) | 566
#6 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2474527
#7 | Search (#5 AND #6) | 116
#8 | Search (#5 AND #6) Filters: Humans | 116
#9 | Search (#5 AND #6) Filters: Humans; English | 114
#10 | Search (#5 AND #6) Filters: Humans; English; Adult: 19+ years | 98

### Supplemental Pharmaceutical Search and Deduplication (8/1/2016)

Supplemental Pharmaceutical Search And Deduplication (8/1/2016)

| Search String | Results
#1 | Search “Fractures, Bone”[Mesh] | 157410
#2 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh])) | 74997
#3 | Search (#1 NOT #2) | 140422
#7 | Search (#1 NOT #2) Filters: Publication date from 2009/11/01; Humans; English; Adult: 19+ years | 15369
#10 | Search ((“Calcitonin”[Mesh]) OR ((“Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh]) OR “Estradiol Congeners”[Mesh])) OR ((((“Parathyroid Hormone”[Mesh]) oR “Tamoxifen”[Mesh]) OR “Teriparatide”[Mesh] OR “Raloxifene”[Mesh]) OR “Testosterone”[Mesh]) OR “RANK ligand inhibitor” OR “estropipate” [Supplementary Concept] OR “bazedoxifene” [Supplementary Concept] OR “denosumab” [Supplementary Concept] | 218717
#11 | Search (((((“Diphosphonates”[Mesh]) OR “Alendronate”[Mesh] OR “risedronic acid”[Supplementary Concept]) OR “Etidronic Acid”[Mesh]) OR “ibandronic acid”[Supplementary Concept]) OR “pamidronate”[Supplementary Concept]) OR “zoledronic acid”[Supplementary Concept] OR Bone Density Conservation Agents[mesh] “Calcium Carbonate”[Mesh] OR “Estrogen Receptor Modulators”[Mesh] OR “Selective Estrogen Receptor Modulators”[Mesh] | 5443
#12 | Search (#10 OR #11) | 220200
#13 | Search (#7 AND #12) | 119
#14 | Search (#7 AND #12) Filters: Systematic Reviews | 7
#15 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2477337
#18 | Search (#13 AND #15) | 45
#19 | Search (#14 OR #18) | 47

### Update to Full Search (10/1/2016)

| Search String | Results
#1 | Search (“Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]) | 216915
#5 | Search (“Osteoporosis”[Mesh] OR “Fractures, Bone”[Mesh] OR “Bone Density”[Mesh]) Filters: Publication date from 2016/01/01; Humans; English; Adult: 19+ years | 519
#6 | Search (“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh]) | 308814
#7 | Search (#5 AND #6) | 31
#8 | Search (#5 AND #6) Filters: Systematic Reviews | 2
#9 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2505387
#10 | Search (#7 AND #9) | 24
#11 | Search (#8 OR #10) | 24
#13 | Search (“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh]) | 80677
#16 | Search (“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh])Filters: Humans; English; Adult: 19+ years | 37386
#17 | Search (“Osteoporosis”[Mesh] OR “Bone Density”[Mesh] OR “Calcaneus”[Mesh])Filters: Publication date from 2016/01/01; Humans; English; Adult: 19+ years | 202
#19 | Search (((“Ultrasonography”[Mesh]) OR “Tomography, X-Ray Computed”[Mesh]) OR (“Densitometry”[Mesh] OR “Absorptiometry, Photon”[Mesh])) | 622542
#20 | Search (#17 AND #19) | 80
#21 | Search (#17 AND #19) Filters: Systematic Reviews | 0
#22 | Search (#20 AND #9) | 44
#24 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh])) | 75586
#28 | Search ((“Osteoporosis”[Mesh] OR “Bone Density”[Mesh])) Filters: Publication date from 2016/01/01; Humans; English; Adult: 19+ years | 198
#30 | Search (((((“Diphosphonates”[Mesh]) OR “Alendronate”[Mesh] OR “risedronic acid”[Supplementary Concept]) OR “Etidronic Acid”[Mesh]) OR “ibandronic acid”[Supplementary Concept]) OR “pamidronate”[Supplementary Concept]) OR “zoledronic acid”[Supplementary Concept] OR Bone Density Conservation Agents[mesh] “Calcium Carbonate”[Mesh] OR “Estrogen Receptor Modulators”[Mesh] OR “Selective Estrogen Receptor Modulators”[Mesh] | 5478
#31 | Search (((“Calcitonin”[Mesh]) OR ((“Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh]) OR “Estradiol Congeners”[Mesh])) Or ((((“Parathyroid Hormone”[Mesh]) oR “Tamoxifen”[Mesh]) OR “Teriparatide”[Mesh] OR “Raloxifene”[Mesh]) OR “Testosterone”[Mesh]) OR “RANK ligand inhibitor” OR “estropipate” [Supplementary Concept] OR “bazedoxifene” [Supplementary Concept] OR “denosumab” [Supplementary Concept]) | 219684
#32 | Search (#30 OR #31) | 221184
#33 | Search (#28 AND #32) | 19
#34 | Search (#28 AND #32) Filters: Systematic Reviews | 0
#36 | Search (#33 AND #9) | 12
#38 | Search (#11 OR #22 OR #36) | 71

Total New Unduplicated Database Additions = 76

### TBS Add on (10/1/2016)

TBS Add On (10/1/2016)

| Search String | Results
#1 | Search “trabecular bone score ” | 160
#2 | Search (“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh]) | 308814
#3 | Search (“trabecular bone score ”) AND ((“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh])) | 22
#4 | Search (“trabecular bone score ”) AND ((“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh])) Filters: Systematic Reviews | 0
#5 | Search (“trabecular bone score ”) AND ((“Mass Screening”[Mesh] OR “Risk Assessment”[Mesh])) Schema: all Filters: Systematic Reviews | 0
#6 | Search ((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh]) | 2505387
#7 | Search (“trabecular bone score ”) AND (((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh])) | 43
#8 | Search (“trabecular bone score ”) AND (((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh])) Filters: Humans | 43
#9 | Search (“trabecular bone score ”) AND (((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh])) Filters: Humans; Adult: 19+ years | 41
#10 | Search (“trabecular bone score ”) AND (((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh])) Filters: Humans; English; Adult: 19+ years | 40
#11 | Search (“trabecular bone score ”) AND (((“Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trial” [Publication Type] OR “Meta-Analysis” [Publication Type] OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh] OR “Sensitivity and Specificity”[Mesh])) Filters: Publication date from 2015/01/01; Humans; English; Adult: 19+ years | 14

Total New Unduplicated Database Additions = 12