# References

1 Curry SJ, Grossman DC, Whitlock EP, . Behavioral counseling research and evidence-based practice recommendations: U.S. Preventive Services Task Force perspectives. Ann Intern Med. 2014;160(6):407-13. PMID: 24723080.24723080
2 Lin JS, Eder M, Weinmann S, . Behavioral Counseling to Prevent Skin Cancer: Systematic Evidence Review to Update the 2003 U.S. Preventive Services Task Force Recommendation. Rockville, MD. 2011.
3 U. S. Preventive Services Task Force. Behavioral counseling to prevent skin cancer: recommendation statement. Am Fam Physician. 2012;86(8):1-3. PMID: 23062167.23062167
4 U. S. Preventive Services Task Force. Screening for skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(3):188-93. PMID: 19189908.19189908
5 Wolff T, Tai E, Miller T. Screening for skin cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;150(3):194-8. PMID: 19189909.19189909
6 Albert MR, Weinstock MA. Keratinocyte carcinoma. CA Cancer J Clin. 2003;53(5):292-302. PMID: 14570228.14570228
7 American Cancer Society. Skin Cancer: Basal and Squamous Cell. Atlanta, GA: American Cancer Society ]. http://www.cancer.org/acs/groups/cid/documents/webcontent/003139-pdf.pdf.
8 American Cancer Society. Melanoma Skin Cancer. American Cancer Society [2016 Jan 12]. http://www.cancer.org/cancer/skincancer-melanoma/detailedguide/index.
9 Clark WH, Jr., Elder DE, Guerry Dt, . Model predicting survival in stage I melanoma based on tumor progression. J Natl Cancer Inst. 1989;81(24):1893-904. PMID: 2593166.2593166
10 Rigel DS, Carucci JA. Malignant melanoma: prevention, early detection, and treatment in the 21st century. CA Cancer J Clin. 2000;50(4):215-36; quiz 37-40. PMID: 10986965.10986965
11 Balch CM, Soong SJ, Gershenwald JE, . Prognostic factors analysis of 17,600 melanoma patients: validation of the American Joint Committee on Cancer melanoma staging system. J Clin Oncol. 2001;19(16):3622-34. PMID: 11504744.11504744
12 McGovern VJ, Mihm MC, Jr., Bailly C, . The classification of malignant melanoma and its histologic reporting. Cancer. 1973;32(6):1446-57. PMID: 4757934.4757934
13 Tannous ZS, Lerner LH, Duncan LM, . Progression to invasive melanoma frommalignant melanoma in situ, lentigo maligna type. Hum Pathol. 2000;31(6):705-8. PMID: 10872664.10872664
14 Clark WH, Jr., Elder DE, Van Horn M. The biologic forms of malignant melanoma. Hum Pathol. 1986;17(5):443-50. PMID: 3699806.3699806
15 Tuong W, Cheng LS, Armstrong AW. Melanoma: epidemiology, diagnosis, treatment, and outcomes. Dermatol Clin. 2012;30(1):113-24, ix. PMID: 22117873.22117873
16 Shain AH, Bastian BC. From melanocytes to melanomas. Nat Rev Cancer. 2016;16(6):345-58. PMID: 27125352.27125352
17 Perera E, Sinclair R. An estimation of the prevalence of nonmelanoma skin cancer in the U.S. F1000Res. 2013;2(107):107. PMID: 24358841.24358841
18 Harris RB, Griffith K, Moon TE. Trends in the incidence of nonmelanoma skin cancers in southeastern Arizona, 1985-1996. J Am Acad Dermatol. 2001;45(4):528-36. PMID: 11568742.11568742
19 Karagas MR, Greenberg ER, Spencer SK, . Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire Skin Cancer Study Group. Int J Cancer. 1999;81(4):555-9. PMID: 10225444.10225444
20 Eisemann N, Waldmann A, Geller AC, . Non-melanoma skin cancer incidence and impact of skin cancer screening on incidence. J Invest Dermatol. 2014;134(1):43-50. PMID: 23877569.23877569
21 Housman TS, Feldman SR, Williford PM, . Skin cancer is among the most costly of all cancers to treat for the Medicare population. J Am Acad Dermatol. 2003;48(3):425-9. PMID: 12637924.12637924
22 Australian Institute of Health and Welfare. Non-melanoma skin cancer: General practice consultations, hospitalisation and mortality. Canberra, Australia: Australian Institute of Health and Welfare, Cancer Australia [2017 April 5]. http://www.aihw.gov.au/WorkArea/DownloadAsset.aspx?id=6442454591.
23 Collins B, Smith C, Anderson M, . Head and neck skin cancer in the immunocompromised patient: a quantitative analysis. J Okla State Med Assoc. 2015;108(1):8-12. PMID: 25790580.25790580
24 Guy GP, Jr., Thomas CC, Thompson T, . Vital signs: melanoma incidence and mortality trends and projections - United States, 1982-2030. MMWR Morb Mortal Wkly Rep. 2015;64(21):591-6. PMID: 26042651.26042651
25 Kohler BA, Sherman RL, Howlader N, . Annual Report to the Nation on the Status of Cancer, 1975-2011, Featuring Incidence of Breast Cancer Subtypes by Race/Ethnicity, Poverty, and State. J Natl Cancer Inst. 2015;107(6):djv048. PMID: 25825511.25825511
26 Linos E, Swetter SM, Cockburn MG, . Increasing burden of melanoma in the United States. J Invest Dermatol. 2009;129(7):1666-74. PMID: 19131946.19131946
27 American Cancer Society. Cancer Facts & Figures 2016. Atlanta, GA: American Cancer Society [2017 Jan 3]. http://www.cancer.org/research/cancerfactsstatistics/cancerfactsfigures2016/.
28 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2015. CA Cancer J Clin. 2015;65(1):5-29. PMID: 25559415.25559415
29 National Cancer Institute. SEER Stat Fact Sheets: Melanoma of the Skin. Bethesda, MD: National Cancer Institute [2016 Jan 12]. http://seer.cancer.gov/statfacts/html/melan.html.
30 Howlader N, Noone AM, Krapcho M, . SEER Cancer Statistics Review, 1975-2013. Bethesda, MD: National Cancer Institute; 2016.
31 Weinstock MA, Bogaars HA, Ashley M, . Nonmelanoma skin cancer mortality. A population-based study. Arch Dermatol. 1991;127(8):1194-7. PMID: 1863078.1863078
32 American Cancer Society. Key Statistics for Basal and Squamous Cell Skin Cancers. American Cancer Society [2017 April 10]. https://www.cancer.org/cancer/basal-and-squamous-cell-skin-cancer/about/key-statistics.html.
33 Livingstone E, Windemuth-Kieselbach C, Eigentler TK, . A first prospective population-based analysis investigating the actual practice of melanoma diagnosis, treatment and follow-up. Eur J Cancer. 2011;47(13):1977-89. PMID: 21612915.21612915
34 Welch HG, Woloshin S, Schwartz LM. Skin biopsy rates and incidence of melanoma: population based ecological study. BMJ. 2005;331(7515):481. PMID: 16081427.16081427
35 Erdei E, Torres SM. A new understanding in the epidemiology of melanoma. Expert Rev Anticancer Ther. 2010;10(11):1811-23. PMID: 21080806.21080806
36 Joseph MG, Zulueta WP, Kennedy PJ. Squamous cell carcinoma of the skin of the trunk and limbs: the incidence of metastases and their outcome. Aust N Z J Surg. 1992;62(9):697-701. PMID: 1520151.1520151
37 Brantsch KD, Meisner C, Schonfisch B, . Analysis of risk factors determining prognosis of cutaneous squamous-cell carcinoma: a prospective study. Lancet Oncol. 2008;9(8):713-20. PMID: 18617440.18617440
38 Brougham ND, Dennett ER, Cameron R, . The incidence of metastasis from cutaneous squamous cell carcinoma and the impact of its risk factors. J Surg Oncol. 2012;106(7):811-5. PMID: 22592943.22592943
39 SEER Training Modules. Skin Cancer: Melanoma. U. S. National Institutes of Health, National Cancer Institute [2017 April 7]. https://training.seer.cancer.gov/melanoma/.
40 Veierod MB, Couto E, Lund E, . Host characteristics, sun exposure, indoor tanning and risk of squamous cell carcinoma of the skin. Int J Cancer. 2014;135(2):413-22. PMID: 24408678.24408678
41 Khalesi M, Whiteman DC, Tran B, . A meta-analysis of pigmentary characteristics, sun sensitivity, freckling and melanocytic nevi and risk of basal cell carcinoma of the skin. Cancer Epidemiol. 2013;37(5):534-43. PMID: 23849507.23849507
42 Gandini S, Sera F, Cattaruzza MS, . Meta-analysis of risk factors for cutaneous melanoma: III. Family history, actinic damage and phenotypic factors. Eur J Cancer. 2005;41(14):2040-59. PMID: 16125929.16125929
43 Gandini S, Sera F, Cattaruzza MS, . Meta-analysis of risk factors for cutaneous melanoma: I. Common and atypical naevi. Eur J Cancer. 2005;41(1):28-44. PMID: 15617989.15617989
44 Cho E, Rosner BA, Colditz GA. Risk factors for melanoma by body site. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1241-4. PMID: 15894679.15894679
45 Tucker MA, Halpern A, Holly EA, . Clinically recognized dysplastic nevi. A central risk factor for cutaneous melanoma. JAMA. 1997;277(18):1439-44. PMID: 9145715.9145715
46 Veierod MB, Weiderpass E, Thorn M, . A prospective study of pigmentation, sun exposure, and risk of cutaneous malignant melanoma in women. J Natl Cancer Inst. 2003;95(20):1530-8. PMID: 14559875.14559875
47 Marghoob AA, Slade J, Salopek TG, . Basal cell and squamous cell carcinomas are important risk factors for cutaneous malignant melanoma. Screening implications. Cancer. 1995;75(2 Suppl):707-14. PMID: 7804999.7804999
48 Pomerantz H, Huang D, Weinstock MA. Risk of subsequent melanoma after melanoma in situ and invasive melanoma: a population-based study from 1973 to 2011. J Am Acad Dermatol. 2015;72(5):794-800. PMID: 25769192.25769192
49 Spanogle JP, Clarke CA, Aroner S, . Risk of second primary malignancies following cutaneous melanoma diagnosis: a population-based study. J Am Acad Dermatol. 2010;62(5):757-67. PMID: 20223559.20223559
50 Olsen CM, Carroll HJ, Whiteman DC. Familial melanoma: a meta-analysis and estimates of attributable fraction. Cancer Epidemiol Biomarkers Prev. 2010;19(1):65-73. PMID: 20056624.20056624
51 Rivers JK. Melanoma. Lancet. 1996;347(9004):803-6. PMID: 8622339.8622339
52 Leachman SA, Carucci J, Kohlmann W, . Selection criteria for genetic assessment of patients with familial melanoma. J Am Acad Dermatol. 2009;61(4):677 e1-14. PMID: 19751883.19751883
53 Hussain SK, Sundquist J, Hemminki K. The effect of having an affected parent or sibling on invasive and in situ skin cancer risk in Sweden. J Invest Dermatol. 2009;129(9):2142-7. PMID: 19242514.19242514
54 Lambert WC, Kuo HR, Lambert MW. Xeroderma pigmentosum. Dermatol Clin. 1995;13(1):169-209. PMID: 7712643.7712643
55 Read J, Wadt KA, Hayward NK. Melanoma genetics. J Med Genet. 2016;53(1):1-14. PMID: 26337759.26337759
56 Potrony M, Badenas C, Aguilera P, . Update in genetic susceptibility in melanoma. Ann Transl Med. 2015;3(15):210. PMID: 26488006.26488006
57 Kubica AW, Brewer JD. Melanoma in immunosuppressed patients. Mayo Clin Proc. 2012;87(10):991-1003. PMID: 23036673.23036673
58 Brewer JD, Christenson LJ, Weaver AL, . Malignant melanoma in solid transplant recipients: collection of database cases and comparison with surveillance, epidemiology, and end results data for outcome analysis. Arch Dermatol. 2011;147(7):790-6. PMID: 21768478.21768478
59 Berg D, Otley CC. Skin cancer in organ transplant recipients: Epidemiology, pathogenesis, and management. J Am Acad Dermatol. 2002;47(1):1-17. PMID: 12077575.12077575
60 Euvrard S, Kanitakis J, Claudy A. Skin cancers after organ transplantation. N Engl J Med. 2003;348(17):1681-91. PMID: 12711744.12711744
61 Silverberg MJ, Leyden W, Warton EM, . HIV infection status, immunodeficiency, and the incidence of non-melanoma skin cancer. J Natl Cancer Inst. 2013;105(5):350-60. PMID: 23291375.23291375
62 Armstrong BK, English DR. Epidemiologic studies. In: Balch CM, Houghton AN, Milton GW, Sober AJ, Soong S-J, editors. Cutaneous melanoma. 2nd ed. Philadelphia: JB Lippincott; 1992.
63 International Agency for Research on Cancer. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans: Solar and Ultraviolet Radiation. Lyon, France: 1992.
64 Oliveria SA, Saraiya M, Geller AC, . Sun exposure and risk of melanoma. Arch Dis Child. 2006;91(2):131-8. PMID: 16326797.16326797
65 Whiteman DC, Whiteman CA, Green AC. Childhood sun exposure as a risk factor for melanoma: a systematic review of epidemiologic studies. Cancer Causes Control. 2001;12(1):69-82. PMID: 11227927.11227927
66 International Agency for Research on Cancer. Agents classified by the IARC Monographs, Volumes 1-114. Lyon, France [2016 Jan]. http://monographs.iarc.fr/ENG/Classification/index.php.
67 Council on Environmental Health Section on Dermatology, Balk SJ. Ultraviolet radiation: a hazard to children and adolescents. Pediatrics. 2011;127(3):588-97. PMID: 21357336.21357336
68 U.S. Preventive Services Task Force. Final Recommendation Statement: Skin Cancer: Counseling. [2016 January 26]. http://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/skin-cancer-counseling.
69 Boniol M, Autier P, Boyle P, . Cutaneous melanoma attributable to sunbed use: systematic review and meta-analysis. BMJ. 2012;345:e4757. PMID: 22833605.22833605
70 Colantonio S, Bracken MB, Beecker J. The association of indoor tanning and melanoma in adults: systematic review and meta-analysis. J Am Acad Dermatol. 2014;70(5):847-57 e1-18. PMID: 24629998.24629998
71 Veierod MB, Adami HO, Lund E, . Sun and solarium exposure and melanoma risk: effects of age, pigmentary characteristics, and nevi. Cancer Epidemiol Biomarkers Prev. 2010;19(1):111-20. PMID: 20056629.20056629
72 Cust AE, Armstrong BK, Goumas C, . Sunbed use during adolescence and early adulthood is associated with increased risk of early-onset melanoma. Int J Cancer. 2011;128(10):2425-35. PMID: 20669232.20669232
73 Lazovich D, Isaksson Vogel R, Weinstock MA, . Association Between Indoor Tanning and Melanoma in Younger Men and Women. JAMA Dermatol. 2016;152(3):268-75. PMID: 26818409.26818409
74 Wehner MR, Shive ML, Chren MM, . Indoor tanning and non-melanoma skin cancer: systematic review and meta-analysis. BMJ. 2012;345:e5909. PMID: 23033409.23033409
75 Ferrucci LM, Vogel RI, Cartmel B, . Indoor tanning in businesses and homes and risk of melanoma and nonmelanoma skin cancer in 2 US case-control studies. J Am Acad Dermatol. 2014;71(5):882-7. PMID: 25062934.25062934
76 Fischer AH, Wang TS, Yenokyan G, . Association of Indoor Tanning Frequency With Risky Sun Protection Practices and Skin Cancer Screening. JAMA Dermatol. 2016. PMID: 27732686.27732686
77 Heckman CJ, Munshi T, Darlow S, . The association of tanning behavior with psycho-tropic medication use among young adult women. Psychol Health Med. 2016;21(1):60-6. PMID: 26068581.26068581
78 Heckman CJ, Cohen-Filipic J, Darlow S, . Psychiatric and addictive symptoms of young adult female indoor tanners. Am J Health Promot. 2014;28(3):168-74. PMID: 23621780.23621780
79 Petit A, Lejoyeux M, Reynaud M, . Excessive indoor tanning as a behavioral addiction: a literature review. Curr Pharm Des. 2014;20(25):4070-5. PMID: 24001299.24001299
80 Lin SW, Wheeler DC, Park Y, . Prospective study of ultraviolet radiation exposure and risk of cancer in the United States. Int J Cancer. 2012;131(6):E1015-23. PMID: 22539073.22539073
81 Walls AC, Han J, Li T, . Host risk factors, ultraviolet index of residence, and incident malignant melanoma in situ among US women and men. Am J Epidemiol. 2013;177(9):997-1005. PMID: 23579556.23579556
82 Wu S, Cho E, Li WQ, . History of Severe Sunburn and Risk of Skin Cancer Among Women and Men in 2 Prospective Cohort Studies. Am J Epidemiol. 2016;183(9):824-33. PMID: 27045074.27045074
83 Ransohoff KJ, Ally MS, Stefanick ML, . Impact of residential UV exposure in childhood versus adulthood on skin cancer risk in Caucasian, postmenopausal women in the Women's Health Initiative. Cancer Causes Control. 2016;27(6):817-23. PMID: 27153844.27153844
84 Lin SW, Wheeler DC, Park Y, . Prospective study of ultraviolet radiation exposure and mortality risk in the United States. Am J Epidemiol. 2013;178(4):521-33. PMID: 23863757.23863757
85 Green AC, Williams GM, Logan V, . Reduced melanoma after regular sunscreen use: randomized trial follow-up. J Clin Oncol. 2011;29(3):257-63. PMID: 21135266.21135266
86 International Agency for Research on Cancer Working Group on artificial ultraviolet light and skin cancer. The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: A systematic review. Int J Cancer. 2007;120(5):1116-22. PMID: 17131335.17131335
87 Boniol M, Autier P, Boyle P, . Correction: Cutaneous melanoma attributable to sunbed use: systematic review and meta-analysis. BMJ. 2012;345:e8503. PMID: 22833605.22833605
88 National Conference of State Legislatures. Indoor tanning restrictions for minors - a state-by-state comparison. Washington, DC [2016 Jan 14]. http://www.ncsl.org/research/health/indoor-tanning-restrictions.aspx.
89 Wei-Passanese EX, Han J, Lin W, . Geographical variation in residence and risk of multiple nonmelanoma skin cancers in US women and men. Photochem Photobiol. 2012;88(2):483-9. PMID: 22211791.22211791
90 Xiang F, Lucas R, Hales S, . Incidence of nonmelanoma skin cancer in relation to ambient UV radiation in white populations, 1978-2012: empirical relationships. JAMA Dermatol. 2014;150(10):1063-71. PMID: 25103031.25103031
91 Wu S, Han J, Vleugels RA, . Cumulative ultraviolet radiation flux in adulthood and risk of incident skin cancers in women. Br J Cancer. 2014;110(7):1855-61. PMID: 24595003.24595003
92 de Maleissye MF, Beauchet A, Saiag P, . Sunscreen use and melanocytic nevi in children: a systematic review. Pediatr Dermatol. 2013;30(1):51-9. PMID: 22994908.22994908
93 Green A, Williams G, Neale R, . Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet. 1999;354(9180):723-9. PMID: 10475183.10475183
94 Lazovich D, Vogel RI, Berwick M, . Melanoma risk in relation to use of sunscreen or other sun protection methods. Cancer Epidemiol Biomarkers Prev. 2011;20(12):2583-93. PMID: 22016471.22016471
95 Heurung AR, Raju SI, Warshaw EM Adverse reactions to sunscreen agents: epidemiology, responsible irritants and allergens, clinical characteristics, and management. Dermatitis. 2014;25(6):289-326. PMID: 25384223.25384223
96 Linos E, Keiser E, Fu T, . Hat, shade, long sleeves, or sunscreen? Rethinking US sun protection messages based on their relative effectiveness. Cancer Causes Control. 2011;22(7):1067-71. PMID: 21637987.21637987
97 Koster B, Thorgaard C, Philip A, . Prevalence of sunburn and sun-related behaviour in the Danish population: a cross-sectional study. Scand J Public Health. 2010;38(5):548-52. PMID: 20484310.20484310
98 Milne E, Simpson JA, Johnston R, . Time spent outdoors at midday and children's body mass index. Am J Public Health. 2007;97(2):306-10. PMID: 17194858.17194858
99 Foley P, Nixon R, Marks R, . The frequency of reactions to sunscreens: results of a longitudinal population-based study on the regular use of sunscreens in Australia. Br J Dermatol. 1993;128(5):512-8. PMID: 8504041.8504041
100 Institute of Medicine. Dietary Reference Intakes for Calcium and Vitamin D. Ross AC, Taylor CL, Yaktine AL, Del Valle HB, editors. Washington, DC: The National Academies Press; 2011.
101 Andersen R, Brot C, Jakobsen J, . Seasonal changes in vitamin D status among Danish adolescent girls and elderly women: the influence of sun exposure and vitamin D intake. Eur J Clin Nutr. 2013;67(3):270-4. PMID: 23388663.23388663
102 Brot C, Vestergaard P, Kolthoff N, . Vitamin D status and its adequacy in healthy Danish perimenopausal women: relationships to dietary intake, sun exposure and serum parathyroid hormone. Br J Nutr. 2001;86 Suppl 1:S97-103. PMID: 11520426.11520426
103 Burgaz A, Akesson A, Michaelsson K, . 25-hydroxyvitamin D accumulation during summer in elderly women at latitude 60 degrees N. J Intern Med. 2009;266(5):476-83. PMID: 19570054.19570054
104 Touvier M, Deschasaux M, Montourcy M, . Determinants of vitamin D status in Caucasian adults: influence of sun exposure, dietary intake, sociodemographic, lifestyle, anthropometric, and genetic factors. J Invest Dermatol. 2015;135(2):378-88. PMID: 25211176.25211176
105 Forrest KY, Stuhldreher WL Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011;31(1):48-54. PMID: 21310306.21310306
106 Marks R, Foley PA, Jolley D, . The effect of regular sunscreen use on vitamin D levels in an Australian population. Results of a randomized controlled trial. Arch Dermatol. 1995;131(4):415-21. PMID: 7726582.7726582
107 Jayaratne N, Russell A, van der Pols JC Sun protection and vitamin D status in an Australian subtropical community. Prev Med. 2012;55(2):146-50. PMID: 22634425.22634425
108 Linos E, Keiser E, Kanzler M, . Sun protective behaviors and vitamin D levels in the US population: NHANES 2003-2006. Cancer Causes Control. 2012;23(1):133-40. PMID: 22045154.22045154
109 U.S. Department of Health and Human Services. The Surgeon General's Call to Action to Prevent Skin Cancer. Washington, D.C.: U.S. Department of Health and Human Services, Office of the Surgeon General; 2014.
110 British Association of Dermatologists, Cancer Research UK, Diabetes UK, . Consensus Vitamin D position statement. National Health Service; 2010.
111 Mead MN Benefits of sunlight: a bright spot for human health. Environ Health Perspect. 2008;116(4):A160-7. PMID: 18414615.18414615
112 American Cancer Society. Cancer Prevention & Early Detection Facts & Figures 2015-2016. Atlanta: American Cancer Society; 2015.
113 American Academy of Dermatology, AAD Association. Position Statement on Vitamin D. American Academy of Dermatology; 2009.
114 U.S. Preventive Services Task Force. Final Recommendation Statement: Vitamin D Deficiency: Screening, 2014. [2016 Jan 15]. http://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/vitamin-d-deficiency-screening.
115 Hoel DG, Berwick M, de Gruijl FR, . The risks and benefits of sun exposure 2016. Dermatoendocrinol. 2016;8(1):e1248325. PMID: 27942349.27942349
116 Razzaque MS. Sunlight exposure: Do health benefits outweigh harm? J Steroid Biochem Mol Biol. 2016. PMID: 27645314.27645314
117 Al Mheid I, Patel RS, Tangpricha V, . Vitamin D and cardiovascular disease: is the evidence solid? Eur Heart J. 2013;34(48):3691-8. PMID: 23751422.23751422
118 Hidayat R, Setiati S, Soewondo P. The association between vitamin D deficiency and type 2 diabetes mellitus in elderly patients. Acta Med Indones. 2010;42(3):123-9. PMID: 20724765.20724765
119 van der Rhee H, Coebergh JW, de Vries E. Is prevention of cancer by sun exposure more than just the effect of vitamin D? A systematic review of epidemiological studies. Eur J Cancer. 2013;49(6):1422-36. PMID: 23237739.23237739
120 Jelinek GA, Marck CH, Weiland TJ, . Latitude, sun exposure and vitamin D supplementation: associations with quality of life and disease outcomes in a large international cohort of people with multiple sclerosis. BMC Neurol. 2015;15:132. PMID: 26243188.26243188
121 Ganji V, Milone C, Cody MM, . Serum vitamin D concentrations are related to depression in young adult US population: the Third National Health and Nutrition Examination Survey. Int Arch Med. 2010;3:29. PMID: 21067618.21067618
122 Modan-Moses D, Levy-Shraga Y, Pinhas-Hamiel O, . High prevalence of vitamin D deficiency and insufficiency in adolescent inpatients diagnosed with eating disorders. Int J Eat Disord. 2015;48(6):607-14. PMID: 25130505.25130505
123 Daraghmeh AH, Bertoia ML, Al-Qadi MO, . Evidence for the vitamin D hypothesis: The NHANES III extended mortality follow-up. Atherosclerosis. 2016;255:96-101. PMID: 27855294.27855294
124 Chowdhury R, Kunutsor S, Vitezova A, . Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348:g1903. PMID: 24690623.24690623
125 Berwick M, Armstrong BK, Ben-Porat L, . Sun exposure and mortality from melanoma. J Natl Cancer Inst. 2005;97(3):195-9. PMID: 15687362.15687362
126 Berwick M, Begg CB, Fine JA, . Screening for cutaneous melanoma by skin self-examination. J Natl Cancer Inst. 1996;88(1):17-23. PMID: 8847720.8847720
127 Paddock LE, Lu SE, Bandera EV, . Skin self-examination and long-term melanoma survival. Melanoma Res. 2016;26(4):401-8. PMID: 26990272.26990272
128 Weinstock MA, Lott JP, Wang Q, . Skin Biopsy Utilization and Melanoma Incidence among Medicare Beneficiaries. Br J Dermatol. 2016. PMID: 27639256.27639256
129 U.S. Department of Health and Human Services. Healthy People 2020. Washington, DC: U.S. Department of Health and Human Services, Office of Disease Prevention and Health Promotion [2016 Jan 14]. https://www.healthypeople.gov/2020/topics-objectives/topic/cancer/objectives.
130 Holman DM, Berkowitz Z, Guy GP, Jr., . The association between demographic and behavioral characteristics and sunburn among U.S. adults - National Health Interview Survey, 2010. Prev Med. 2014;63:6-12. PMID: 24589442.24589442
131 CDC. Sunburn and sun protective behaviors among adults aged 18-29 years--United States, 2000-2010. MMWR Morb Mortal Wkly Rep. 2012;61(18):317-22. PMID: 22572977.22572977
132 Buller DB, Cokkinides V, Hall HI, . Prevalence of sunburn, sun protection, and indoor tanning behaviors among Americans: review from national surveys and case studies of 3 states. J Am Acad Dermatol. 2011;65(5 Suppl 1):S114-23. PMID: 22018060.22018060
133 Coups EJ, Stapleton JL, Hudson SV, . Sun protection and exposure behaviors among Hispanic adults in the United States: differences according to acculturation and among Hispanic subgroups. BMC Public Health. 2012;12:985. PMID: 23153104.23153104
134 Jacobsen AA, Galvan A, Lachapelle CC, . Defining the Need for Skin Cancer Prevention Education in Uninsured, Minority, and Immigrant Communities. JAMA Dermatol. 2016;152(12):1342-7. PMID: 27626892.27626892
135 Glenn BA, Lin T, Chang LC, . Sun protection practices and sun exposure among children with a parental history of melanoma. Cancer Epidemiol Biomarkers Prev. 2015;24(1):169-77. PMID: 25587110.25587110
136 Geller AC, Brooks DR, Colditz GA, . Sun protection practices among offspring of women with personal or family history of skin cancer. Pediatrics. 2006;117(4):e688-94. PMID: 16585282.16585282
137 Wehner MR, Chren MM, Nameth D, . International prevalence of indoor tanning: a systematic review and meta-analysis. JAMA Dermatol. 2014;150(4):390-400. PMID: 24477278.24477278
138 Hamidi R, Cockburn MG, Peng DH. Prevalence and predictors of skin self-examination: prospects for melanoma prevention and early detection. Int J Dermatol. 2008;47(10):993-1003. PMID: 18986343.18986343
139 Robinson JK, Rigel DS, Amonette RA. What promotes skin self-examination? J Am Acad Dermatol. 1998;38(5):752-7. PMID: 9591820.9591820
140 Coups EJ, Stapleton JL, Hudson SV, . Skin cancer surveillance behaviors among US Hispanic adults. J Am Acad Dermatol. 2013;68(4):576-84. PMID: 23182066.23182066
141 Olsen CM, Thompson BS, Green AC, . Sun Protection and Skin Examination Practices in a Setting of High Ambient Solar Radiation: A Population-Based Cohort Study. JAMA Dermatology. 2015;151(9):982-90. PMID: 26039788.26039788
142 Glenn BA, Chen KL, Chang LC, . Skin Examination Practices Among Melanoma Survivors and Their Children. J Cancer Educ. 2016. PMID: 26856594.26856594
143 Mujumdar UJ, Hay JL, Monroe-Hinds YC, . Sun protection and skin self-examination in melanoma survivors. Psychooncology. 2009;18(10):1106-15. PMID: 19142859.19142859
144 Akamine KL, Gustafson CJ, Davis SA, . Trends in sunscreen recommendation among US physicians. JAMA Dermatol. 2014;150(1):51-5. PMID: 24005847.24005847
145 Feldman SR, Fleischer AB, Jr. Skin examinations and skin cancer prevention counseling by US physicians: a long way to go. J Am Acad Dermatol. 2000;43(2 Pt 1):234-7. PMID: 10906644.10906644
146 Oliveria SA, Christos PJ, Marghoob AA, . Skin cancer screening and prevention in the primary care setting: national ambulatory medical care survey 1997. J Gen Intern Med. 2001;16(5):297-301. PMID: 11359547.11359547
147 Saraiya M, Frank E, Elon L, . Personal and clinical skin cancer prevention practices of US women physicians. Arch Dermatol. 2000;136(5):633-42. PMID: 10815857.10815857
148 Balk SJ, O'Connor KG, Saraiya M. Counseling parents and children on sun protection: a national survey of pediatricians. Pediatrics. 2004;114(4):1056-64. PMID: 15466105.15466105
149 Bandi P, Cokkinides VE, Weinstock MA, . Physician sun protection counseling: prevalence, correlates, and association with sun protection practices among US adolescents and their parents, 2004. Prev Med. 2010;51(2):172-7. PMID: 20478331.20478331
150 American College of Obstetricians and Gynecologists. Committee opinion no. 626: the transition from pediatric to adult health care: preventive care for young women aged 18-26 years. Obstet Gynecol. 2015;125(3):752-4. PMID: 25730254.25730254
151 Wilkinson J, Bass C, Diem S, . Preventive Services for Children and Adolescents. Bloomington, MN: Institute for Clinical Systems Improvement; 2013.
152 Royal Australian College of General Practitioners. Guidelines for preventive activities in general practice 8th edition. East Melbourne, Australia: Royal Australian College of General Practitioners; 2012.
153 National Institute for Health and Care Excellence. Skin cancer prevention: public health guideline. National Institute for Health and Care Excellence; 2011.
154 International Agency for Research on Cancer. IARC Handbooks of Cancer Prevention Volume 5: Sunscreens. Lyon, France: World Health Organization; 2001.
155 Guide to Community Preventive Services. Cancer Prevention and Control: Skin Cancer Prevention. Community Preventive Services Task Force; 2014.
156 Community Preventive Services Task Force. Community-wide Interventions to Prevent Skin Cancer: Recommendation of the Community Preventive Services Task Force. Am J Prev Med. 2016;51(4):540-1. PMID: 27647054.27647054
157 American Academy of Dermatology. AADA provides input on skin cancer screening recommendation. American Academy of Dermatology [2017 January 3]. https://www.aad.org/media/news-releases/aada-provides-input-on-skin-cancer-screening-recommendation.
158 Skin Cancer Foundation. Early Detection and Self Exams. Skin Cancer Foundation [2017 January 3]. http://www.skincancer.org/skin-cancer-information/early-detection.
159 Royal Australian College of General Practitioners. Skin checks. Royal Australian College of General Practitioners [2017 January 3]. http://www.racgp.org.au/afp/2012/july/skin-checks/.
160 U.S. Preventive Services Task Force. Counseling to Prevent Skin Cancer: Recommendations and Rationale. Rockville, MD: Agency for Healthcare Research and Quality; 2003.
161 Bibbins-Domingo K, Grossman DC, Curry SJ, . Screening for Skin Cancer: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(4):429-35. PMID: 27458948.27458948
162 Wernli KJ, Henrikson NB, Morrison CC, . Screening for Skin Cancer in Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;316(4):436-47. PMID: 27458949.27458949
163 Veritas Health Innovation. Covidence Systematic Review Software. Melbourne, Australia.
164 United Nations Development Programme. Human Development Index: 2015 Rankings. United Nations Development Programme [2015]. http://hdr.undp.org/en/2015-report.
165 Krist AH, Baumann LJ, Holtrop JS, . Evaluating Feasible and Referable Behavioral Counseling Interventions. Am J Prev Med. 2015;49(3 Suppl 2):S138-49. PMID: 26296548.26296548
166 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
167 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589.15615589
168 Crane LA, Deas A, Mokrohisky ST, . A randomized intervention study of sun protection promotion in well-child care. Prev Med. 2006;42(3):162-70. PMID: 16376977.16376977
169 Glasser A, Shaheen M, Glenn BA, . The sun sense study: an intervention to improve sun protection in children. Am J Health Behav. 2010;34(4):500-10. PMID: 20218761.20218761
170 Gritz ER, Tripp MK, Peterson SK, . Randomized controlled trial of a sun protection intervention for children of melanoma survivors. Cancer Epidemiol Biomarkers Prev. 2013;22(10):1813-24. PMID: 24097199.24097199
171 Norman GJ, Adams MA, Calfas KJ, . A randomized trial of a multicomponent intervention for adolescent sun protection behaviors. Arch Pediatr Adolesc Med. 2007;161(2):146-52. PMID: 17283299.17283299
172 Crane LA, Asdigian NL, Baron AE, . Mailed intervention to promote sun protection of children: a randomized controlled trial. Am J Prev Med. 2012;43(4):399-410. PMID: 22992358.22992358
173 Glanz K, Steffen AD, Schoenfeld E, . Randomized trial of tailored skin cancer prevention for children: the Project SCAPE family study. J Health Commun. 2013;18(11):1368-83. PMID: 23806094.23806094
174 Geller AC, Emmons KM, Brooks DR, . A randomized trial to improve early detection and prevention practices among siblings of melanoma patients. Cancer. 2006;107(4):806-14. PMID: 16832795.16832795
175 Glanz K, Schoenfeld ER, Steffen A. A randomized trial of tailored skin cancer prevention messages for adults: Project SCAPE. Am J Public Health. 2010;100(4):735-41. PMID: 20167900.20167900
176 Glanz K, Volpicelli K, Jepson C, . Effects of tailored risk communications for skin cancer prevention and detection: the PennSCAPE randomized trial. Cancer Epidemiol Biomarkers Prev. 2015;24(2):415-21. PMID: 25432953.25432953
177 Glazebrook C, Garrud P, Avery A, . Impact of a multimedia intervention “Skinsafe” on patients' knowledge and protective behaviors. Prev Med. 2006;42(6):449-54. PMID: 16580059.16580059
178 Heckman CJ, Darlow SD, Ritterband LM, . Efficacy of an Intervention to Alter Skin Cancer Risk Behaviors in Young Adults. Am J Prev Med. 2016. PMID: 26810358.26810358
179 Hillhouse J, Turrisi R, Stapleton J, . A randomized controlled trial of an appearance-focused intervention to prevent skin cancer. Cancer. 2008;113(11):3257-66. PMID: 18937268.18937268
180 Janda M, Neale RE, Youl P, . Impact of a video-based intervention to improve the prevalence of skin self-examination in men 50 years or older: the randomized skin awareness trial. Arch Dermatol. 2011;147(7):799-806. PMID: 21422325.21422325
181 Mahler HI, Kulik JA, Gerrard M, . Long-term effects of appearance-based interventions on sun protection behaviors. Health Psychol. 2007;26(3):350-60. PMID: 17500622.17500622
182 Manne S, Jacobsen PB, Ming ME, . Tailored versus generic interventions for skin cancer risk reduction for family members of melanoma patients. Health Psychol. 2010;29(6):583-93. PMID: 21090893.21090893
183 Prochaska JO, Velicer WF, Redding C, . Stage-based expert systems to guide a population of primary care patients to quit smoking, eat healthier, prevent skin cancer, and receive regular mammograms. Prev Med. 2005;41(2):406-16. PMID: 15896835.15896835
184 Prochaska JO, Velicer WF, Rossi JS, . Multiple risk expert systems interventions: impact of simultaneous stage-matched expert system interventions for smoking, high-fat diet, and sun exposure in a population of parents. Health Psychol. 2004;23(5):503-16. PMID: 15367070.15367070
185 Rat C, Quereux G, Riviere C, . Targeted melanoma prevention intervention: a cluster randomized controlled trial. Ann Fam Med. 2014;12(1):21-8. PMID: 24445100.24445100
186 Vuong K, Trevena L, Bonevski B, . Feasibility of a GP delivered skin cancer prevention intervention in Australia. BMC Fam Pract. 2014;15:137. PMID: 25070692.25070692
187 Weinstock MA, Risica PM, Martin RA, . Melanoma early detection with thorough skin self-examination: the “Check It Out” randomized trial. Am J Prev Med. 2007;32(6):517-24. PMID: 17533068.17533068
188 Youl PH, Soyer HP, Baade PD, . Can skin cancer prevention and early detection be improved via mobile phone text messaging? A randomised, attention control trial. Prev Med. 2015;71:50-6. PMID: 25524612.25524612
189 Glanz K, Yaroch AL, Dancel M, . Measures of sun exposure and sun protection practices for behavioral and epidemiologic research. Arch Dermatol. 2008;144(2):217-22. PMID: 18283179.18283179
190 Rosenberg DE, Norman GJ, Sallis JF, . Covariation of adolescent physical activity and dietary behaviors over 12 months. J Adolesc Health. 2007;41(5):472-8. PMID: 17950167.17950167
191 Patrick K, Calfas KJ, Norman GJ, . Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Pediatr Adolesc Med. 2006;160(2):128-36. PMID: 16461867.16461867
192 Baker J, Finch L, Soyer HP, . Mediation of improvements in sun protective and skin self-examination behaviours: results from the healthy text study. Psychooncology. 2016;25(1):28-35. PMID: 26555140.26555140
193 Hillhouse J, Turrisi R, Stapleton J, . Effect of seasonal affective disorder and pathological tanning motives on efficacy of an appearance-focused intervention to prevent skin cancer. Arch Dermatol. 2010;146(5):485-91. PMID: 20479295.20479295
194 Abar BW, Turrisi R, Hillhouse J, . Preventing skin cancer in college females: heterogeneous effects over time. Health Psychol. 2010;29(6):574-82. PMID: 20939638.20939638
195 Walton AE, Janda M, Youl PH, . Uptake of skin self-examination and clinical examination behavior by outdoor workers. Arch Environ Occup Health. 2014;69(4):214-22. PMID: 24499249.24499249
196 Janda M, Youl P, Neale R, . Clinical skin examination outcomes after a video-based behavioral intervention: analysis from a randomized clinical trial. JAMA Dermatology. 2014;150(4):372-9. PMID: 24553807.24553807
197 Paskett E, Thompson B, Ammerman AS, . Multilevel Interventions To Address Health Disparities Show Promise In Improving Population Health. Health Aff (Millwood). 2016;35(8):1429-34. PMID: 27503968.27503968
198 Stange KC, Breslau ES, Dietrich AJ, . State-of-the-art and future directions in multilevel interventions across the cancer control continuum. J Natl Cancer Inst Monogr. 2012;2012(44):20-31. PMID: 22623592.22623592
199 Watson M, Garnett E, Guy GP, . The Surgeon General's Call to Action to Prevent Skin Cancer. Washington DC 2014.
200 Sandhu PK, Elder R, Patel M, . Community-wide Interventions to Prevent Skin Cancer: Two Community Guide Systematic Reviews. Am J Prev Med. 2016;51(4):531-9. PMID: 27647053.27647053
201 Finch L, Janda M, Loescher LJ, . Can skin cancer prevention be improved through mobile technology interventions? A systematic review. Prev Med. 2016;90:121-32. PMID: 27374946.27374946
202 Weinstock MA, Rossi JS, Redding CA, . Sun protection behaviors and stages of change for the primary prevention of skin cancers among beachgoers in southeastern New England. Ann Behav Med. 2000;22(4):286-93. PMID: 11253439.11253439
203 Rossi J, Redding C, Weinstock M. Technology based interventions for skin cancer prevention. Ann Behav Med. 1998;20:S180.
204 Weinstock MA, Rossi JS, Redding CA, . Randomized controlled community trial of the efficacy of a multicomponent stage-matched intervention to increase sun protection among beachgoers. Prev Med. 2002;35(6):584-92. PMID: 12460526.12460526