# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jennifer Lin, MD, MCR, Director of the Kaiser Permanente Research Affiliates Evidence-Based Practice Center, Jennifer Croswell, MD, MPH, and Tracy Wolff, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Deborah Bowen, PhD, for expert consultation; Smyth Lai, MLS, for creating and conducting literature searches; Nadia Redmond for assistance with meta-analyses; Aruna Kamineni, PhD, MPH, for contributions to the research plan; Vina Graham and Michelle Chapdelaine, MPH, for administrative assistance; Gabrielle Gunderson, MPH, for project management assistance; Michael Goldstein, MD, Monika Janda, PhD, DeAnn Lazovich, PhD, Sancy Leachman, MD, PhD, and Yelena Wu, PhD, for expert feedback on the draft report; and the Centers for Disease Control and Prevention Skin Cancer Workgroup and Christopher Bengson, MD, MHS, for expert review of this report.