# Chapter 4 Discussion

## Summary of Evidence

We included 21 trials that reported the impact of primary care-relevant behavioral interventions on skin cancer outcomes, sunburn, sun protection behaviors, and skin self-exam. The bulk of the evidence available was for the behavioral outcomes of sun protection behaviors and skin self-exam; evidence was much more limited for indoor tanning and for health outcomes. Most trials were of fair quality, and though there were several common intervention components across studies, measures were heterogeneous enough to preclude pooling of results. A summary of the evidence is located in Error! Reference source not found..

The evidence base has expanded substantially since the previous evidence review published in 2012: 14 of the 21 included studies are new since the previous evidence review. All nine studies reporting direct evidence for KQ1 are new since the previous review, as are all four studies of children aged 3–10, both studies of harms of interventions, and two of three studies of relatives of melanoma survivors. All studies assessing skin self-exam exclusively are new since the previous USPSTF evidence review on skin cancer screening.

### Intermediate and Health Outcomes

All studies for KQ1 represent new evidence. Across nine fair- to good-quality pediatric and adult trials, the body of evidence suggests no consistent association between interventions and sunburn frequency in adults or children. In the single pediatric trial that suggested an intervention effect, it was for nonsevere sunburn only and not for more severe, blistering sunburns that are the hallmark risk factor for skin cancer later in life. One study in young adults suggested an intervention was associated with improvement in red or painful sunburns, but constitutes the only data for this age group. Baseline rates of sunburn were variable and low in some but not all populations (for example, in 4–10 year olds and their parents) so a floor effect may be possible in some studies.

The body of evidence for nevi or cancer outcomes is limited to two fair-quality studies. Based on one trial (n=867), an intervention promoting sun protection does not alter nevi counts in white children aged 3–10 over 3-year followup relative to controls. Based on another fair-quality trial among adults (n=1356), an intervention to promote skin self-exam is not associated with increased atypical nevi, non-melanoma skin cancer, or melanoma detection over 12 months compared to controls. No studies of sun protection-focused interventions among adults assessed skin cancer outcomes.

Studies were limited by short followup times (up to 3 years for children, up to 2 years for adults, 3–6 months in most studies), so it is possible that time frames were not sufficient to allow for observation of nevi or cancer events. However, sunburn outcomes would be observable within a relatively short study period, especially when outcome assessments occur at the end of summer, as most of these studies did.

### Behavioral Outcomes

The current body of evidence builds on and supports the previous review's findings, adding evidence among children aged 3–10 from four new studies. Small to moderate effects of behavioral interventions on increased sun protection behaviors were observed in predominantly white or fair-skinned children aged 0–3, children aged 3–10, adolescents, young adults, and less consistently, adults compared to control populations. Though individual sun protection behaviors were inconsistently reported, sunscreen use was the most commonly improved behavior, followed by intentional sun exposure or outdoor tanning in adults and use of protective clothing in children. The clinical significance of these incremental increases in behaviors is unclear.

We found few consistent patterns according to age or population risk factors. Increased sun protection behaviors among intervention groups were observed relative to control groups in studies of all age groups, though overall, adult trial results were more mixed and fewer studies demonstrated an intervention effect. None of the trials among relatives of melanoma survivors (one in children and two in adults) found a significant effect on sun protection behavior, but the reasons for this are unclear. Family members of melanoma patients did not report higher levels of baseline sun protection behaviors relative to other included trials, except for sun avoidance in children in one study. Family members may be receiving skin cancer prevention information from multiple sources, or may require specific messaging. Study design limitations also may be a factor: two studies provided standard, non-tailored interventions to the control group and found increases in sun protection behavior in both groups. In the study of adult siblings of melanoma patients, the control group's “usual care” may have involved skin cancer screening, as melanoma patients were encouraged to invite their siblings to make screening appointments.

Intervention effects were not demonstrated for indoor tanning in young adults in two of three studies, but appearance-focused messages appeared to show an intervention effect in a single study of female university students who already were using indoor tanning. In the two studies finding no effect, baseline rates of indoor tanning were low; however, focusing solely on reducing indoor tanning may represent a missed opportunity for primary prevention.

Skin self-exam interventions were focused on adults, likely because skin cancer risk increases with increasing age. Relative to control conditions, interventions can increase rates of skin self-exam in young adults and adults. However, health benefits may be more likely if skin self-exam is repeated over time. No trial exceeded 12 months, and repeated measures were reported in only two trials with mixed results. One trial among men over age 50 (n=930) found that skin self-exam peaked at 6 months in the intervention group and returned to levels similar to the control group's at 12 months. The other study with repeated measures (n=1356) found sustained increases at 12 months.

### Harms of Behavioral Interventions

Harms of behavioral interventions were rarely reported. Based on a single fair-quality trial, skin procedures may increase in the first six months after a skin self-exam-focused trial without a corresponding increase in cancer detection. Given the paucity of evidence for favorable association between skin self-exam and melanoma mortality or between skin self-exam interventions (discussed in Chapter 1) and cancer detection (discussed in KQ1), increased biopsy resulting from skin self-exam remains a potential harm. However, there was insufficient evidence to draw firm conclusions.

No included trials reported evidence on paradoxically increased sun exposure accompanying sun protection behaviors, and no trials assessed vitamin D levels in participants. Skin cancer worry did not differ between groups at followup in one adult study focused on risk assessment and sun protection counseling, but baseline values for worry were not reported.

## Observational Evidence on the Association Between Skin Cancer Prevention Behaviors and Health Outcomes

In the case of sparse data from trials on the direct link between interventions and health outcomes, assessment of observational evidence for associations between the behaviors that might result from interventions and health outcomes may help contextualize the findings. As a contextual question, we searched for new studies that would suggest different or more precise findings since those reported in the previous review and recommendation statement on UV exposure and skin cancer and other health outcomes, and between skin self-exam and skin cancer outcomes (described in Chapter 1).

### UV Exposure and Health Outcomes

In its 2012 recommendation, the USPSTF found convincing evidence linking UV radiation exposure during childhood and youth to a moderately increased risk for melanoma later in life (range of OR 1.8–4.4); and for adults, adequate evidence linking recreational UV radiation exposure to an increase in melanoma risk (range of OR 1.3–5.0) based on case control and cohort studies of fair to good quality.^2, 68^ Our scan for more recent observational studies generally confirms this evidence. Overall, recent observational evidence provides even stronger evidence for the risks of indoor tanning use^40, 69-79^ and continued mixed evidence on the association between ambient sun exposure and melanoma development.^80-84^ Followup data from a randomized trial included in the previous evidence review suggest a protective effect for sunscreen use and risk of invasive, but not in situ, melanoma development in adults.^85^ One large population-based study, also confirming the previous evidence review's findings, found increased risk of both melanoma incidence and melanoma death with increasing quartile of UV exposure, but a beneficial association for increasing UV exposure quartile and reduced risk of several other cancers.^80, 84^ Reduced physical activity and Vitamin D deficiency, potential harms of sun protection behavior, have not been detected in observational studies. Increased sunscreen use was associated with increased sunburns in cross-sectional studies,^96, 97^ suggesting a potential false reassurance pathway, but no included trials found evidence for this potential harm.

Reductions in UV exposure could prospectively reduce skin cancer risk. However, the best evidence would likely come from trials such as those included in this review, and no data beyond 3 years was available.

### Skin Self-Exam and Health Outcomes

The 2009 USPSTF review on skin cancer screening found no new evidence on the effectiveness of either skin examination by a physician or skin self-exam in reducing the morbidity or mortality of skin cancer, but discussed one fair-quality case-control study.^4, 5^ A 20-year followup study of this same population published in 2016 found no beneficial association between skin self-exam and melanoma death. However, a more expansive measure of skin awareness did appear to be a significant independent predictor of melanoma death. As part of our systematic evidence review (KQs 4 and 5) we searched for trials or cohort studies examining the link between skin self-exam and health outcomes or harms and found no studies.

## Intervention Considerations Across Age Groups

There were few patterns suggesting that specific intervention components, settings, or delivery inform intervention effectiveness. Interventions that found an effect on sun protection behaviors were typically, though not always, 12 months or longer, with more mail, phone, or virtual contact points with participants. Consistent with behavioral theory, this may suggest that higher intensity interventions or those that reinforce messages over time may improve intervention effectiveness. Interventions finding an effect were typically multi-component, with varying combinations of in-person counseling, phone counseling, virtual contact, print media, video, and sun protection aids or skin self-exam aids. The impact of physician counseling was difficult to assess. The two pediatric studies involving physician counseling also included other components such as print materials and sunscreen samples, and found improvements in sun protection behaviors relative to controls, but the two adult studies involving physician counseling—both single session interventions—found no intervention effect.

The two trials using solely electronic intervention delivery methods were effective for improving multiple behaviors compared to control conditions: one year of text messages and a self-administered online interactive education program improved sun protection, outdoor tanning, and skin self-exam. Similarly, the single study that focused on both parent and child sun protection behaviors also found an intervention effect for sun protection behaviors. If confirmed in other studies, family-focused and electronically-delivered interventions, perhaps combined with in-person counseling may represent promising approaches for future interventions.

In most trials of pediatric and adult populations, outcome assessments were timed to coincide with the end of summer or fall, which increases recall potential for recent summer behavior. However, most trials also found that sun protection and sunburn increased in both intervention and control groups between baseline and followup assessments. This likely highlights seasonal fluctuations in sun protection behaviors, and demonstrates the importance of including control groups. However, since many studies used minimal or non-tailored interventions for control groups, the effect of these comparison interventions, and therefore the precise impact of the main intervention, cannot adequately be assessed.

## Applicability to U.S. Health Care

In general, study populations were likely applicable to white or fair-skinned U.S. primary health care populations. All six pediatric studies and eleven of 16 adult studies were conducted in the United States. Most participants were white, representing the population with the highest risk of melanoma. However, it is unknown whether these findings also apply to people of color, who have less favorable skin cancer mortality outcomes compared with fair-skinned populations. From the limited information reported, a fairly broad representation of socioeconomic status was present in the included study populations. Most pediatric studies' interventions were focused primarily on parents as the primary facilitator of their child's skin cancer prevention behavior. Although one study intervened directly with adolescents age 11-15, overall the findings may be most applicable to younger children.

All intervention components are theoretically implementable from or referable from primary care, though the ability of individual clinicians and practices to initiate intervention components likely varies widely. Single-session risk assessment and physician counseling may be the most easily translated into clinical practice,^1^ though no intervention effect was noted for this very low-dose intervention based on two non-U.S. studies. Components such as extended mailed interventions or text messaging campaigns may be more difficult to implement in clinical practice, though may be more easily implemented if non-physician team members are involved.

These findings should be interpreted in the context of prevalent cultural messaging about skin cancer prevention. Many people may be first exposed to sun protection messages, particularly around sunscreen use, in their daily lives rather than in a clinical encounter. Multi-component or multi-level strategies increasingly are considered best practice for cancer prevention interventions;^156, 197, 198^ important target areas may include policy and community-level or occupational interventions, such as mass media campaigns, built environments to increase shaded areas, or free sunscreen dispensers at public beaches.^155, 156, 199, 200^

## Limitations of Included Studies

We found few studies focused on adolescents, young adults or parents of children under age 3. Men over age 50, who as a group have the highest skin cancer risk, were the focus of only a single study. Evidence on health outcomes was limited.

In general, included trials were well-conducted, with adequate study designs that tested interventions developed with a theoretical basis and reporting some measure of practitioner training, intervention fidelity and/or adherence. All trials focused either on at-risk populations or included a tailoring component, allowing specific messaging for participants. Most studies reported seasonal considerations of intervention design, timing, and outcome assessment. However, several limitations should be considered. First, the widespread use of composite measures for behavioral outcome assessment represents a limitation with respect to efforts to assess links between interventions and clinical outcomes. While a composite measure may ease understanding of a series of behaviors that are likely practiced in concert (for example, sunglasses, sunscreen, and hat use) and small changes are likely encouraging, an incremental change of a fraction of a point on a scale is more challenging to interpret clinically. Further, there was considerable heterogeneity in the types of scales used, the level of adaptation of existing measures, time frames assessed within items, and length of followup. Second, very few studies reported frequencies or absolute values that would allow assessment of behavior change over time or meta-analysis. Third, behavioral outcomes were assessed via self-report, introducing inherent response biases. Social desirability bias is possible; participants in either group might give a response they feel would be received favorably. Self-reported measures are also dependent on accurate participant recall, which can fluctuate even over very short time periods.

Included trials also had limitations with respect to reported health outcomes data. Given that skin cancer can take 10-20 years to develop, detecting improvements in skin cancer outcomes may have limited feasibility. Sunburn was assessed via heterogeneous self-reported measures and therefore was subject to bias. Direct observation of sunburn may be possible but is challenging to measure because of its impermanence and may require specialized equipment for true objective measurement. In the single study that looked at skin cancer outcomes, no confirmation with pathology reports was mentioned; further, the authors reported no attempt to identify skin cancer outcomes in people not reporting a skin procedure.

## Limitations of Our Approach

We only included interventions that were conducted in or referable from primary care, and excluded both multilevel interventions in which the impact of a primary care component could not be assessed and populations of current survivors of skin cancer. We did not include interventions taking place in worksites, schools, or other community settings, since those are reviewed by the Community Preventive Services Task Force. Thus we are unable to assess the impact of primary care-relevant interventions relative to interventions in other contexts.

We limited our review to randomized trials and controlled trials. We were limited by the heterogeneity of the measures reported, and chose not to pool results. We were able to calculate standardized effect sizes for only a subset of studies. We limited our assessment of harms to those reported in included interventions. We excluded outcomes of attitudes, intentions, barriers, self-efficacy and other psychosocial measures that may mediate or moderate the impact of interventions; we acknowledge that these measures reflect attention to the theoretical mechanisms through which interventions can impact behavior. We did not analyze message framing (for example, gain or loss frame) or nuanced differences between messages beyond what was reported by trial authors.

## Future Research Needs

Interventions focused on skin cancer prevention in young adults, who are most likely to practice indoor or outdoor tanning, are needed. Interventions that demonstrate increased sun protection practices in relatives of melanoma survivors, another population at increased risk of melanoma, represent a gap in the body of evidence. Studies of multilevel interventions with a primary care component, designed to allow assessment of the primary care component, also would strengthen the body of evidence. In particular, studies that explore a primary care role in counseling frequent users of indoor tanning would provide valuable evidence given that indoor tanning behavior may have an addictive component. Studies of racially and ethnically diverse populations are needed, as are studies intervening with adolescents, young adults, and parents of preschool children.

The body of evidence would be strengthened by studies of sufficient power to observe longer-term health outcomes in trial cohorts, particularly those with interventions focused on promoting sun protection behavior, and by measures of maintenance of sun protection behaviors after trial completion. Ideally, measurement of sun exposure, sunburn, precursor lesions, and cancer should be objective and thoroughly reported. Studies with behavioral outcomes would be strengthened by use of standardized measures, frequency measures in addition to scales, and by complete and transparent reporting of unadjusted data. Investigations into the potential harms and benefits of skin self-exam, ideally using standardized measures, would further strengthen the body of evidence.

A summary of current ongoing studies is provided in Appendix C. Studies of mobile and electronic methods of intervention delivery increasingly are being conducted;^201^ evidence on how these interventions, if successful, can be integrated and maintained in primary care settings also will provide relevant evidence.

## Conclusion

The body of evidence on the impact of behavioral interventions has increased substantially since the previous review and generally reaffirms its findings, adding limited new evidence on intermediate and health outcomes and for behavioral outcomes in children aged 3–10. The current evidence base suggests that behavioral interventions can increase sun protection behavior in both pediatric and, less consistently, in adult populations; but the clinical significance of these increases is unclear. There is no consistent evidence that interventions are associated with improved sunburn frequency in children or adults. Interventions can increase skin self-exam in adults relative to control conditions, and may lead to increased skin procedures without detecting additional atypical nevi or skin cancers.

Figure 1 Analytic Framework and Key Questions

1. Does counseling patients in skin cancer prevention improve a) intermediate outcomes (sunburn or precursor lesions) or b) skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality)?
2. Do primary care-relevant counseling interventions improve skin cancer prevention behaviors (e.g., reduced sun exposure, sunscreen use, use of protective clothing, avoidance of indoor tanning, and skin self-examination)?
3. What are the harms of counseling interventions for skin cancer prevention (e.g., increased time in the sun, reduced physical activity, vitamin D deficiency, and anxiety)?
4. What is the association between skin self-examination and skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality)?^*^
5. What are the harms of skin self-examination?^*^

* Key Questions (KQs) 4 and 5 will only be addressed systematically if there is sufficient evidence from KQs 1 to 3 that behavioral counseling increases skin self-examination behavior.

The analytic framework depicts the five Key Questions (KQs). Specifically, it illustrates the following questions: whether counseling patients in skin cancer prevention improves intermediate outcomes (sunburn or precursor lesions) or skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality) (KQ1); whether primary care-relevant counseling interventions improve skin cancer prevention behaviors (e.g., reduced sun exposure, sunscreen use, use of protective clothing, avoidance of indoor tanning, and skin self-examination) (KQ2); the harms of counseling interventions for skin cancer prevention (e.g., increased time in the sun, reduced physical activity, vitamin D deficiency, and anxiety) (KQ3); the association between skin self-examination and skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality) (KQ4); and the harms of skin self-examination (KQ5).

Figure 2 Standardized Mean Difference of Sun Protection Composite Scores in Children (KQ2)

Abbreviations: SMD = standardized mean differences; BL = baseline; IG = intervention group; CG = control group

Note: Five of six trials are included in this forest plot. Studies differ in terms of study population, length of followup and composite scores. Crane 2006 was not included in forest plot because people were recruited at birth and therefore had no baseline data.

Figure 2 is a forest plot depicting the standardized mean difference of change (Cohen's d) in sun protection composite scores in children in 5 of the 6 included studies. The differences ranged from 0 (no effect) to 0.96 (in favor of the intervention). The forest plot shows variation in that the Crane 2006 study was not included in the forest plot because people were recruited at birth and therefore had no baseline data.

Figure 3 Standardized Mean Difference of Sun Protection Composite Scores in Adults (KQ2)

Abbreviations: SMD = standardized mean differences; BL = baseline; IG = intervention group; CG = control group

Note: Ten of twelve trials reporting sun protection composite scores are included in this forest plot. Studies differ in terms of study population, length of followup and composite scores. One study was excluded from forest plot due to differences in outcomes reported.

Figure 3 is a forest plot depicting the standardized mean differences in change (Cohen's d) in composite sun protection scores. The differences ranged from -0.46 (in favor of the control group) to 0.57 (in favor of the intervention group) and between 0.10 and 0.20 for most studies.

Figure 4 Odds of Conducting Skin Self-Exam in Adults (KQ2)

Abbreviations: SSE = skin self-exam, OR = odds radio, IG = intervention group, CG = control group

Note: Seven of 11 studies are included in this forest plot. Studies differ in terms of study population, length of followup and type of skin self-exam (total, any, partial). Four studies were excluded from forest plot due to differences in outcomes reported.

Figure 4 is a forest plot depicting the odds of conducting a skin self-examination in adults. Of the 9 studies that could be included, 6 maintained a significant impact favoring intervention. Odds ratios ranged from 1.16 for a measure of any skin self-examination over 5 months to 2.64 for any skin self-examination.

Table 1 Description of Included Trials

Trial (k=21) | Country | Population | N Randomized | % Followup | Followup (months) | % Female | Age, Mean (SD) or Category, % | Skin Cancer Risk Factors (%) | SES Indicators (%) | Included for KQ(s) | In previous review
Children and adolescents
Crane 2006^168^ Fair Kaiser Kids Sun Care | USA | Children age <1 | 728 | 75.3 | 36 | 49.7 | 0-6 mo | White: 81.9 (fair white skin: 43.7) Blonde/red hair: 20.3 Blue/grey eyes: 74.9 | College degree or more: 42.4 Income ≥$75K/yr: 16.1 | 2 | X
Crane 2012^172^ Fair | USA | Children age 6 | 867^a^ | 70.8 | 36 | 52.5 | 6 (NR) | White: 100.0 (fair white skin: 51.8) Blonde/red hair: 72.3 Blue eyes: 48.7 Painful burn/no tan: 12.1 | College degree or more: 75.1 Income ≥$100K/yr: 35.7 | 1, 2
Glanz 2013^173^ Good Project SCAPE (family) | USA | Children ages 4-10 at increased skin cancer risk | 1301 | 80.5 | 4 | 49.0 | 7.1 (1.1) | White: 65.6 High skin cancer risk: 38.3^b^ Moderate skin cancer risk: 61.7^b^ | College degree or more: 40.2 Married or partnered: 88.7 Employed full-time: 42.7 Income ≥$40K/yr: 73.0 | 1, 2
Glasser 2010^169^ Fair Sun Sense | USA | Children ages 3-10 | 197 | 71.6 | 3 | 48.2 | 3-4: 33.5 5-7: 34.0 8-10: 30.5 | White: 44.7 | NR | 2
Gritz 2013^170^ Fair | USA | Children (age ≤12) of melanoma survivors | 340 | 83.0 | 4 | 49.1 | 7.3 (3.9) | White: 98.2 Sun sensitivity: 2.29 (0.69)^c^ Family history of skin cancer: 100.0 | College degree or more: 78.2 Married: 91.5 | 1, 2
Norman 2007^171,190,191^ Fair SunSmart | USA | Adolescents ages 11-15 | 819 | 80.1 | 24 | 53.5 | 12.7 (1.3) | White: 58.4 High skin sensitivity: 25.2^d^ Moderate skin sensitivity: 44.0^d^ | College degree or more: 66.4 | 2 | X
Adults and young adults
Geller 2006^174^ Fair | USA | Adult (age ≥18) siblings of melanoma patients | 494 | 63.6 | 12 | 53.4 | 18-50: 58.3 ≥51: 41.7 | White: 100.0 (fair skin: 84.8) Family history of skin cancer: 100.0 | At least some college: 76.8 Health insurance: 96.0 Has PCP: 86.0 | 2 | X
Glanz 2010^175^ Fair Project SCAPE (adult) | USA | Adults ages 20-65 at increased skin cancer risk | 724 | 82.3 | 4 | 77.5 | 41.7 (11.0) | White: 80.2 High skin cancer risk: 36.6^b^ Moderate skin cancer risk: 63.4^b^ | College degree or more: 47.5 Income ≥$40K/yr: 63.5 | 1, 2
Glanz 2013^173^ Good Project SCAPE (family) | USA | Parents of children ages 4-10 | 1301 | 80.5 | 4 | >90.0 | NR | White: 68.2 | College degree or more: 40.2 Married or partnered: 88.7 Employed full-time: 42.7 Income ≥$40K/yr: 73.0 | 1, 2
Glanz 2015^176^ Fair PennSCAPE | USA | Adults (age range 18-91) at increased skin cancer risk | 206 | 93.2 | 3 | 73.4 | 55.2 (15.2) | White: 100.0 High skin cancer risk: 60.9^b^ Moderate skin cancer risk: 39.1^b^ NMSC personal history: 15.6 Family history of skin cancer: 43.2 | College degree or more: 70.5 Married or partnered: 68.1 Employed: 57.8 Income >$80K/yr: 60.7 | 1, 2
Glazebrook 2006^177^ Fair Skinsafe | UK | Adults with ≥1 melanoma risk factor | 589 | 77.9 | 6 | 80.3 | 38.3 (14.8) | NR^e^ | College degree or more: 52.5 Professional/nonmanual job: 41.3 | 2 | X
Heckman 2016^178^ Fair UV4.me | USA | Young adults ages 18-25 at increased skin cancer risk | 965 | 65.2 | 3 | 66.1 | 21.8 (2.2) | White: 85.7 Fair skin: 86.3 High/moderate skin cancer risk: 100.0^b^ Family history of skin cancer: 35.2 | College degree or more: 22.1 Employed full-time: 18.1 Receives public assistance: 18.8 | 1, 2
Hillhouse 2008^179,193,194^ Fair | USA | University students ages 17-21 who use indoor tanning | 430 | 95.8 | 6 | 100.0 | 18.6 (0.8) | Always burns, never tans: 7.4^f^ Usually burns, then tans: 23.5^f^ | Family SES “about average”: 55.5 | 2 | X
Janda 2011^180,195^ Fair Skin awareness study | Australia | Adult men ages 50-90 | 930 | 89.5 | 13 | 0.0 | 50-90: 100.0% | Fair/very fair skin: 62.3 Red/fair/blonde hair: 27.0 Blue/grey eyes: 46.6 High skin sensitivity: 6.1^g^ | College degree or more: 22.6 Employed full-time: 41.8 Income >$80K/yr: 25.0 Rural: 49.0 | 2
Mahler 2007^181^ Fair | USA | Adult university students ages 18-44 | 133 | 80.0 | 12 | 80.5 | 20.1 (3.4) | White: 45.0 Family history of skin cancer: 27.1 | College students: 100.0 | 2 | X
Manne 2010^182^ Fair | USA | Adult (age ≥20) FDRs of melanoma patients | 443 | 72.7 | 12 | 63.0 | 47.6 (13.2) | White: 98.2 Family history of skin cancer: 100.0 | College degree or more: 62.1 Married: 70.4 Income ≥$140K/yr: 16.2 Health insurance: 93.8 | 2
Prochaska 2005^183^ Fair | USA | Adults | 5407 | 74.0 | 24 | 69.9 | 44.7 (12.7) | White: 96.7 | Education, mean yrs: 14.5± 3.2 | 2 | X
Prochaska 2004^184^ Fair | USA | Adults | 2460 | 68.9 | 24 | 75.0 | 42.5 (5.5) | White: 92.0 | Education, mean yrs: 14.0±3.2 Married or partnered: 80.0 | 2 | X
Rat 2014^185^ Fair Coparime | France | Adults at increased melanoma risk | 217 | 79.7 | 5 | 76.0 | 43.2 (16.1) | High skin cancer risk: 100.0^h^ | College degree or more: NR^i^ | 1, 2, 3
Vuong 2014^186,j^ Fair | Australia | Adults age ≥18 | 108 | 70.0 | 13 | 59.0 | <50: 59.0 ≥50: 41.0 | High skin cancer risk: 76.0^b^ Moderate skin cancer risk: 18.0^b^ | College degree or more: 70.0 Married or partnered: 63.0 | 2
Weinstock 2007^187^ Fair Check It Out | USA | Adults age ≥18 | 1356 | 66.4 | 12 | 58.3 | 53.2 (14.8) | High skin cancer risk: 24.0^b^ Moderate skin cancer risk: 36.0^b^ | College degree or more: 38.0 Employed: 61.0 | 1, 2, 3
Youl 2015^188,192^ Good Healthy Text | Australia | Adults ages 18-42 | 546 | 93.7 | 12 | 67.4 | 31.9 (6.2) | Fair or very fair skin: 65.8 Red hair: 4.0 Blue/gray eyes: 37.0 Tending to burn not tan: 26.0 Never tans: 15.0 | College degree or more: 71.4 Married or partnered: 70.1 Employed full-time: 57.3 Private health insurance: 64.8 | 1, 2

a Crane 2012 randomized 867 participants but only reported results for white non-Hispanic participants (n=677). The authors report that results for white non-Hispanic participants were similar to results for all participants.

b As assessed by the brief skin cancer risk assessment tool (BRAT), which includes questions about family history, number of large moles, freckles, and sun sensitivity (skin color, natural hair color, ease of tanning, burning).

c Mean (SD). Sun sensitivity index computed from questions on eye color, hair color, and skin; scores range from 1 (high sensitivity) to 4 (low sensitivity)

d Skin sensitivity determined by previously validated instrument with scores ranging 1-10 based on skin reaction to sun, untanned skin color, and hair color.

e In intervention practices, patients invited to participate in IG if they had ≥1 characteristic identified by research as a risk factor for melanoma (red hair, multiple moles, history of sunburn as a child, freckling, family history of melanoma, fair sun-sensitive skin). CG participants selected to match skin and demographic profile of IG participants.

f Study reports Fitzpatrick skin types: type I (always burns, never tans): 7.4%; type II (usually burns, then tans): 23.5%; type III (may burn, tans well): 40.8%; type IV (rarely burns, tans well): 25.8%; type V (very rarely burns, tans well, brown skin): 2.4%.

g Defined as never tanning, only burning or freckling.

h Assessed via the Self-Assessment Melanoma Risk Score (SAMscore). Domains of SAMscore are skin type, freckles, moles, severe blistering sunburn in childhood, lived more than 1 year in high-sunshine country; personal history.

i Study reports there were no significant differences between IG and CG for highest level of education attained.

j The Vuong 2014 study was a controlled clinical trial (not randomized) of patients attending either an intervention clinic or a control clinic. All other included studies were randomized clinical trials or cluster randomized clinical trials.

Abbreviations: k=number of studies; SD=standard deviation, SES=socioeconomic status, KQ=key question, NR=not reported, PCP=primary care provider, NMSC=nonmelanoma skin cancer, FDR=first-degree relative, yr=year.

Table 2 Summary of Outcomes Assessed, by Study

| N randomized | % White | Followup (months) | KQ1 Sunburn | KQ1 Nevi/cancer | KQ2 Sun protection | KQ2 Sunscreen | KQ2 Indoor tanning | KQ2 SSE | KQ3 Harms
Children and adolescents
Crane 2006^168^ (Kaiser Kids Sun Care) | 728 | 81.9 | 36 | . | . | X | X | . | . | .
Crane 2012^172^ | 867 | 100.0 | 36 | X | X | X | X | . | . | .
Glanz 2013^173^ (Project SCAPE [family], children) | 1301 | 65.6 | 4 | X | . | X | X | . | X | .
Glasser 2010^169^ (Sun Sense) | 197 | 44.7 | 3 | . | . | X | X | . | . | .
Gritz 2013^170^ | 340 | 98.2 | 4 | X | . | X | X | . | . | .
Norman 2007^171, 190, 191^ (SunSmart) | 819 | 58.4 | 24 | . | . | X | X | . | . | .
Adults and young adults
Geller 2006^174^ | 494 | 100.0 | 12 | . | . | . | X | . | X | .
Glanz 2010^175^ (Project SCAPE [adult]) | 724 | 80.2 | 4 | X | . | X | X | . | X | .
Glanz 2013^173^ (Project SCAPE [family], parents) | 1301 | 68.2 | 4 | X | . | X | X | . | X | .
Glanz 2015^176^ (PennSCAPE) | 206 | 100.0 | 3 | X | . | X | X | . | X | .
Glazebrook 2006^177^ (Skinsafe) | 589 | NR | 6 | . | . | X | . | . | X | .
Heckman 2016^178^ (UV4.me) | 965 | 85.7 | 3 | X | . | X | X | X | X | .
Hillhouse 2008^179, 193, 194^ | 430 | NR | 6 | . | . | . | . | X | . | .
Janda 2011^180, 195^ (Skin awareness study) | 930 | NR | 13 | . | . | . | . | . | X | .
Mahler 2007^181^ | 133 | 45.0 | 12 | . | . | X | . | . | . | .
Manne 2010^182^ | 443 | 98.2 | 12 | . | . | X | . | . | X | .
Prochaska 2004^184^ | 2460 | 96.7 | 24 | . | . | X | X | . | . | .
Prochaska 2005^183^ | 5407 | 92.0 | 24 | . | . | X | X | . | . | .
Rat 2014^185^ (Coparime) | 217 | NR | 5 | X | . | X | . | X | X | X
Vuong 2014^186,a^ | 108 | NR | 13 | . | . | X | . | . | . | .
Weinstock 2007^187^ (Check It Out) | 1356 | NR | 12 | . | X | . | . | . | X | X
Youl 2015^188, 192^ (Healthy Text) | 546 | NR | 12 | X | . | X | . | . | X | .

“X” indicates outcome was assessed; “.” Indicates outcome was not assessed

a The Vuong 2014 study was a controlled clinical trial (not randomized). All other included studies were randomized clinical trials or cluster randomized clinical trials.

Abbreviations: k=number of studies, KQ=key question.

Table 3 Description of Interventions, by Population

Trial | Study name | N randomized | Population | Intervention component (number of sessions/mailings) | Intervention length | Linked to primary care | Counseling | SSE or SPB aids | Tailored feedback | Comparison
Children and adolescents
Crane 2006^168^ | Kaiser Kids Sun Care | 728 | Children age <1 | PCP counseling (4); print materials for parents promoting child sun protection (4); sunscreen samples; hat | 36 mo | X | X | X | | Usual care
Crane 2012^172^ | | 867 | Children age 6 | Tailored mailings (14): newsletters for parents/children promoting child sun protection | 36 mo | X | | | X | Assessment only
Glanz 2013^173^ | Project SCAPE (family) | 1301 | Children ages 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting children's and parents' sun protection | 1 mo | | | | X | Minimal intervention (standard mailing)
Glasser 2010^169^ | Sun Sense (Slip Slop Slap) | 197 | Children ages 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 1 day | X | X | X | | No intervention (plain T-shirt only)
Gritz 2013^170^ | | 340 | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 5 mo | | | | | Minimal intervention (standard mailing)
Norman 2007^171, 190, 191^ | SunSmart | 819 | Adolescents ages 11-15 | PCP counseling using tailored risk information (1); phone counseling (4); mailed materials promoting sun protection; sunscreen samples | 18 mo | X | X | X | X | Attention control (physical activity)
Adults and young adults
Geller 2006^174^ | | 494 | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 5 mo | | X | | X | Usual care
Glanz 2010^175^ | Project SCAPE (adult) | 724 | Adults ages 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 1 mo | X | | X | X | Minimal intervention Mailed nontailored materials 1x
Glanz 2013^173^ | Project SCAPE (family) | 1301 | Children ages 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting children's and parents' sun protection | 1 mo | | | | X | Minimal intervention (standard mailing)
Glanz 2015^176^ | PennSCAPE | 206 | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 1.5 mo | X | | X | X | Minimal intervention (standard mailings)
Glazebrook 2006^177^ | Skinsafe | 589 | Adults with ≥1 melanoma risk factor | Interactive online program (1) with tailored feedback promoting sun protection and SSE | 1 day | X | | | X | Usual care
Heckman 2016^178^ | UV4.me | 965 | Young adults ages 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | NA | | | | X | Assessment only
Hillhouse 2008^179, 193, 194^ | | 430 | Female university students ages 17-21 who use indoor tanning | Standard print materials (1) promoting appearance-based alternatives to indoor tanning | 1 day | | | | | Assessment only
Janda 2011^180, 195^ | Skin awareness study | 930 | Adult men ages 50-90 | Standard mailing (1) promoting SSE (video, SSE aids; print materials); reminder postcards | 1 mo | | | X | | Minimal intervention SSE guide Print materials
Mahler 2007^181^ | | 133 | Adult university students ages 18-44 | Facial photos of participant with simulated sun damage (1); appearance-focused video promoting sun protection (1) | 1 day | | | | X | Assessment only
Manne 2010^182^ | | 443 | Adult (age ≥20) FDRs of melanoma patients | Tailored mailings (3) promoting sun protection and SSE; phone counseling (1) | 1.5 mo | | X | | X | Minimal intervention Mailed nontailored materials 3x Informational phone call 1x
Prochaska 2005^183^ | | 5407 | Adults | Tailored mailings (3) promoting sun protection | 12 mo | X | | | X | Assessment only
Prochaska 2004^184^ | | 2460 | Adults | Tailored mailings (3) promoting sun protection | 12 mo | | | | X | Assessment only
Rat 2014^185^ | Coparime | 217 | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 1 day | X | X | | X | Assessment only
Vuong 2014^186^ | | 108 | Adults age ≥18 | PCP counseling using tailored feedback; print materials (1) | 1 day | X | X | | X | Assessment only
Weinstock 2007^187^ | Check It Out | 1356 | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 6 mo | X | X | X | X | Attention control (diet)
Youl 2015^188, 192^ | Healthy Text | 546 | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 mo | | | | X | Attention control (physical activity)

Abbreviations: SSE=skin self-exam, SPB=sun protection behavior, PCP=primary care provider, mo=months, CG1=control group 1, CG2=control group 2, 1x=one time, 3x=3 times, FDR=first-degree relative, IG1=intervention group 1, IG2=intervention group 2.

Table 4 Detailed Intervention Descriptions, by Population

Study | Population | Intervention description | Comparison group description | Theoretical basis
Children and adolescents
Crane 2006^168^ Kaiser Kids Sun Care | Children age <1 (through parents) | In the single study focused on children age 0-3, the intervention was primary-care based. In intervention group clinics, the study placed prompts in each child's medical record to discuss sun protection at 2, 6, 18, and 36 months; providers were given materials and asked to provide them to parents at well-child visits. Materials included education materials and sunscreen samples; a child sun hat and sunglasses were also given. Exit interviews from a subsample of study participants suggested that the intervention components were delivered successfully approximately 40%-75% of the time; the lowest reported component was discussion of protective clothing (29%-44% of parents reporting PCP discussed). | Control group clinics practiced usual care, though all clinics received regular information about the study at departmental meetings. Parents in both groups were assessed via survey at baseline, 1, 2, and 3 years. | HBM
Crane 2012^172^ | Children age 6 (through parents) | In this primary care-linked, home-based study, parents received 14 newsletters over 3 years. Newsletters were mailed each spring in 2-week intervals; most were aimed at parents, but mailings in years 2 and 3 included material for children. Early mailings contained review of skin cancer and its causes; later mailings included tailored information specific to each child, sun protection strategies for reducing risk, and suggestions for overcoming barriers. Newsletters contained interactive materials, and were written at a 6th grade or below reading level. Newsletters for children included age appropriate information and activities. All newsletters were pilot tested. Skin exams were conducted each summer, (setting not reported); parents also received a report with of the number of nevi counted. | Control group parents participated in data collection only; those that completing skin exams received a written report of the results. | PAPM
Glanz 2013^173^ Project SCAPE (families) | Children ages 4-10 at increased skin cancer risk; parents of children ages 4-10 | The Project SCAPE family trial, which built on the earlier adult trial (Glanz 2010^175^), recruited children and their parents from a convenience sample of schools and recreation programs in Hawaii and Long Island. The intervention consisted of three packets mailed at 2-week intervals containing personalized risk feedback and recommendations, interactive skin cancer education materials, a family fun guide (containing games and stories about safe sun practices for parents and kids to complete together), suggestions for overcoming barriers, and reminders to engage in preventive practices. [Both child and parent outcomes are reported and included in this report.] | The comparison group received a single mailing containing a non-tailored, publicly available skin cancer prevention brochure for children, a tip sheet on sunscreen, hats, shade and shirts, and a bookmark encouraging child skin examination. | HBM, SCT
Glasser 2010^169^ Sun Sense | Children ages 3-10 | In the Sun Sense study, parent-child pairs were approached in the waiting room of a pediatric clinic waiting room. Intervention group parents received a 10-15 minute presentation from a public health graduate student; children were included when age-appropriate. The presentation discussed the prevalence of skin cancer, its relationship to sun exposure, and promoted 3 sun protection practices (shirt, sunscreen, hat). Families received a take-home package, including a video for children with “Slip Slop Slap” messaging, a shirt, a bucket hat, a large container of broad-spectrum sunscreen, and a brochure from the American Academy of Dermatology. | The comparison group received no intervention and participated in assessments only. | Health Behavior Framework (SCT, TPB, HBM, TTM, Social Influence Theory)
Gritz 2013^170^ | Children (age ≤12) of melanoma survivors | In this mailed-intervention study, parents in the intervention group (who were all melanoma patients) received three mailings sent over 5 months. Each mailing contained both print materials and either a 10 minute DVD (first mailing); magnet (second mailing); or a children's activity booklet (third mailing). The DVD showed melanoma survivors and their families discussing the importance of child sun protection, including overcoming barriers. The booklets contained testimonials from melanoma survivors, sun protection expectations and why/how they protect their children. The children's activity booklet contained puzzles, songs, and quizzes about sun protection. | Parents in the control group, also melanoma patients, received publicly available brochures in the same mailing schedule. Brochure topics were sun protection, physical activity and nutrition. | HBM, SCT
Norman 2007^171,190,191^ SunSmart | Adolescents ages 11-15 | In the SunSmart study, adolescents were recruited through 45 primary care providers from 6 clinics in southern California. At baseline and 12 months, Adolescents in the intervention group participated in a 20-minute computer-based assessment before their primary care appointment, which generated a tailored feedback report on the adolescent's stage of change and self-efficacy provided to both the adolescent and their physician. The physician provided brief counseling (2-3 min) counseling based on the report. At 3, 6, 15, and 18 months the adolescent received phone assessments with a health counselor followed by mailings including tailored feedback from phone sessions, tip sheets, and sunscreen samples. | The control group was an attention control, with a similarly structured intervention focused on adoption and maintenance of physical activity and healthy eating behaviors. | TTM
Adults and young adults
Geller 2006^174^ | Adult (age ≥18) siblings of melanoma patients | In this study, siblings of recently-diagnosed melanoma patients were recruited through melanoma patients seen at 4 multidisciplinary cancer management teaching hospitals in the Boston area. Intervention group participants were provided an initial motivational and goal-setting telephone interview session delivered by a health educator and tailored print materials targeting behaviors in relation to skin self-examination, physician screening, and sun protection. The telephone interview and subsequent print materials were tailored based on responses to a survey conducted at baseline. | Siblings in the control group received usual care; that is, the melanoma patient was encouraged to invite their sibling make an appointment to get screened. Siblings in the control group also participated in all assessments at baseline, 6, and 12 months. | SCT, TPB, HBM, PAPM, TTM
Glanz 2010^175^ Project SCAPE (adults) | Adults ages 20-65 at increased skin cancer risk | The Project SCAPE adult trial recruited participants from the waiting rooms of outpatient primary care practices in Honolulu, Hawaii, and Long Island, New York. The intervention consisted of three packets mailed at 2-week intervals containing personalized risk feedback and recommendations, UV self-monitoring aids, skin self-examination instructions and practice tools, and skin cancer prevention and detection information. | The control group received a single mailing with a standard sun safety booklet, a sunscreen use tip sheet, and a bookmark encouraging skin self-examination. | HBM, SCT
Glanz 2015^176^ PennSCAPE | Adults (age range 18-91) at increased skin cancer risk | The PennSCAPE trial, which was an extension of the original Project SCAPE trial (Glanz 2010^175^), recruited participants from the waiting room of a primary care practice in Pennsylvania. The intervention consisted of three separate mailings sent at 2-week intervals. The first mailing contained a personalized skin cancer profile based on participants' self-reported risk factors; the second mailing contained skin self-exam instructions, feedback on participants' self-reported SSE practices, a body map to track mole changes, and a bookmark with tailored sun protection reminders; the third mailing contained a booklet encouraging clinical skin exam and a tip sheet with personalized sunscreen recommendations. | The control group received three standard informational mailings about skin cancer, skin self-exam, and sun protection. | HBM, SCT
Glazebrook 2006^177^ Skinsafe | Adults with ≥1 melanoma risk factor | In this single-session, primary care-based study conducted in the U.K., participants were recruited in primary care practices. Based on patient phenotype, doctors or nurses prescribed the Skinsafe computer program, which the patient then self-completed at a dedicated workstation in the practice waiting room. The interactive computer program included animation, photographs, and text to inform users about risk of sun exposure, skin risk factors, early signs of melanoma, ways to reduce risk, how to check skin for suspicious lesions, and provided individualized feedback about personal risk factors. The intervention was conducted in 1998. | The control group was selected to match the phenotypic characteristics of enrolled intervention group participants. They did not receive an intervention and participated in baseline and 6 months followup. | HBM
Heckman 2016^178^ UV4.me | Young adults ages 18-25 at increased skin cancer risk | In this web-based study, U.S. young adults age 18-25 were recruited online via web banner ads. Participants were randomized to 1 of 3 conditions: a tailored, interactive web program called UV4.me (IG1); a public website condition (IG2); or an assessment only control group (CG). IG1 participants received periodic reminders to access and complete the intervention modules. The UV4.me intervention included 12 modules on topics such as indoor tanning, UV and health, skin cancer, sunscreen, and skin exams. Each module took about 10 minutes to review and included a goal-setting section. The public website group (IG2) received automated email reminders to visit the Skin Cancer Foundation website, which provided information on various skin cancer topics, such as prevention, true stories, news, and healthy lifestyles. On average, the 70.4% of IG1 participants who accessed the UV4.me website visited it more than 5 times, and the 84% of IG2 participants who accessed the Skin Cancer Foundation website visited it twice. | The assessment control group received no intervention and participated in assessments only. | Integrative Model for Behavioral Prediction
Hillhouse 2008^179, 193, 194^ | University students ages 17-21 who use indoor tanning | This single-session study of an appearance-focused intervention recruited female indoor tanners from two US universities. The intervention consisted of a professionally produced 24-page booklet with sections on the history of tanning, tanning norms, effects of UV radiation, effects of indoor tanning, indoor tanning guidelines, and appearance-enhancing alternatives to indoor tanning. Participants were asked to summarize and rate each section. | The control group received no intervention and participated in assessments only. | Jaccard behavioral alternative model, TPB, HBM
Janda 2011^180, 195^ Skin Awareness | Adult men ages 50-90 | In this study of older men (50 years or older), the intervention group received a 12 minute DVD featuring a sport/TV personality which discussed what skin cancer is, risk factors for skin cancer, and explained that older men are at increased risk to develop skin cancer. Additionally the intervention group received written instructions on how to conduct a skin self-examination and a body chart diagram to record any suspicious found skin lesions, facilitate self-monitoring, and/or to aid recall when visiting a physician. The intervention group also received postcards to remind them to watch the DVD and examine their skin. | The control group received a generic self-skin examination guide and brochure, but no video, body chart, or reminder post cards. | Extended HBM
Mahler 2007^181^ | Adult university students ages 18-44 | This single-session study of an appearance-focused intervention included undergraduate students from a university in Southern California. Participants were randomized in a two-by-two factorial design, to receive either a brief video session, a UV facial photograph, both, or assessment only. The video sessions consisted of an 11-minute videotaped slideshow about photoaging of the skin due to UV exposure, effective practices for reducing photoaging, and general information about sunscreen. The UV facial photographs were taken with a modified instant camera that highlights nonuniform skin pigmentation resulting from chronic sun exposure and the resulting skin damage. Participants receiving the UV facial photographs also had natural-light instant photographs taken for comparison. Participants received course credit for their participation. | Participants were randomized in a two-by-two factorial design, to receive either a brief video session, a UV facial photograph, both, or assessment only. | HBM, TPB, PMT
Manne 2010^182^ | Adult (age ≥20) FDRs of melanoma patients | In this study of family members of patients with melanoma, the intervention group received mailed print materials and a phone call from a health educator targeting the participant's engagement with skin examination by a health care provider, skin self-examination, and sun protection habits. The print materials and phone call were specific to the study participant's age and gender, family history of melanoma, and previous knowledge of skin cancer. | The comparison group received generic print materials and a telephone call with general information on melanoma, melanoma risk, and skin examinations. | Preventive Health Model, TPM
Prochaska 2004^184^ | Adults | This study aimed to intervene on multiple risk behaviors simultaneously. Participants were recruited from a school-provided list of parents of 9th graders, and underwent a theory-based risk assessment for smoking, diet, and sun exposure. They were considered “at-risk” if they were in the precontemplation, contemplation, or preparation stage of change for at least one behavior. For each of their relevant behaviors, intervention group participants received mailed tailored feedback reports at 0, 6, and 12 months, as well as progress questionnaires to complete at 6 and 12 months. | Control group participants received no intervention and participated in assessments only. | TTM
Prochaska 2005^183^ | Adults | This study, which built on the earlier trial of multiple risk expert systems interventions (Prochaska 2004^184^), recruited participants from a list of primary care patients provided by a large health insurance organization. To be eligible, participants needed to be at-risk for one of the following behaviors: smoking, high-fat diet, sun exposure, and relapse from regular mammography. For each of their relevant behaviors, intervention participants received mailed individualized computer reports at 0, 6 and 12 months, as well as progress questionnaire to complete at 6 and 12 months. | Control group participants received no intervention and participated in assessments only. | TTM
Rat 2014^185^ | Adults at increased melanoma risk | The Cohort of Patients at Risk for Melanoma (COPARIME) was a French cluster RCT that included a single risk assessment session with PCP counseling. Participants were recruited from primary care waiting rooms and completed the Self-Assessment Melanoma Risk Score (SAMScore). Intervention group participants received a total skin exam from their PCP, counseling on melanoma, and a brochure on prevention. Both intervention and control group were assessed by phone at 5 months. | Control group participants completed the SAMScore risk assessment survey in the waiting room but received no counseling or intervention. | No theoretical basis reported
Vuong 2014^186^ | Adults age ≥18 | This single-session study took place in two general practices in Sydney, Australia. In the intervention practice, general practitioners were trained on a skin cancer risk assessment tool, advice to give patients about sun protection. Patients completed the paper-based skin cancer risk assessment tool in the waiting room before their appointment, self-scored it, and shared it with their physician. The physicians counseled patients based on their individual level of risk from the assessment and their sun protection behaviors. Intervention patients also received the SunSmart UV Alert pamphlet, which contained information about UV radiation, the UV index, and sun protection. | The control practice provided usual care, though control patients completed a skin cancer risk assessment after completing the baseline survey, and also completed the followup surveys at 1 and 13 months. | PMT
Weinstock 2007^187^ Check It Out | Adults age ≥18 | The Check-it-Out study recruited medium or high-risk adults from primary care practices in Rhode Island or Massachusetts. Participants with a scheduled visit to their PCP were invited to participate. The intervention consisted of two counseling sessions by a health educator (one in the clinic immediately before the patient's primary care appointment, one by phone) and educational materials and aids including: a booklet from the American Cancer Society, a 14-minute video on SSE, a magnet shaped as a hand mirror, a shower card with SSE instructions, a hand mirror, and a body diagram. | The attention control group received diet-focused materials, such as pamphlets, tips for diet improvement, a video, and a self-assessment tool. | TTM, HBM, SCT (SCT for control group only)
Youl 2015^188, 192^ Healthy Text | Adults age 18-42 | The Healthy Text study recruited a random sample of residents of Queensland, Australia from the electoral roll and government health insurance register. Participants were randomized to one of three groups: sun protection, skin self-exam, or attention control. Each group received one text message per week for 12 weeks, and then one text message per month for the following 9 months. The sun protection and SSE text messages contained tailored information (such as participant names and skin cancer risk factors), had a conversational tone, and focused on social support, self-efficacy, perceived environmental opportunity, goal setting, and outcome expectancies. | The attention control group received a similarly structured text messaging intervention focused on promoting physical activity. | SCT

Abbreviations: PCP=primary care provider, UV=ultraviolet, SSE=skin self-exam, RCT=randomized clinical trial, HBM=Health Belief Model; SCT=Social Cognitive Theory; PAPM=Precaution Adoption Process Model; TPB=Theory of Planned Behavior; TTM=Transtheoretical Model; PMT=Protection Motivation Theory, IG1=intervention group 1, IG2=intervention group 2, CG=control group.

Table 10 Summary of Evidence, by Population and Key Question

Key Question | No. of Studies (k), no. of obs. (n) | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Study Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence | Applicability
Children and adolescents^a^
KQ1: Intermediate and health outcomes | k=3 RCTs n=2508 (All 3 trials identified in update all in populations ages 3-10 years) | One fair-quality trial among children age 6 (n=867) found a small intervention effect for the odds of nonsevere sunburn but no differences between groups in the odds of severe sunburn or number of nevi at 3-year followup. Two other trials among children (both mean age 7) found no differences between intervention and control groups in sunburn frequency at 4-month followup. No studies reported skin cancer outcomes. | Skin cancer/nevi: NA Sunburn: Inconsistent, Imprecise | Suspected^b^ | Good: 1 Fair: 2 | Few studies overall; none in children <3 years or adolescents. Sunburn assessed by parent self-report; limited reporting of absolute values. | Skin cancer/nevi: Insufficient Sunburn: Low | Likely applicable to US primary care for predominantly fair-skinned populations, though feasibility may vary
KQ2: Behavioral outcomes | k=6 RCTs n=4252 (4 trials identified in update, all in populations ages 3-10 years) | Five of 6 trials found statistically significantly greater improvements in parent-reported sun protection composite scores in intervention participants vs control participants at 3-months to 3-years followup. Effects were observed in all age groups. Standardized effect sizes ranged from 0 to 0.96 (0.16 to 0.50 in larger trials). In general, effects on individual sun protection behaviors, including sunscreen use, were consistent within each trial. No trials reported indoor tanning use. | Sun protection: Reasonably consistent, Imprecise Indoor tanning: NA Skin self-exam: NA | Suspected^b^ | Good: 1 Fair: 5 | Limited reporting of absolute values; clinical interpretation of composite scores difficult to assess; self-reported data; heterogeneous measures and time frames. Only one study each of children <3 years and adolescents . | Low | Likely applicable to US primary care for predominantly fair-skinned populations, though feasibility may vary
KQ3: Harms of intervention | No studies | NA | NA | NA | NA | NA | Insufficient | NA
KQ4: Association between SSE and outcomes | No studies | NA | NA | NA | NA | NA | Insufficient | NA
KQ5: Harms of SSE | No studies | NA | NA | NA | NA | NA | Insufficient | NA
Adults and young adults^a^
KQ1: Intermediate and health outcomes | k=7 RCTs n=5315 (All 7 trials identified in update) | Of 6 trials, only one (n=965, 86% white, young adults mean age 22) reported a statistically significant difference in self-reported sunburns at 3-months follow-up in intervention compared to control participants. All other trials were conducted among adults with broader age ranges; none found an intervention effect. One US-based trial focused on skin-self exam promotion (n=1356) reported minimal cases of melanoma, NMSC, and atypical nevi, and no differences between groups over 12-months follow-up. | Nevi/skin cancer: NA Sunburn: Inconsistent, Imprecise | Not detected | Overall: Good: 2 Fair: 5 Cancer/nevi: Fair: 1 Sunburn: Good: 2, Fair: 4 | Skin cancer/nevi: Single study with 12- month followup, outcome assessment methods not clear Sunburn: Baseline rates low in some studies; heterogeneous self-reported measures | Skin cancer/nevi: Insufficient Sunburn: Low | Sunburn findings are likely applicable. Cancer/nevi findings possibly applicable in SSE-focused intervention populations; unclear for interventions focused on sun protection behavior or indoor tanning.
KQ2: Behavioral outcomes | k=16 15 RCTs, 1 CCT n=16,309 (10 trials identified in update) | Most trials found greater improvements in self-reported sun protection composite scores in intervention vs control participants at 3 months to 2 years followup; 6 of 12 reported statistically significant between-group differences. Sunscreen use (4 trials) and intentional outdoor exposure (3 trials) were the most frequently reported improved behaviors. There was no evidence of effect modification by age, risk factors, or intervention components. 1 of 3 trials reporting indoor tanning, a study of female young adult indoor tanners (n=430, mean age 19), found relatively smaller increases in number of indoor tanning sessions in the past 3 months in the intervention vs control conditions at 6 month followup. 9 of 11 trials showed statistically significantly increased reporting of total, partial, or any skin self-exam (SSE) in the intervention vs controls groups. 3 of the above trials were conducted in young adults (n=1528). 2 of these reported intervention effects: 1 for sun protection behavior and SSE (k=965) and 1 for indoor tanning (k=430). | Sun protection: Reasonably consistent, Imprecise Indoor tanning: Inconsistent/Imprecise SSE: Reasonably consistent/Imprecise | Not detected | Overall: Good: 2 Fair: 14 Sun protection: Good: 2 Fair: 11 Indoor tanning: Fair: 3 SSE: Good: 2 Fair: 9 | Same limitations as listed in KQ2 (Children and adolescents) | Sun protection: Low Indoor tanning: Low SSE: Moderate | Likely applicable to US primary care for predominantly fair-skinned populations; feasibility may vary
KQ3: Harms of intervention | k=2 RCTs n=1573 (both trials identified in update, both in adult populations) | Skin procedures were more common in the intervention group in one trial of SSE promotion (n=1356) at 6 months follow-up but not 12 months. Cancer worry did not differ between groups in one trial of counseling and risk assessment (n =217). None of the above trials involved young adults. | NA | Not detected | Fair: 2 | Few studies; outcome measurement not well described | Insufficient | May be applicable
KQ4: Association between SSE and outcomes | No studies | NA | NA | NA | NA | NA | Insufficient | NA
KQ5: Harms of SSE | No studies | NA | NA | NA | NA | NA | Insufficient | NA

a One study (Glanz 2013) reported outcomes for both children and adults.

b One trial (n=867) only reported results for white non-Hispanic participants (n=677).

Abbreviations: KQ=key question, EPC=evidence-based practice center, RCT=randomized clinical trial, CCT=controlled clinical trial, SSE=skin self-exam, NA=not applicable.