# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence review to update its 2012 recommendation on behavioral counseling for skin cancer prevention. This review addresses the benefits and harms associated with counseling for the primary and secondary prevention of skin cancer.

Our review differs in structure compared to the previous USPSTF review on Skin Cancer Counseling.^2^ The previous review did not include skin self-exam as a behavioral outcome. Skin self-exam was included in the 2009 USPSTF evidence review on Skin Cancer Screening,^5^ but was not included in the 2016 update,^162^ which focused solely on clinician skin exam. Also, we limited our discussion of the epidemiologic associations between sun exposure and health outcomes to contextual assessments, whereas the previous review assessed these with key questions (KQs).

## Analytic Framework and Key Questions

We developed an analytic framework with five KQs based on the previous review and a scan of the research conducted since the previous review (Error! Reference source not found.).

1. Does counseling patients in skin cancer prevention improve a) intermediate outcomes (sunburn or precursor lesions) or b) skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality)?
2. Do primary care-relevant counseling interventions improve skin cancer prevention behaviors (e.g., reduced sun exposure, sunscreen use, use of protective clothing, avoidance of indoor tanning, and skin self-examination)?
3. What are the harms of counseling interventions for skin cancer prevention (e.g., increased time in the sun, reduced physical activity, vitamin D deficiency, and anxiety)?
4. What is the association between skin self-examination and skin cancer outcomes (melanoma, squamous cell, or basal cell carcinoma incidence, morbidity, or mortality)?
5. What are the harms of skin self-examination?

Our final research plan stated that KQs 4 and 5 would be addressed systematically only if there is sufficient evidence from KQs 1 to 3 that behavioral counseling increases skin self-exam behavior. However, no studies met our inclusion criteria for KQs 4 and 5.

We also addressed one contextual question, which is described in Chapter 1: What is the association between sun exposure, sun protection behavior, indoor tanning, skin self-examination, and a) skin cancer incidence, morbidity, or mortality or b) other health outcomes?

## Data Sources and Searches

We worked with a research librarian to develop our literature search (Appendix B). All search strategies were peer-reviewed by a second research librarian.

We re-evaluated all articles included in the previous USPSTF Evidence Report on Behavioral Counseling for Skin Cancer Screening and in the USPSTF Skin Cancer Screening Evidence Report published in 2009 (note: the 2009 update included literature published between 1999 and 2005). For articles published since the previous reviews, the librarian created two search strategies: one for counseling and one for skin self-exam. For counseling on sun protection behaviors we searched for articles published from 2009 to March 31, 2016. For skin self-exam we searched for articles published from August 2005 to March 31, 2016. We searched Cochrane Central Register of Controlled Trials, Medline, and PubMed, publisher-supplied to locate relevant studies for all KQs (Appendix B). Results of the literature search were imported into EndNote. We supplemented our database searches by reviewing reference lists from recent and relevant systematic reviews. We also searched ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP) for relevant ongoing trials (Appendix C). We updated our search on June 7, 2017.

## Study Selection

Two reviewers independently reviewed 2,100 titles and abstracts using Covidence,^163^ an online platform, and 355 articles (Appendix B Figure 1) against specified inclusion criteria (Appendix B Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or those we rated as poor quality.

For all key questions, the population of interest was people of any age without skin cancer, including parents/caregivers of children who would be the focus of a counseling intervention. We excluded studies where 25 percent or more of the population had a prior history of skin cancer or were otherwise under surveillance for skin cancer. We limited studies to settings with an established link to primary care and in countries categorized as “Very High” in the Human Development Index.^164^ We defined primary care-relevant counseling interventions as those that were delivered in primary care settings, judged to be feasible for implementation in primary care, or available for referral from primary care.^165^ We excluded studies set in the community with no link to primary care, at a worksite, within childcare or recreational settings, and mass media campaigns. We included any intervention aimed at improving sun protection behaviors or teaching skin self-exam in a primary care or primary care-linked setting, and excluded multi-component interventions (such as a community-level intervention including media campaigns, screening days, with primary care counseling included) where the effect of primary care-relevant counseling could not be assessed. For comparison groups we included usual care, assessment-only controls, attention-control groups using an equivalent-intensity intervention on a different health topic, or comparison groups using minimal intervention; we excluded studies comparing two equivalent-intensity skin cancer counseling interventions. For questions on behavioral counseling (KQ1, KQ2, KQ3) we included only randomized or controlled clinical trials. For skin self-exam questions (KQ4, KQ5), trials and prospective cohort studies were eligible for inclusion.

For KQ1, intermediate outcomes were defined as sunburn, nevi, and actinic keratosis, and health outcomes included melanoma, basal cell or squamous cell carcinoma incidence, morbidity or mortality. Behavioral outcomes for KQ2 could be parent- or self-reported outcomes that related to sun protective behaviors (e.g., composite scores, use of protective clothing, sun avoidance, use of sunscreen), skin self-exam, or indoor tanning use. For KQ3, we included any harm of behavioral counseling interventions or skin self-exam.

## Quality Assessment and Data Abstraction

At least two reviewers critically appraised all articles that met the inclusion criteria based on the USPSTF's design-specific quality criteria for trials (Appendix B Table 2). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear if it met, at least one criterion but had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations; we excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, in consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into a Microsoft Access® database (Microsoft Corporation, Redmond, Washington). A second reviewer checked the data for accuracy. Evidence tables were tailored for each KQ. Tables generally included details on study design and quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity), intervention details, length of followup, measure descriptions, and outcomes.

## Data Synthesis and Analysis

We synthesized results by KQ, using a standardized summary of evidence table to summarize the overall strength of evidence for each. This table included the number and design of included studies, summary of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of the findings.

We report results for child and adolescent populations and adult populations separately. The data reported for each population and outcome did not allow for quantitative pooling due to the limited number of contributing studies and the variability of the outcomes measured, so we provided a narrative synthesis of results. For sun protection and skin self-exam outcomes (KQ2), we present forest plots showing the standardized mean differences in change between groups (using the Cohen's d statistic) to illustrate the range of effects seen across studies but have not provided pooled estimates given the small number of contributing studies and variability in measures.

### Grading the Strength of the Body of Evidence

We graded the strength of evidence by each KQ according to AHRQ's guidance for Evidence-based Practice Centers,^166^ which was informed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^167^ For each key question we grade the evidence according to consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). These are four of the five suggested domains; we did not address the fifth required domain—directness—in the summary of evidence as directness is addressed in the design and structure of the key questions (i.e., whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, non-reporting of outcomes important to patients).

We provide an overall assessment of the strength of evidence for each KQ. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effects. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effects. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Applicability assesses how the overall body of evidence would apply to the U.S. population based on settings, populations and intervention characteristics. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion criteria was available for public comment from March 17 to April 13, 2016. We made a few minor changes to our review methods based on the comments received. A final research plan was posted on the USPSTF website on June 30, 2016.

A draft version of this report was reviewed by invited content experts and federal partners, who are listed in the acknowledgements. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and, subsequently, addressed in this version of the report.

## AHRQ and USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues regarding the scope for the final evidence synthesis. This research was funded by AHRQ under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, assisted in external review of the draft report, and reviewed the draft report.