# Chapter 1 Introduction

The Agency for Healthcare Research and Quality (AHRQ) has requested an updated evidence review on behavioral counseling for the prevention of skin cancer. Behavioral counseling can refer to various preventive services designed to encourage people to engage in healthy behaviors and reduce unhealthy behaviors.^1^ The United States Preventive Services Task Force (USPSTF) will use this review to update its 2012 recommendation on behavioral counseling for skin cancer prevention^2, 3^ and its 2009 recommendation on skin self-exam for skin cancer detection.^4, 5^

## Condition Definition

Skin cancer is an abnormal growth of cells that begins in the outermost (epidermal) layer of the skin. Skin cancer is broadly classified as melanoma and non-melanoma skin cancer (NMSC). Most NMSCs are keratinocyte carcinoma, which includes basal cell carcinomas (BCC) and squamous cell carcinomas (SCC).^6^ Both BCC and SCC typically develop in sun-exposed areas of the body.^7^ Melanomas arise from pigment-producing cells (melanocytes) and are the least common skin cancers, but are more likely to grow and spread if not treated.^8^ The depth of vertical growth is directly related to prognosis.^9-11^

There are four major histologic subtypes of melanoma:^12^ superficial spreading, nodular, lentigo maligna melanoma, and acral lentiginous. Superficial spreading and nodular melanomas are the most common types. Nodular melanomas begin their vertical growth phase immediately, whereas other types may take decades.^13, 14^ Lentigo maligna melanomas are slow-growing tumors that appear most commonly on sun-exposed areas such as the face, neck and forearms.^15^ Acral lentiginous melanomas appear most commonly on the palms and soles of the feet, and are the most common subtype observed in people with dark skin.^15^ Different melanoma subtypes may follow distinct progression trajectories, and researchers are beginning to integrate genetic, clinical, and histopathological insights into the melanoma literature.^16^

### Prevalence and Burden

Skin cancer is the most commonly diagnosed cancer in the United States. Precise estimates of basal cell and squamous cell carcinomas are not available since non-melanoma skin cancers are not required to be reported to cancer registries. Based on data from the Medical Expenditure Panel Survey, a 2015 study estimated that about 4.3 million U.S. adults were treated for NMSC annually between 2007 and 2011. This finding aligns with a 2013 study that used U.S. and Australian data to compare melanoma incidence; after accounting for population size differences, it estimated that 4.3 million NMSC cases were treated in the U.S. in 2010.^17^ The incidence of NMSC increases with age,^18-20^ and is more common in men than in women.^18-20^ Incidence appears to be increasing over time, possibly related to increased exposure to ultraviolet (UV) radiation, increased detection, and increased longevity. NMSC ranks fifth among the most costly cancers to treat according to Medicare claims data.^21^

Reliable estimates of NMSC mortality are not available for the U.S., but Australia has reported an average of 382 NMSC deaths per year (about 3 per 100,000 for males and 1 per 100,000 for females) for 1998–2005.^22^ Although NMSC mortality is elevated among immunocompromised individuals, death from these cancers is relatively uncommon in the general population.^6, 23^

Melanoma incidence has been increasing more rapidly than most other potentially preventable cancers in the United States, but overall melanoma mortality rates have not increased significantly.^24-26^ An estimated 76,380 new cases of melanoma were expected in 2016.^27^ It is the fifth leading incident cancer in men, the eighth in women, and the sixth leading cancer overall.^28, 29^ According to 2006–2012 Surveillance Epidemiology and End Results (SEER) data, the 5-year survival for melanoma is 91.5 percent, ranging from 98.4 percent for local stage disease to 17.9 percent for distant.^29, 30^ Although only two percent of all skin cancers are melanoma, it is estimated to cause more than 80% of skin cancer deaths,^31, 32^ with 10,130 expected in 2016.^27^ The increase in melanoma incidence has been attributed to increased UV radiation exposure^33^ and increased detection.^34^

Melanoma incidence and mortality increase with age. Between 2008 and 2012, incidence was 12.6 cases per 100,000 in U.S. residents under age 65 compared to 83.7 cases per 100,000 in those aged 65 and older. During the same time period, observed mortality rates were 1.2 per 100,000 and 13.5 per 100,000 for <65 and ≥65 year-olds, respectively.^30^

While the relationship between gender and melanoma incidence is complex and can vary by geographic location,^35^ older men and younger women generally are at increased melanoma risk.^30^ Overall age-adjusted melanoma incidence in the U.S. during 2008–2012 was 28.2 per 100,000 in men compared to 16.8 per 100,000 in women. Females aged 15–49 years had modestly higher incidence than their male counterparts, but the highest rates were observed in men aged 70 or older (116 to 188.4 per 100,000) and were more than double those of similarly-aged women (45.1 to 57.5 per 100,000). Although 5-year survival is similar for both men and women, age-adjusted melanoma mortality rates are higher in men than in women (4.1 vs. 1.7 deaths per 100,000 observed during 2008-2012).^30^

Melanoma risk is highest among non-Hispanic whites, with an age-adjusted incidence of 30.2 per 100,000 during 2008–2012. Individuals of Hispanic ethnicity and Native Americans had a similar incidence (white Hispanics: 4.6 per 100,000; non-white Hispanics: 4.5 per 100,000; Native Americans: 4.0 per 100,000; blacks: 1.1 per 100,000). Although melanoma mortality rates are greater in whites (whites: 3.1 per 100,000 vs. blacks: 0.4 per 100,000 during 2008–2012), 5-year relative survival among individuals diagnosed during 2005–2011 was lower in blacks (69.4%) compared to whites (91.2%).^30^

### Etiology and Natural History

Basal cell carcinomas develop from the malignant proliferation of cells in the basal layer of the epidermis (basal keratinocytes) and rarely metastasize. Squamous cell carcinomas arise from keratinocytes in the mid-layer of the epidermis; a small proportion of these metastasize in the absence of treatment.^36-38^

Melanomas develop through a process of unregulated growth of melanocytes, melanin-producing cells found in the basal layer of the epidermis. Melanocytes may grow in a horizontal lentiginous pattern to appear on the skin as a freckle, and clusters of melanocytes may develop into nevi. Melanomas typically have metastatic potential when they infiltrate the dermis and begin a vertical growth phase into deeper layers of the skin. Although less common, thin melanomas that have not invaded the dermis or entered the vertical growth phase also can metastasize.^39^

Important host factors include:

Sun-sensitive phenotypes. Individuals with fair skin, light-colored eyes, and red hair are at increased risk of skin cancer.^40-42^ Fair skin that sunburns easily increases risk of melanoma 2-fold compared to skin phenotypes that never burn.^42^ Natural red hair and natural blond hair confer a 3.6-fold and 2-fold increase in melanoma risk, respectively, compared to natural dark hair.^42^

Nevi. Increased number of nevi and atypical nevi are associated with an increased risk of melanoma.^43, 44^ Typical nevi are associated with increased risk in a dose-response manner based on the number of nevi present.^45, 46^ Atypical nevi also confer risk in a dose-response relationship with number, with a 1.5-fold increased risk associated with a single atypical nevus and a more than 6-fold increased risk associated with five atypical nevi compared to none.^43^

History of skin cancer. Individuals with a history of NMSC are at increased risk of melanoma,^47^ and a history of melanoma is associated with increased risk of developing a second primary melanoma.^48, 49^

Family history and genetic disorders. Familial syndromes account for <7–10 percent of melanomas,^50, 51^ with pooled estimates suggesting that family history increases melanoma risk 1.7-fold^42^ and that melanoma risk is higher among those with multiple affected relatives.^52^ Individuals with familial atypical multiple mole and melanoma (FAMMM) syndrome have a high lifetime risk of developing melanoma, and those with basal cell nevus syndrome develop multiple basal cell carcinomas at an early age. Some evidence suggests that a family history of squamous cell carcinoma may confer increased risk of this same cancer.^53^ Several rare genetic conditions also confer increased skin cancer risk, including xeroderma pigmentosum and albinism.^54^

Genetic mutations. Mutations in certain known high-penetrance melanoma predisposition genes, such as CDKN2A and CDK4, are associated with an increased risk of developing melanoma. Mutations in the CDKN2A gene accounts for susceptibility in about 20-40% of melanoma families.^55, 56^

Immunosuppression. Patients with immunosuppression—such as those who have acquired human immunodeficiency virus infection, have undergone organ transplantation, or are on immunosuppressive therapies—are at increased risk of melanoma and non-melanoma skin cancer.^57-61^

## Association Between UV Exposure and Skin Cancer

Ultraviolet radiation causes most skin cancers through damage to DNA,^7^ and represents the major environmental risk factor for all types of skin cancer.^62, 63^ Any tan or color to the skin after exposure signals UV damage. More severe damage presents as sunburn, a well-established risk factor for skin cancer especially when it occurs in childhood and is blistering or painful.^64, 65^ The World Health Organization's International Agency for Research on Cancer (IARC) has classified UV radiation, UV radiation-emitting devices, solar radiation, and indoor tanning devices as carcinogenic to humans (Group 1) with sufficient evidence linking these to melanoma and other skin cancers. Other Group 1 agents include tobacco, high-risk human papillomavirus, alcohol, formaldehyde, asbestos, and coal.^66^ Sunlight is the major source of UV radiation; indoor tanning is also a source of exposure to UV radiation.^67^

In its 2012 recommendation, the USPSTF found convincing evidence linking UV radiation exposure during childhood and youth to a moderately increased risk for skin cancer later in life; and for adults, adequate evidence linking UV radiation exposure to a small increase in skin cancer risk.^68^

Our scan of observational studies published since the previous review confirms these associations and provides even stronger evidence for the risks of indoor tanning use;^40, 69-79^ continued mixed evidence on the role of ambient sun exposure in melanoma development;^80-84^ and new followup data from a randomized clinical trial (RCT) that suggests a protective effect for sunscreen use and melanoma development.^85^

### Indoor Tanning and Skin Cancer

A preponderance of recent evidence suggests indoor tanning increases risk of skin cancer, with a strong association for younger age at exposure. The previous USPSTF review found that regular indoor tanning was associated with increased melanoma risk (relative risk [RR] range 1.6 to 2.3),^2^ and the IARC in 2006 estimated that people younger than age 35 at first indoor tanning exposure had a 1.75-fold increased melanoma risk compared with those aged 35 or older at first exposure.^86^

In our scan of research published since the previous review, we found additional evidence for the risks of indoor tanning. A meta-analysis of 27 studies provides evidence for a dose-response relationship between indoor tanning in women under age 50 and melanoma risk, estimating a 1.8 percent increase in risk (95% confidence interval [CI] 0 to 3.8) for each additional session of sunbed use per year.^69^ The meta-analysis also estimated that people younger than age 35 have a 1.59-fold increased melanoma risk compared to those aged 35 or older at first exposure.^87^ Four additional studies have found a positive association between increasing indoor tanning frequency and increased melanoma risk (Odds Ratio [OR] 1.34 to 6.1).^70-73^

Two systematic reviews,^69, 74^ one cohort study,^40^ and one case-control study^75^ found evidence that ever versus never use of indoor tanning is associated with increased risk of squamous cell carcinoma (RR 1.67 to 2.23)^40, 69, 74^ and basal cell carcinoma (RR 1.09 to 1.29).^69, 74, 75^

In addition, recent research suggests indoor tanning behaviors can co-occur with other high-risk sun exposure behaviors^76^ and psychotropic medication use.^77^ Indoor tanning patterns resemble addiction in some users.^78, 79^ In the U.S., 43 states and the District of Columbia have laws regulating the use of indoor tanning by minors, and 15 of these states and the District of Columbia have banned minors from indoor tanning.^88^

### Sun Exposure and Skin Cancer

The previous USPSTF evidence review assessed 18 fair-quality studies, mainly with case control designs, examining the association between sun exposure and melanoma. The review found that total sun exposure in childhood was associated with an increased risk for melanoma (OR 1.81 to 4.4), and that occupational sun exposure may be associated with a decreased risk for melanoma. Increasing recreational sun exposure was associated with increased melanoma risk (OR 1.3 to 5.0), as was recreational sun exposure during childhood (OR 1.7 to 3.5),^2^ but neither total nor chronic sun exposure was strongly associated with melanoma risk.^2^

Evidence published since the previous review remains mixed about the association between ambient sun exposure and melanoma risk.^80-83^ A cohort of non-Hispanic white individuals (n=450,934) aged 50–71 in the National Institutes of Health (NIH)-AARP Diet and Health Study was examined for associations between incident cancer and UV radiation exposure, assessed by linking daily reports from NASA's Total Ozone Mapping Spectrometer (TOMS) database with each participant's census tract location between 1978–1993 and 1996–2005. At 9-year followup, increased UV radiation exposure was associated with both increased melanoma risk (highest versus lowest quartile; hazard ratio [HR] 1.22, 95% CI 1.13 to 1.32; p<0.001)^80^ and melanoma death (HR 1.13, 95% CI 1.02 to 125).^84^

However, two large recent studies found no association between ambient sun exposure and melanoma risk. A meta-analysis of prospectively collected data of women and men aged 20 and older (n=250,151) in the Nurses' Health Study (1980–2008), the Nurses' Health Study 2 (1989–2009), and the Health Professionals Followup Study (1986–2008) confirmed an association between melanoma in situ risk and sunburn, but did not find an association between melanoma in situ risk and the ultraviolet index of the person's state of residence at birth, at age 15, or at age 30.^81^ Similarly, an analysis from the Women's Health Initiative (1993–2005, n=56,557) with a median followup of 11.9 years found no association between melanoma risk and ambient UV exposure during childhood and adulthood based on geographic residence.^83^

The previous USPSTF review found evidence from 11 primarily fair-quality cohort and case-control studies that increasing intermittent or recreational sun exposure in childhood and over one's lifetime is associated with an increased risk for both squamous cell and basal cell carcinoma (OR 1.27 to 3.86). Four studies published since the previous review (two meta-analyses^89, 90^ and two cohort studies^83, 91^) suggest an increased risk of NMSC in people with increased ambient UV radiation exposure.

### Sunscreen Use and Skin Cancer

The previous USPSTF review found no clear protective or harmful association between sunscreen use and melanoma risk, based on one good-quality trial and nine observational studies.^2^ Another systematic review of 15 pediatric studies (n=20,743 children) found that 12 of 15 studies did not suggest a protective effect of sunscreen against melanocytic nevi development in children; but 8 of 15 studies reported an association between sunscreen use and increased melanocytic nevi count.^92^

Two recent publications suggest new evidence for a protective effect for sunscreen use and melanoma development in adults. Long-term followup data from the good-quality Nambour Skin Prevention Trial (n=1621)—which was included in the previous review^85, 93^—and one case control study published since the previous review^94^ suggest evidence for a protective effect of sunscreen against melanoma. In the Nambour trial, adults (mean age 49 years, 93.0% with fair or medium skin color) were randomly assigned to the sunscreen intervention group, which was asked to apply SPF 15 sunscreen daily, or to the control group, which was asked to continue their usual approach to sunscreen use. At 4.5 years, there were significantly fewer incident squamous cell carcinomas in the sunscreen intervention group compared with the control group, but no difference in BCC or melanoma. At 8-year followup, people randomly assigned to the sunscreen intervention group had a decreased risk only for squamous cell carcinoma compared with controls (RR, 0.65 [CI, 0.45 to 0.94]).^93^ Follow up of the trial population has continued with regular questionnaires and searches of the regional cancer registry. The most recent report (2011) presented melanoma incidence estimates (n=1339, 82% of the original study population). Ten years after trial cessation (15 years since trial initiation), 11 incident melanomas had been identified in the sunscreen intervention group, and 22 in the control group. Overall melanoma risk was reduced in the sunscreen intervention group compared to controls after adjustment for sex, skin type, numbers of nevi, previous history of skin cancer, and sun exposure (adjusted HR 0.49; 95% CI 0.24 to 1.02). Risk reduction was most pronounced for invasive melanomas (3 in sunscreen intervention group versus 11 in control group; HR 0.27; 95% CI 0.08 to 0.97, p=0.045) compared with in situ melanomas (HR 0.73; 95% CI 0.29 to 1.81). Average melanoma thickness was 0.53 millimeters in the sunscreen intervention group and 1.2 millimeters in controls (p=0.08).^85^

The large U.S.-based case-control study (2011) published since the previous review included cases (age 29–59 at diagnosis, n=1167) and age- and gender-matched controls (n=1101). Mean scores for SPF 15+ sunscreen use and other sun protection behaviors were low but higher in the control group than in cases (p<0.05). Routine sunscreen use, but no other measures of sunscreen use, was associated with lower likelihood of melanoma (adjusted OR 0.44, 95% CI 0.23 to 0.86).^94^ Estimates of risk reduction attributed to other sun protection behaviors were similar (adjusted OR = 0.59, 95% CI 0.44 to 0.78).

### Potential Harms of Sun Protection Behaviors

Potential harms of sun protection include skin reactions from sunscreen use, paradoxically increased sun exposure through false reassurance, vitamin D deficiency, reduced physical activity, and anxiety.^2, 95-97^ The previous USPSTF review found very little evidence and limited potential harm from reduced sun exposure, including one trial suggesting that sun protection did not lead to decreased physical activity or increased body mass index in youth.^98^ We found no recent studies on reduced physical activity as a harm of sun avoidance.

Sunscreen users may experience irritant, allergic, phototoxic, or photoallergic contact dermatitis after sunscreen use;^95^ one study of Australian adults over age 40 (n=603) found that 19 percent of users developed an adverse reaction based on use in 1991–1992.^99^ The previous USPSTF review concluded that sunscreen with a higher SPF may increase intentional sun exposure in healthy student volunteers but in general does not promote paradoxically increased sun exposure, based on six trials.^2^ More recently, a cross-sectional analysis of data from the National Health and Nutrition Examination Survey (NHANES) (n=3052 white adults) found that frequent sunscreen use was associated with higher odds of multiple sunburns (OR=1.23, 95% CI 1.06 to 1.42, p=0.01).^96^ A 2010 Danish population-based cross-sectional study (n=3,499) of people ages 15–59 found similar results, and 66 percent of people with sunburn reported using sunscreen to prolong time in the sun.^97^

Sunlight is the body's main source of vitamin D, which is necessary for calcium absorption.^100^ Sun exposure is positively associated with vitamin D levels.^101-104^ An analysis of NHANES 2005-2006 data (n=4495) found an overall 41.6 percent prevalence of vitamin D deficiency in adults (defined as ≤20 ng/mL), with highest estimates in black (82.1%) and Hispanic individuals (69.2%) compared to white individuals (30.9%).^105^ The previous review identified one trial finding that sunscreen use does not significantly decrease vitamin D levels or cause vitamin D deficiency.^106^ More recently, neither a followup study of Nambour trial participants,^107^ nor an analysis of NHANES data^108^ found a decrease in vitamin D levels associated with sunscreen use.

Minimal ambient sun exposure a few days per week in summer (5–15 minutes for fair-skinned individuals and 15–30 minutes for dark-skinned individuals) may be sufficient to sustain vitamin D concentrations.^109-111^ The American Cancer Society, the office of the U.S. Surgeon General, and a coalition of seven U.K. medical societies have concluded that the benefits of sun protection outweigh the potential risk of vitamin D deficiency.^109, 110, 112^ The American Academy of Dermatology recommends against obtaining vitamin D from unprotected sun exposure or indoor tanning devices.^113^

Aside from sunlight, adequate vitamin D can be obtained safely from food and dietary supplements.^109^ Natural dietary sources of vitamin D include fatty fish and fish liver oils, and many foods and beverages in the U.S., such as milk, yogurt, and orange juice, are fortified with vitamin D.^109^ The USPSTF currently finds insufficient evidence to recommend for or against routine screening for Vitamin D deficiency (2014).^114^

## Association Between UV Exposure and Other Health Outcomes

In the previous review, four of seven fair- or good-quality studies suggested sun exposure in predominantly white populations may be inversely related to risk for advanced breast and prostate cancer and non-Hodgkin lymphoma.^2^ Research into potential beneficial associations between vitamin D and other health outcomes has increased substantially since the previous review,^115-124^ but studies of associations between UV exposure and health outcomes besides skin cancer are less common. The NIH-AARP Diet and Health Study (described above) found that despite an association with increased melanoma risk and melanoma death, increased sun exposure may reduce risk for several cancers.^80^ At 9-year followup, UV radiation exposure was inversely associated with total cancer risk (highest versus lowest quartile; HR = 0.97, 95% CI 0.95 to 0.99; p<0.001). For individual cancers, after adjustment for individual-level risk factors, UV radiation exposure was associated with decreased risk of: non-Hodgkin lymphoma (HR 0.82, 95% CI 0.74 to 0.92) colon (HR 0.88, 95% CI 0.82 to 0.96), squamous cell lung (HR 0.86, 95% CI 0.75 to 0.98), pleural (HR 0.57, 95% CI 0.38 to 0.84), prostate (HR 0.91, 95% CI 0.88 to 0.95), kidney (HR 0.83, 95% CI 0.73 to 0.94), and bladder (HR 0.88, 95% CI 0.81 to 0.96) cancers.^80^ An analysis of total deaths (n=41,425) also found a decreased risk of death from lung, prostate, and liver cancers when comparing the highest vs. lowest ambient UV radiation quartile.^84^

## Association Between Skin Self-Exam and Skin Cancer Outcomes

The 2009 USPSTF review on skin cancer screening^5^ found no new evidence on the effectiveness of either skin examination by a physician or skin self-exam in reducing the morbidity or mortality of skin cancer. The authors described one fair-quality case-control study on skin self-exam published in 1996 and a subsequent followup study (2005)^125, 126^ of the same participants. We identified no new studies, but identified a 20-year followup study of the same study population published in 2016 that suggests no beneficial association between skin self-exam and skin cancer death.^127^

In the original study,^125^ melanoma cases diagnosed in 1987–1989 (n=650) were obtained from the Connecticut Tumor Registry (CTR), a National Cancer Institute Surveillance Epidemiology and End-Results (SEER) site. Age- and sex-matched controls (n=549) were identified from the general public through random-digit dialing. A trained nurse used a structured questionnaire to interview participants about family history, sun exposures, and history of skin examination, and the nurse also counted nevi on the participants' backs and arms. Of the 650 cases, 86 had conducted skin self-exam (13.2%). Participants were followed biannually for a mean of 5.4 years.

At followup, skin self-exam was associated with a reduced risk of melanoma diagnosis (adjusted OR 0.66, 95% CI 0.44 to 0.99).^125, 126^ An analysis of cases only (n=528) assessed risk of death from melanoma. At followup, 58 people (11.0%) had died from melanoma; 24 (4.5%) from other causes. History of severe sunburn, high intermittent sun exposure, presence of solar elastosis (a histologic measure of sun damage), and skin awareness (defined as endorsement of the question: “Prior to your biopsy, did you ever think about your skin, how it looked, whether there were any changes, or whether there were any marks?”) were significant predictors of melanoma death, but history of skin self-exam was not (HR 0.06, 95% CI 0.2 to 1.5). On multivariable analysis, solar elastosis and skin awareness, as well as melanoma thickness, head/neck location, and mitoses, remained independent predictors of melanoma death.^125^

In the 2016 analysis, deaths were examined for the original case population (n=554) through 2007 (18–20 years from diagnosis) identified through SEER data, the National Death Index, and the Social Security Index. By 2007, 45 percent had died; 48.4 percent from melanoma (calculated percent of all cases 21.8%). Skin self-exam was not associated with melanoma death based on either univariate or multivariable analysis (adjusted HR 1.12, 95% CI 0.61 to 2.06) p=0.71). However, skin awareness remained independently associated with a decreased risk of melanoma death (HR 0.46, 95% CI 0.28 to 0.75, p<0.01).^127^

### Skin Self-Exam Potential Harms

Skin self-exam is self-conducted and noninvasive. Psychosocial harms, such as anxiety or cancer worry, are possible. If skin self-exam is followed by clinician investigation and biopsy, procedural harms might occur from biopsy, such as pain, infection, or cosmetic harms such as scarring. There is evidence for overdiagnosis of skin cancer, given the sharp rise in skin biopsies and melanoma incidence over the past several decades as melanoma death rates have remained steady.^34, 128^ However, there is limited data on the role that skin self-exam might play in increased biopsies (discussed more in Chapter 3).

## Current Prevalence of Sunburn, Sun Protection Behaviors, and Skin Self-Exam

Sun protective behaviors fall short of the Healthy People 2020 objective, which has set a target for 73.7 percent of adults aged 18 and older to follow protective measures to reduce the risk of skin cancer.^129^ An analysis of National Health Interview Survey (NHIS) data from 2010 found that 37.1% of U.S. adults aged 18 and older had experienced at least one sunburn during the past year, and sunburn prevalence was highest among adults aged 18–29 (52.0%).^130^ In a separate analysis of NHIS data for 18–29 year-olds, the highest reported use of any sun-protective behavior between 2000–2010 was 37 percent, and the prevalence of reported sunburn remained steady between 2000–2010 (49.1% for men and 51.3% for women in 2010) despite a trend of increasing sun protective behavior during the same time period.^131^ National surveys conducted between 2004–2009 estimate that about 30 percent of U.S. adults routinely practice sun-protective behaviors. Less than 40 percent of adolescents report sun-protective behavior, and 69 percent of all adolescents reported sunburn in the previous summer.^132^ An analysis of 2010 NHIS data found that in Hispanic adults with sun-sensitive skin (n=1676), 47.1 percent never or rarely used sunscreen, 16.8 percent never or rarely stayed in the shade, 60.3 percent never or rarely used sun protective clothing, and 43.1 percent reported having a sunburn in the past year. Greater acculturation was associated with fewer sun protection behaviors and higher reported sunburn.^133^ Sun protection behaviors and skin self-exam were low in a sample of uninsured, minority, or immigrant individuals in Florida, as were measures of skin cancer awareness.^134^ Family members of people with melanoma report similar sun protection behaviors compared to those at average risk.^135, 136^ A 2014 meta-analysis of the prevalence of indoor tanning in U.S., Europe, and Australia estimated ever-exposure to indoor tanning at 35.7 percent for adults, 55.0 percent for university students, and 19.3 percent for adolescents, based on data from 406,696 participants.^137^

Estimates of skin self-exam prevalence vary widely. A systematic review of 14 studies reports between 7 percent and 61 percent of average-risk individuals engage in thorough skin self-exam either in their lifetime, within the past 3 months, or within the past month.^138^ A 1996 survey of 1000 randomly chosen U.S. residents found that 46 percent report performing skin self-exam at least once in the past year.^139^ In a 2011 survey of Hispanic adults (n=788), 17.9 percent reported ever having conducted a skin self-exam.^140^ A recent population-based study in Queensland, Australia—the region with the highest melanoma incidence in the world—reports 55.1 percent of adults aged 40 through 69 performed a skin self-exam in the past three years.^141^ Family members of people with melanoma report similar frequencies of engaging in skin self-exam compared with the general population.^142, 143^

## Current Clinical Practice in the United States

Estimates of the frequency of clinician-provided skin cancer prevention counseling vary. The most recently published estimate used National Ambulatory Medical Care Survey (NAMCS) data from 1989–2010 and found that clinicians mentioned sunscreen at approximately 0.07 percent of patient visits to ambulatory care offices.^144^ The study noted clinicians were most likely to recommend sunscreen use to elderly patients and least likely to recommend sunscreen use to children.^144^ Two studies analyzing 1997 data found that skin cancer prevention counseling was reported at 1.0 percent to 2.3 percent of visits to primary care physicians.^145, 146^

Surveys of physicians and patients suggest higher self-reported rates of skin cancer prevention counseling. In a mailed survey of 3,032 female physicians, 27 percent said they were likely to provide skin cancer counseling or screening to a typical patient at least once per year,^147^ and a separate American Academy of Pediatrics survey found that 22.3 percent of pediatricians reported providing sun protection counseling to most patients in all age groups.^148^ In a nationally representative telephone survey of 1,589 adolescents and parents, 44 percent reported ever receiving sun protection counseling from a physician.^149^

## Recommendations of Other Groups

A role for physicians in educating patients about skin cancer prevention is endorsed by the American Cancer Society,^112^ American Congress of Obstetricians and Gynecologists,^150^ the American Academy of Pediatrics,^67^ the Institute for Clinical Systems Improvement,^151^ the Australian College of General Practitioners,^152^ the U.K.'s National Institute for Health and Care Excellence,^153^ and the International Agency for Research on Cancer.^154^

The Community Preventive Services Task Force Recommends education and policy approaches to encourage skin-protective behaviors in child care centers, primary and middle schools, outdoor recreational sites, and outdoor occupational settings.^155^ They also recommend multi-component community-wide interventions—such as individual-level strategies, mass media campaigns, and environmental and policy changes across multiple settings within a defined geographic area—to increase UV radiation protective behaviors and prevent skin cancer.^156^ Although multi-component interventions may involve health care settings, the Community Preventive Services Task Force focuses on interventions that target multiple settings or an entire community.^156^

The American Academy of Dermatology encourages the general population to regularly examine their skin for early signs of skin cancer.^157^ The Skin Cancer Foundation and the American Cancer Society recommend individuals perform skin self-exam monthly.^8, 158^ The Royal Australian College of General Practitioners recommends skin self-exam at different frequencies depending on risk (every 3 months for high-risk individuals, annually for low-risk individuals).^159^ Additional information about recommendations of other groups is in Appendix A Table 1.

## Previous USPSTF Recommendations

In 2012, the USPSTF recommended counseling children, adolescents, and young adults aged 10 to 24 who have fair skin about minimizing their exposure to ultraviolet radiation to reduce risk for skin cancer (B recommendation). They found moderate certainty that counseling has a moderate net benefit, but that for adults older than age 24, evidence of the benefits of counseling is sparse and of unknown clinical significance, and the balance of benefits and harms cannot be determined (I statement).^68^ This replaced the task force's 2003 recommendation, in which the USPSTF found insufficient evidence to make a recommendation on behavioral counseling for skin cancer (I statement).^160^

In 2009, in a separate recommendation statement, the USPSTF found insufficient evidence to assess the balance of benefits and harms of screening for skin cancer by primary care clinicians or by patient skin self-exam (I statement), citing the lack of studies on whether early detection of skin cancer reduces mortality or morbidity from skin cancer as a critical evidence gap.^4^ In 2016, the USPSTF updated its recommendation on physician skin examination only (finding insufficient evidence; I statement).^161^ The evidence for skin self-exam was not included in the 2016 evidence update, and is included in this report.