# Appendix B Methods

## Skin cancer counseling and skin self-exam search strategy

Databases searched:

MEDLINE

PubMed

Cochrane Central Register of Controlled Trials (CENTRAL)

Key:

- / = subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- adj# = adjacent within x number of words
- pt = publication type
- fs = floating subheading
- * = truncation
- kw = keyword

### Medline (via Ovid)

#### KQs 1-3, Trials & Harms

Database: Ovid MEDLINE(R) <1946 to March Week 4 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <March 30, 2016>, Ovid MEDLINE(R) Daily Update <March 30, 2016>

Search Strategy:

----------------------------------------------------------------------------------------------------------

1. Skin Neoplasms/
2. Melanoma/
3. Hutchinson's Melanotic Freckle/
4. Hutchinson$ Melanotic Freckle.ti,ab.
5. Melanoma, Amelanotic/
6. melanoma$.ti,ab.
7. lentigo maligna.ti,ab.
8. Carcinoma, Basal Cell/
9. Carcinoma, Squamous Cell/
10. Neoplasms, Basal cell/
11. Neoplasms, Squamous cell/
12. skin cancer$.ti,ab.
13. ((carcinoma$ or neoplas$) adj5 (skin or cutaneous)).ti,ab.
14. Nevus/
15. Nevus, Pigmented/
16. Dysplastic Nevus Syndrome/
17. (nevus or naevus or nevi or naevi).ti,ab.
18. ((naevoid or nevoid) adj3 syndrome$).ti,ab.
19. Keratosis/
20. keratos#s.ti,ab.
21. Sunburn/
22. Sunburn$.ti,ab.
23. Sunscreening Agents/
24. sunscreen$.ti,ab.
25. Protective clothing/
26. protective cloth$.ti,ab.
27. (((hat or hats) and (wear$ or wore or brim$)) or (use$ adj3 hat) or (use$ adj3 hats)).ti,ab.
28. Sunlight/
29. Ultraviolet Rays/
30. sunlamp$.ti,ab.
31. tanning.ti,ab.
32. sunbed$.ti,ab.
33. photoprotection.ti,ab.
34. sun protecti$.ti,ab.
35. ((seek$ or sun) and shade).ti,ab.
36. ((avoid$ or minimiz$ or minimis$) and midday sun).ti,ab.
37. sun awareness.ti,ab.
38. sun safety.ti,ab.
39. sun exposure.ti,ab.
40. (skin adj3 self adj3 (exam$ or check$)).ti,ab.
41. or/1-40
42. Health promotion/
43. Health Education/
44. Patient Education as Topic/
45. Preventive Health Services/
46. Consumer Health Information/
47. Counseling/
48. Directive Counseling/
49. Behavior Therapy/
50. Health Behavior/
51. Physician's Role/
52. Teaching Materials/
53. Parents/ed [Education]
54. health promotion.ti,ab.
55. (preventive health or health prevention).ti,ab.
56. consumer health.ti,ab.
57. health behavio$.ti,ab.
58. counsel$.ti,ab.
59. behav$ therap$.ti,ab.
60. advice.ti,ab.
61. advise.ti,ab.
62. educat$.ti,ab.
63. provid$ information.ti,ab.
64. behavio$ intervention$.ti,ab.
65. prevention intervention$.ti,ab.
66. or/42-65
67. 41 and 66
68. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
69. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
70. Random$.ti,ab.
71. control groups/ or double-blind method/ or single-blind method/
72. clinical trial$.ti,ab.
73. controlled trial$.ti,ab.
74. meta analy$.ti,ab.
75. or/68-74
76. 67 and 75
77. limit 76 to (english language and yr=“2009 -Current”)
78. remove duplicates from 77
79. Sunscreening Agents/
80. sunscreen$.ti,ab.
81. Protective Clothing/
82. protective cloth$.ti,ab.
83. (((hat or hats) and (wear$ or wore or brim$)) or (use$ adj3 hat) or (use$ adj3 hats)).ti,ab.
84. ((UV absorb$ or ultraviolet absorb$ or UV protect$ or ultraviolet protect$) and (laundry or detergent$)).ti,ab.
85. sun protect$.ti,ab.
86. photoprotect$.ti,ab.
87. ((seek$ or sun) and shade).ti,ab.
88. ((avoid$ or minimiz$ or minimis$) and (sun exposure or midday sun)).ti,ab.
89. (avoid$ and (sunlamp$ or sunbed$ or tanning bed$ or tanning booth$ or tanning salon$ or tanning device$ or indoor tanning or artificial light or artificial UV or artificial ultraviolet)).ti,ab.
90. or/79-89
91. adverse effects.fs.
92. harm$.ti,ab.
93. adverse$.ti,ab.
94. (increas$ and ((time and sun) or sun exposure)).ti,ab.
95. ((reduce$ or reduction) and physical activit$).ti,ab.
96. Sedentary Lifestyle/
97. sedentary behavio$.ti,ab.
98. depression/
99. Depressive Disorder/
100. mood disorders/
101. Anxiety/
102. (depression or depressed or depressive).ti,ab.
103. mood.ti,ab.
104. (anxiety or anxious).ti,ab.
105. vitamin D deficiency/
106. (vitamin D adj5 deficien$).ti,ab.
107. Medical Overuse/
108. Unnecessary Procedures/
109. ((unnecessary or unneeded) adj3 (surg$ or procedure$ or biops$)).ti,ab.
110. overdiagnos$.ti,ab.
111. or/91-110
112. (67 or 90) and 111
113. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
114. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
115. Random$.ti,ab.
116. control groups/ or double-blind method/ or single-blind method/
117. clinical trial$.ti,ab.
118. controlled trial$.ti,ab.
119. meta analy$.ti,ab.
120. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
121. cohort.ti,ab.
122. longitudinal.ti,ab.
123. (follow up or followup).ti,ab.
124. 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123
125. 112 and 124
126. limit 125 to (english language and yr=“2009 -Current”)
127. remove duplicates from 126
128. 78 or 127

#### KQs 4-5, Skin Self-Exam

Database: Ovid MEDLINE(R) <1946 to March Week 4 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <March 30, 2016>, Ovid MEDLINE(R) Daily Update <March 30, 2016>

Search Strategy:

------------------------------------------------------------------------------------------------------------------

1. Skin Neoplasms/
2. Melanoma/
3. Hutchinson's Melanotic Freckle/
4. Hutchinson$ Melanotic Freckle.ti,ab.
5. Melanoma, Amelanotic/
6. melanoma$.ti,ab.
7. lentigo maligna.ti,ab.
8. Carcinoma, Basal Cell/
9. Carcinoma, Squamous Cell/
10. Neoplasms, Basal cell/
11. Neoplasms, Squamous cell/
12. skin cancer$.ti,ab.
13. ((carcinoma$ or neoplas$) adj5 (skin or cutaneous)).ti,ab.
14. Nevus/
15. Nevus, Pigmented/
16. Dysplastic Nevus Syndrome/
17. (nevus or naevus or nevi or naevi).ti,ab.
18. ((naevoid or nevoid) adj3 syndrome$).ti,ab.
19. Keratosis/
20. keratos#s.ti,ab.
21. or/1-20
22. Self examination/
23. (self adj3 (exam$ or check$)).ti,ab.
24. 22 or 23
25. 21 and 24
26. limit 25 to (english language and yr=“2005 -Current”)
27. remove duplicates from 26

### CENTRAL

#### KQs 1-3, Trials & Harms

Issue 3 of 12, March 2016

#1 melanoma:ti,ab,kw
#2 “lentigo maligna”:ti,ab,kw
#3 (carcinoma* or neoplas*):ti,ab,kw near/5 (skin or cutaneous):ti,ab,kw
#4 (skin next cancer*):ti,ab,kw
#5 carcinoma:ti,ab,kw and (basal or squamous):ti,ab,kw
#6 (nevus or naevus or nevi or naevi):ti,ab,kw
#7 ((naevoid or nevoid) near/3 syndrome*):ti,ab,kw
#8 keratos?s:ti,ab,kw
#9 sunburn*:ti,ab,kw
#10 suncreen*:ti,ab,kw
#11 (protective next cloth*):ti,ab,kw
#12 sunlight:ti,ab,kw
#13 ((hat or hats) and (wear* or wore or brim*)):ti,ab,kw or (use* near/3 (hat or hats)):ti,ab,kw 36
#14 sunlamp*:ti,ab,kw
#15 tanning:ti,ab,kw
#16 sunbed*:ti,ab,kw
#17 photoprotection:ti,ab,kw
#18 (seek* and shade):ti,ab,kw
#19 sun:ti,ab,kw
#20 (skin near/3 self near/3 (exam* or check*)):ti,ab,kw
#21 {or #1-#20}
#22 “health promotion”:ti,ab,kw
#23 “preventive health”:ti,ab,kw
#24 “consumer health”:ti,ab,kw
#25 counsel*:ti,ab,kw
#26 (behavior* or behaviour*):ti,ab,kw next (therap* or intervention*):ti,ab,kw
#27 health:ti,ab,kw next (behavior or behaviour):ti,ab,kw
#28 (advice or advise):ti,ab,kw
#29 educat*:ti,ab,kw
#30 (provid* next information):ti,ab,kw
#31 (prevention next intervention*):ti,ab,kw
#32 {or #22-#31}
#33 #21 and #32 Publication Year from 2009 to 2016, in Trials
#34 sunscreen:ti,ab,kw
#35 (protective next cloth*):ti,ab,kw
#36 (hat or hats):ti,ab,kw
#37 (UV or ultraviolet):ti,ab,kw and (laundry or detergent):ti,ab,kw
#38 (sun next protect*):ti,ab,kw
#39 photoprotect*:ti,ab,kw
#40 (seek* or sun):ti,ab,kw and shade:ti,ab,kw
#41 (avoid* or minimiz* or minimis*):ti,ab,kw and (“sun exposure” or “midday sun”):ti,ab,kw
#42 avoid*:ti,ab,kw and (sunlamp* or sunbed* or tanning or “artificial light” or “artificial uv” or “artificial ultraviolet”):ti,ab,kw
#43 {or #34-#42}
#44 harm*:ti,ab,kw
#45 (adverse next effect*):kw
#46 adverse*:ti,ab
#47 (increas* and time and sun):ti,ab,kw
#48 increas*:ti,ab,kw and (sun next exposure):ti,ab,kw
#49 (reduce* or reduction):ti,ab,kw and (physical next activit*):ti,ab,kw
#50 (sedentary next behavi*):ti,ab,kw
#51 (depression or depressed or depressive):ti,ab,kw
#52 mood:ti,ab,kw
#53 (anxiety or anxious):ti,ab,kw
#54 (“vitamin D” near/5 deficien*):ti,ab,kw
#55 (unnecessary or unneeded):ti,ab,kw near/3 (surg* or procedure* or biops*):ti,ab,kw
#56 overdiagnos*:ti,ab,kw
#57 {or #44-#56}
#58 #43 and #57 Publication Year from 2009 to 2016, in Trials
#59 #33 or #58

#### KQs 4-5, Skin Self-Examination

Issue 3 of 12, March 2016

#1 melanoma:ti,ab,kw
#2 “lentigo maligna”:ti,ab,kw
#3 (carcinoma* or neoplas*):ti,ab,kw near/5 (skin or cutaneous):ti,ab,kw
#4 (skin next cancer*):ti,ab,kw
#5 carcinoma:ti,ab,kw and (basal or squamous):ti,ab,kw
#6 (nevus or naevus or nevi or naevi):ti,ab,kw
#7 ((naevoid or nevoid) near/3 syndrome*):ti,ab,kw
#8 keratos?s:ti,ab,kw
#9 {or #1-#8}
#10 (self near/3 (exam* or check*)):ti,ab,kw
#11 #9 and #10 Publication Year from 2005 to 2016, in Trials

### PubMed, publisher-supplied

#### KQs 1-3, Trials & Harms

Search | Query
#58 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #38 OR #57
#57 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #56 AND (“2009/01/01”[Date - Publication] : “3000”[Date - Publication])) AND English[Language]
#56 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#45 AND #55) AND publisher[sb]
#55 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54
#54 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search overdiagnos*[tiab]
#53 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search unnecessary procedure*[tiab] OR unneeded procedure*[tiab] OR unnecessary surg*[tiab] OR unneeded surg*[tiab] OR unnecessary biops*[tiab] OR unneeded biops*[tiab]
#52 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “vitamin d”[tiab] AND deficien*[tiab]
#51 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search anxiety[tiab] OR anxious[tiab]
#50 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search depression[tiab] OR depressed[tiab] OR depressive[tiab] OR mood[tiab]
#49 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sedentary[tiab] AND behavio*[tiab]
#48 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (reduce*([tiab] OR reduction[tiab]) AND (“physical activity”[tiab] OR “physical activities”[tiab])
#47 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search increas*[tiab] AND sun[tiab]
#46 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search adverse* [tiab] OR harm*[tiab]
#45 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #11 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44
#44 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (avoid*[tiab]) AND (tanning[tiab] OR sunlamp*[tiab] OR sunbed*[tiab] OR “artificial light”[tiab] OR “artificial uv”[tiab] OR “artificial ultraviolet”[tiab])
#43 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (seek*[tiab] OR sun[tiab]) AND shade[tiab]
#42 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (avoid*[tiab] OR minimiz*[tiab] OR minimis*[tiab]) AND (sun[tiab])
#41 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sun protect*[tiab]
#40 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (UV[tiab] OR ultraviolet[tiab]) AND (laundry[tiab] OR detergent*[tiab])
#39 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search hat[tiab] OR hats[tiab]
#38 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #37 AND (“2009/01/01”[Date - Publication] : “3000”[Date - Publication])) AND English[Language]
#37 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 AND #35 AND #36) AND publisher[sb]
#36 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search random*[tiab] OR placebo*[tiab] OR trial[tiab] OR trials[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR “meta analyses”[tiab] OR “meta analytic”[tiab] OR systematic[sb]
#35 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34
#34 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search prevention intervention*[tiab]
#33 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search provid* information[tiab]
#32 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search educat*[tiab]
#31 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search advise[tiab]
#30 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search advice[tiab]
#29 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search health behavio*[tiab]
#28 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio*[tiab] AND intervention*[tiab]
#27 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search counsel*[tiab]
#26 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “consumer health”[tiab]
#25 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “preventive health”[tiab]
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health promotion”[tiab]
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search skin[tiab] AND self[tiab] AND (exam*[tiab] OR check*[tiab])
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sun exposure”[tiab]
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sun safety”[tiab]
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sun awareness”[tiab]
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sun protective”[tiab]
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sun protection”[tiab]
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search photoprotection[tiab]
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sunbed*[tiab]
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search tanning[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sunlamp*[tiab]
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sunlight[tiab]
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search protective cloth*[tiab]
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sunscreen*[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search sunburn*[tiab]
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search keratosis[tiab] OR keratoses[tiab]
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (naevoid[tiab] OR nevoid[tiab]) AND syndrome*[tiab]
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search nevus[tiab] OR naevus[tiab] OR nevi[tiab] OR naevi[tiab]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search carcinoma[tiab] and (basal[tiab] or squamous[tiab])
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (carcinoma*[tiab] OR neoplas*[tiab]) AND (skin[tiab] OR cutaneous[tiab])
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “lentigo maligna”[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “skin cancer”[tiab] OR “skin cancers”[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search melanoma*[tiab]

#### Skin Self-Examination

Search | Query
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #11 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 AND #10) AND publisher[sb]
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search self[tiab] AND (exam*[tiab] OR check*[tiab])
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search keratosis[tiab] OR keratoses[tiab]
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (naevoid[tiab] OR nevoid[tiab]) AND syndrome*[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search nevus[tiab] OR naevus[tiab] OR nevi[tiab] OR naevi[tiab]
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search carcinoma[tiab] and (basal[tiab] or squamous[tiab])
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (carcinoma[tiab] OR neoplas*[tiab] AND (skin[tiab] OR cutaneous[tiab])
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “lentigo maligna”[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “skin cancer”[tiab] OR “skin cancers”[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search melanoma*[tiab]

## Counseling to prevent skin cancer: search to identify existing systematic reviews

The search for existing synthesized literature and guidelines for literature published from 2011 through 2015 from: the Agency for Healthcare Research and Quality, Canadian Agency for Drugs and Technologies in Health, CDC Community Guide, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, Health Technology Assessment, DynaMed, Institute for Clinical Systems Improvement, Institute of Medicine, PubMed, NHS Health Technology Assessment Programme and the National Institute for Health and Clinical Excellence.

Cochrane Database of Systematic Reviews Issue 12 of 12, December 2015

#1 melanoma:ti,ab,kw
#2 carcinoma:ti,ab,kw
#3 “skin cancer”:ti,ab,kw
#4 (sunscreen* or sunlamp* or sunbed*):ti,ab,kw
#5 (“sun exposure” or “sun protection” or “sun protective”):ti,ab,kw
#6 (#1 or #2 or #3 or #4 or #5) Publication Year from 2011 to 2015, in Cochrane Reviews (Reviews and Protocols)

Database of Abstracts of Reviews of Effects

((melanoma OR skin cancer OR (carcinoma AND skin) OR sunscreen* or sunlamp* or sunbed* or tanning OR sun exposure or sun protection or sun protective )) IN DARE FROM 2011 TO 2015

Health Technology Assessment (CRD HTA)

(melanoma OR skin cancer OR (carcinoma AND skin) OR sunscreen* or sunlamp* or sunbed* or tanning OR sun exposure or sun protection or sun protective ) IN HTA FROM 2011 TO 2015

PubMed search strategy

Search | Query
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#12) AND systematic[sb]) AND English[Language]) AND (“2011”[Date - Publication] : “3000”[Date - Publication])
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“skin cancer”[tiab] OR melanoma[tiab]) AND (inprocess[sb] OR pubmednotmedline[sb] OR publisher[sb])
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Sunburn”[Mesh]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sunlight/adverse effects”[Mesh:NoExp] OR “Ultraviolet Rays/adverse effects”[Mesh])
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“sun protection”[tiab] OR “sun protective”[tiab])
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (tanning[tiab] OR sunbed*[tiab] OR sunlamp*[tiab])
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sunscreening Agents”[Mesh] OR sunscreen*[tiab])
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Carcinoma, Squamous Cell/epidemiology”[Mesh:noexp] OR “Carcinoma, Squamous Cell/etiology”[Mesh:noexp] OR “Carcinoma, Squamous Cell/genetics”[Mesh:noexp] OR “Carcinoma, Squamous Cell/prevention and control”[Mesh:noexp] OR “Neoplasms, Squamous Cell/epidemiology”[Mesh:noexp] OR “Neoplasms, Squamous Cell/etiology”[Mesh:noexp] OR “Neoplasms, Squamous Cell/genetics”[Mesh:noexp] OR “Neoplasms, Squamous Cell/prevention and control”[Mesh:noexp]) AND (skin[tiab] OR cutaneous[tiab] OR “skin neoplasms”[mesh:noexp])
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Neoplasms, Basal Cell/epidemiology”[Mesh:NoExp] OR “Neoplasms, Basal Cell/etiology”[Mesh:NoExp] OR “Neoplasms, Basal Cell/genetics”[Mesh:NoExp] OR “Neoplasms, Basal Cell/prevention and control”[Mesh:NoExp])
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Carcinoma, Basal Cell/epidemiology”[Mesh:NoExp] OR “Carcinoma, Basal Cell/etiology”[Mesh:NoExp] OR “Carcinoma, Basal Cell/genetics”[Mesh:NoExp] OR “Carcinoma, Basal Cell/prevention and control”[Mesh:NoExp])
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Melanoma/epidemiology”[Mesh:NoExp] OR “Melanoma/etiology”[Mesh:NoExp] OR “Melanoma/genetics”[Mesh:NoExp] OR “Melanoma/prevention and control”[Mesh:NoExp])
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Skin Neoplasms/epidemiology”[Mesh:NoExp] OR “Skin Neoplasms/etiology”[Mesh:NoExp] OR “Skin Neoplasms/genetics”[Mesh:NoExp] OR “Skin Neoplasms/prevention and control”[Mesh:NoExp])

Appendix B Figure 1 Literature Flow Diagram

Appendix B Figure 1 is a flow chart that summarizes the search and selection of articles. There were 2,928 citations identified through literature databases. An additional 394 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 2,311 unique citations were screened at the title/abstract stage. The full text of 372 citations were examined for inclusion for one or more of the five Key Questions.

Appendix B Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Population | - Persons of any age; - Parents/caregivers of children; - Children of melanoma survivors | Persons with prior history of skin cancer or who are otherwise under surveillance for skin cancer because of known increased risk (more than 25%)
Setting | - Any setting linked with primary care health care delivery (e.g., home, clinic); - Studies conducted in countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme) | Settings not affiliated with primary care, such as community, worksite, child care, school, or recreational/tourism settings
Intervention | - Stand-alone or multicomponent/multidimensional interventions aimed at improving sun protection behaviors or teaching skin self-examination; - Intervention must be initiated in, conducted in, or referable from primary care; - Interventions may include, but are not limited to: individual or group counseling, peer counseling, home visits, structured education, technology- or computer-based support, and distribution of written materials; - Interventions may be conducted by, but are not limited to: nurses/nurse practitioners, lay health workers, and physicians; - Health care system interventions (e.g., staff training) | - Interventions not referable from primary care (occupational, recreational/tourism, policy-level interventions); - Mass media campaigns; - Community interventions not affiliated with primary care; - Multicomponent interventions for which the effects of the primary care–relevant counseling component cannot be isolated
Comparison | Usual care, no intervention, waitlist, or minimal intervention | Another skin cancer counseling intervention
Outcomes | KQs 1, 4: Skin cancer outcomes: melanoma, basal cell, or squamous cell carcinoma incidence, morbidity, or mortality; intermediate outcomes: sunburn, nevi, and actinic keratosis KQ 2: Behavioral outcomes: sunscreen use; time spent in the sun; shade seeking; avoiding midday sun; avoiding indoor tanning; use of protective clothing, hats, or sunglasses; composite measures of sun protection behavior; skin self-examination behavior KQ 3: Any harm of behavioral counseling interventions, such as anxiety, increased time spent in the sun, reduced physical activity, or vitamin D deficiency KQ 5: Any harm of skin self-examination, including overdiagnosis and cosmetic or psychosocial harms | All KQs: Skin cancer metastasis or progression KQs 1, 2, 4: Outcomes with less than 3 months of followup after baseline assessment
Study design | KQs 1, 2: Randomized and controlled clinical trials KQs 3–5: Randomized and controlled clinical trials; prospective cohort studies | Case-control studies, cross-sectional designs, case series, case reports, narrative reviews, commentaries, editorials, and theses; qualitative studies; ecologic studies
Language | English
Timing | 2009 to present^*^
Quality | Fair or good (according to design-specific USPSTF criteria) | Poor (according to design-specific USPSTF criteria)

* The USPSTF will continue to consider and use evidence that was included in its prior systematic reviews. For skin self-examination, the search period will begin with August 2005, the search date of the last USPSTF review on this topic.

Appendix B Table 2 Quality Assessment Criteria

Study Design | Quality criteria
Randomized controlled trials USPSTF methods^2^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid, and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^3^ | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid, and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?

Abbreviations: USPSTF = U.S. Preventive Services Task Force

## References

1 United Nations Development Programme. Human Development Index: 2015 Rankings. United Nations Development Programme [2015]. http://hdr.undp.org/en/2015-report.
2 United States Preventive Services Task Force. US Preventive Services Task Force Procedure Manual. 2015.
3 Wells G, Shea B, O'connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.