# Appendix A

Appendix A Table 1 Recommendations on Counseling for Skin Cancer Prevention From Other Groups

Organization | Country | Year | Recommendation
American Academy of Dermatology | U.S. | 2016 | Recommends clinicians provide sun protection counseling for all individuals.^1^ Encourages members of the public to regularly examine their skin for signs of skin cancer and to see a board-certified dermatologist if they notice any unusual spots on their skin, including anything changing, itching or bleeding.^2^
Skin Cancer Foundation | U.S. | 2016 | Endorses the U.S. Surgeon General's recommendations to increase awareness about skin cancer prevention and the dangers of indoor tanning.^3^ Recommends members of the public conduct monthly head-to-toe self-examinations of the skin to find any new or changing lesions that might be cancerous or precancerous.^4^
American Cancer Society (ACS) | U.S. | 2015 | Recommends health care providers play a role in counseling patients about ways to protect themselves from skin cancer.^5^ Recommends minimizing UV exposure by limiting time spent outdoors during peak UV exposure hours, wearing protective clothing, applying adequate sunscreen, and avoiding indoor tanning devices.^5^ ACS also recommends individuals engage in monthly skin self-exams.^6^
American Congress of Obstetricians and Gynecologists (ACOG) | U.S. | 2015 | Recommends clinicians talk to patients about sun exposure, sun-protective behaviors, and the harms of indoor tanning.^7^
Michigan Quality Improvement Consortium | U.S. | 2015 | Recommends clinicians provide routine education and counseling to parents and children about skin cancer prevention^8^
Community Preventive Services Task Force | U.S. | 2014 | Recommends education and policy approaches to encourage skin-protective behaviors in various settings, including child care centers, primary and middle schools, outdoor recreational sites, and outdoor occupational settings.^9^
American Academy of Family Physicians (AAFP) | U.S. | 2014 | Endorses the USPSTF's previous recommendation that clinicians counsel children, adolescents, and young adults ages 10-24 who have fair skin about minimizing their exposure to UV radiation to reduce risk of skin cancer. Notes that the current evidence is insufficient to assess the balance of benefits and harms of patient skin self-exam.^10^
U.S. Surgeon General | U.S. | 2014 | Recommends clinicians play a role in reducing UV exposure by providing counseling to patients, particularly adolescents and young adults with fair skin.^11^
Institute for Clinical Systems Improvement (ICSI) | U.S. | 2013 | Recommends that counseling patients to limit sun exposure is reasonable.^12^ Endorses the USPSTF's previous recommendation statement that the current evidence is insufficient to assess the balance of benefits and harms of patient skin self-exam.^13^
American Academy of Pediatrics (AAP) | U.S. | 2011 | Recommends pediatricians educate patients and parents about UV radiation exposure and protective behaviors, such as avoiding sunburns, wearing clothing and hats, limiting outdoor activities during periods of peak sun exposure, wearing sunglasses, and applying sunscreen.^14^
Alberta Health Services | Canada | 2013 | Recommends counseling in health care settings, particularly for children, adolescents, and young adults, about minimizing exposure to UV radiation to reduce the risk of skin cancer.^15^ Recommends regular skin-self exam to help individuals become familiar with their skin and notice any changes.^16^
Royal Australian College of General Practitioners | Australia | 2012 | Recommends clinicians advise all individuals, particularly children, to adopt sun-protective measures such as minimizing sun exposure and using sunscreen.^17^ Recommends individuals engage in skin self-exam annually (low-risk), every 3-6 months (medium risk), or every 3 months (high-risk).^18^
National Institute for Health and Care Excellence (NICE) | U.K. | 2011 | Recommends health care providers participate in prevention activities, such as one-to-one or group counseling, to raise awareness of the risks of UV exposure and the benefits of sun-protective behaviors.^19^
International Agency for Research on Cancer (IARC), World Health Organization | International | 2001 | Recommends that health promotion interventions seek to increase appropriate use of sunscreen but cautions that sunscreen should not be used as a means of extending the duration of sun exposure.^20^

Appendix A Table 2 Sun Protection Habits Survey

[table image]

Source: Glanz K, Yaroch AL, Dancel M, . Measures of sun exposure and sun protection practices for behavioral and epidemiologic research. Arch Dermatol. 2008;144(2):217-22 18283179 .

## References

1 American Academy of Dermatology. AADA responds to the USPSTF recommendations on sun-protection counseling. American Academy of Dermatology [2017 January 3]. https://www.aad.org/media/news-releases/aada-responds-to-the-uspstf-recommendations-on-sun-protection-counseling.
2 American Academy of Dermatology. AADA provides input on skin cancer screening recommendation. American Academy of Dermatology [2017 January 3]. https://www.aad.org/media/news-releases/aada-provides-input-on-skin-cancer-screening-recommendation.
3 Skin Cancer Foundation. Foundation's Response to the Acting Surgeon General's Call to Action To Prevent Skin Cancer. Skin Cancer Foundation [2017 January 3]. http://www.skincancer.org/media-and-press/press-release-2014/surgeon.
4 Skin Cancer Foundation. Early Detection and Self Exams. Skin Cancer Foundation [2017 January 3]. http://www.skincancer.org/skin-cancer-information/early-detection.
5 American Cancer Society. Cancer Prevention & Early Detection Facts & Figures 2015-2016. Atlanta: American Cancer Society; 2015.
6 American Cancer Society. Skin exams. American Cancer Society [2017 January 3]. http://www.cancer.org/cancer/cancercauses/sunanduvexposure/skincancerpreventionandearlydetection/skin-cancer-prevention-and-early-detection-skin-exams.
7 American College of Obstetricians and Gynecologists. Committee opinion no. 626: the transition from pediatric to adult health care: preventive care for young women aged 18-26 years. Obstetrics and gynecology. 2015;125(3):752-4. PMID: 25730254.25730254
8 Michigan Quality Improvement Consortium. Routine Preventive Services for Children and Adolescents (Ages 2-21). Southfield, MI: Michigan Quality Improvement Consortium; 2015.
9 Guide to Community Preventive Services. Cancer Prevention and Control: Skin Cancer Prevention. Community Preventive Services Task Force; 2014.
10 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Leawood, KS: American Academy of Family Physicians; 2015.
11 U.S. Department of Health and Human Services. The Surgeon General's Call to Action to Prevent Skin Cancer. Washington, D.C.: U.S. Department of Health and Human Services, Office of the Surgeon General; 2014.
12 Wilkinson J, Bass C, Diem S, . Preventive Services for Children and Adolescents. Bloomington, MN: Institute for Clinical Systems Improvement; 2013.
13 Institute for Clinical Systems Improvement. Level III – Skin Cancer Screening and Counseling. Institute for Clinical Systems Improvement [2017 January 3]. https://www.icsi.org/guideline_sub-pages/preventive_services_adults/level_iii__skin_cancer_screening_and_counseling/.
14 Council on Environmental Health Section on Dermatology, Balk SJ Ultraviolet radiation: a hazard to children and adolescents. Pediatrics. 2011;127(3):588-97. PMID: 21357336.21357336
15 Alberta Provincial Cutaneous Tumour Team. Prevention of Skin Cancer: Clinical Practice Guideline CU-014. Edmonton, Canada: Alberta Health Services; 2013.
16 Alberta Health Services. Prevention of Skin Cancer. Alberta Health Services [2017 January 3]. http://www.albertahealthservices.ca/assets/info/hp/cancer/if-hp-cancer-guide-cu014-prevention.pdf.
17 Royal Australian College of General Practitioners. Guidelines for preventive activities in general practice 8th edition. East Melbourne, Australia: Royal Australian College of General Practitioners; 2012.
18 Royal Australian College of General Practitioners. Skin checks. Royal Australian College of General Practitioners [2017 January 3]. http://www.racgp.org.au/afp/2012/july/skin-checks/.
19 National Institute for Health and Care Excellence. Skin cancer prevention: public health guideline. National Institute for Health and Care Excellence; 2011.
20 International Agency for Research on Cancer. IARC Handbooks of Cancer Prevention Volume 5: Sunscreens. Lyon, France: World Health Organization; 2001.