# References

1 Moyer VA, U.S. Preventive Services Task Force. Vitamin D and calcium supplementation to prevent fractures in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 May 07;158(9):691-6. doi: 10.7326/0003-4819-158-9-201305070-00603. PMID: 23440163.23440163
2 Chung M, Lee J, Terasawa T, . Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2011 Dec 20;155(12):827-38. doi: 10.7326/00034819-155-12-201112200-00005. PMID: 22184690.22184690
3 Kanis JA. Assessment of Osteoporosis at the Primary Health Care Level. Geneva, Switzerland: World Health Organization Scientific Group; 2008.
4 Ensrud KE. Epidemiology of fracture risk with advancing age. J Gerontol A Biol Sci Med Sci. 2013 Oct;68(10):1236-42. doi: 10.1093/gerona/glt092. PMID: 23833201.23833201
5 Institute of Medicine. Dietary Reference Intakes for Calcium and Vitamin D. Washington, DC: The National Academies Press; 2011.
6 Office of the Surgeon General. Reports of the Surgeon General’s Workshop on Osteoporosis and Bone Health. 2002 December 12-13; Washington, DC. Office of the Surgeon General.
7 Seeman E, Delmas PD. Bone quality--the material and structural basis of bone strength and fragility. N Engl J Med. 2006 May 25;354(21):2250-61. doi: 10.1056/NEJMra053077. PMID: 1672361616723616.
8 Cooper C, Westlake S, Harvey N, . Review: developmental origins of osteoporotic fracture. Osteoporos Int. 2006;17(3):337-47. doi: 10.1007/s00198-005-2039-5. PMID: 16331359.16331359
9 LaFleur J, McAdam-Marx C, Kirkness C, . Clinical risk factors for fracture in postmenopausal osteoporotic women: a review of the recent literature. Ann Pharmacother. 2008 Mar;42(3):375-86. doi: 10.1345/aph.1K203. PMID: 18230704.18230704
10 Holroyd C, Cooper C, Dennison E. Epidemiology of osteoporosis. Best Pract Res Clin Endocrinol Metab. 2008 Oct;22(5):671-85. doi: 10.1016/j.beem.2008.06.001. PMID: 19028351.19028351
11 Cummings SR, Melton LJ. Epidemiology and outcomes of osteoporotic fractures. Lancet. 2002 May 18;359(9319):1761-7. doi: 10.1016/s0140-6736(02)08657-9. PMID: 12049882.12049882
12 Robbins J, Aragaki AK, Kooperberg C, . Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007 Nov 28;298(20):2389-98. doi: 10.1001/jama.298.20.2389. PMID: 18042916.18042916
13 Goss PE, Hershman DL, Cheung AM, . Effects of adjuvant exemestane versus anastrozole on bone mineral density for women with early breast cancer (MA.27B): a companion analysis of a randomised controlled trial. Lancet Oncol. 2014 Apr;15(4):474-82. doi: S1470-2045(14)70035-X [pii]; 10.1016/S1470-2045(14)70035-X [doi]. PMID: 24636210.24636210
14 Cranney A, Horsley T, O’Donnell S, . Effectiveness and safety of vitamin D in relation to bone health. Evid Rep Technol Assess (Full Rep). 2007 Aug(158):1-235. PMID: 18088161.18088161
15 Chung M, Balk EM, Brendel M, . Vitamin D and calcium: a systematic review of health outcomes. Evid Rep Technol Assess (Full Rep). 2009 Aug(183):1-420. PMID: 20629479.20629479
16 Manson JE, Brannon PM, Rosen CJ, . Vitamin D Deficiency - Is There Really a Pandemic? N Engl J Med. 2016 Nov 10;375(19):1817-20. doi: 10.1056/NEJMp1608005. PMID: 27959647.27959647
17 Newberry SJ, Chung M, Shekelle PG, . Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update) Evidence Report/Technology Assessment No. 217. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2012-00006-I.) AHRQ Publication No. 14-E004-EF. Rockville, MD: Agency for Healthcare Research and Quality; September 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm
18 Fraser WD, Milan AM. Vitamin D assays: past and present debates, difficulties, and developments. Calcif Tissue Int. 2013 Feb;92(2):118-27. doi: 10.1007/s00223-012-9693-3. PMID: 23314742.23314742
19 Pfeiffer CM, Lacher DA, Schleicher RL, . Challenges and Lessons Learned in Generating and Interpreting NHANES Nutritional Biomarker Data. Adv Nutr. 2017 Mar;8(2):290-307. doi: 10.3945/an.116.014076. PMID: 28298273.28298273
20 Malabanan A, Veronikis IE, Holick MF. Redefining vitamin D insufficiency. Lancet. 1998 Mar 14;351(9105):805-6. PMID: 9519960.9519960
21 Chapuy MC, Schott AM, Garnero P, . Healthy elderly French women living at home have secondary hyperparathyroidism and high bone turnover in winter. EPIDOS Study Group. J Clin Endocrinol Metab. 1996 Mar;81(3):1129-33. doi: 10.1210/jcem.81.3.8772587. PMID: 8772587.8772587
22 Holick MF, Siris ES, Binkley N, . Prevalence of Vitamin D inadequacy among postmenopausal North American women receiving osteoporosis therapy. J Clin Endocrinol Metab. 2005 Jun;90(6):3215-24. doi: 10.1210/jc.2004-2364. PMID: 15797954.15797954
23 Thomas MK, Lloyd-Jones DM, Thadhani RI, . Hypovitaminosis D in medical inpatients. N Engl J Med. 1998 Mar 19;338(12):777-83. doi: 10.1056/NEJM199803193381201. PMID: 9504937.9504937
24 Heaney RP, Dowell MS, Hale CA, . Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. J Am Coll Nutr. 2003 Apr;22(2):142-6. PMID: 12672710.12672710
25 Hansen KE, Jones AN, Lindstrom MJ, . Vitamin D insufficiency: disease or no disease? J Bone Miner Res. 2008 Jul;23(7):1052-60. doi: 10.1359/jbmr.080230. PMID: 18302509.18302509
26 Bischoff-Ferrari H. Vitamin D: what is an adequate vitamin D level and how much supplementation is necessary? Best Pract Res Clin Rheumatol. 2009 Dec;23(6):789-95. doi: 10.1016/j.berh.2009.09.005. PMID: 19945690.19945690
27 Office of Dietary Supplements, National Institutes of Health. Vitamin D: Moving Toward Evidence-based Decision Making in Primary Care. 2014 December 2-3; Bethesda, MD.
28 Taylor CL, Bailey RL, Carriquiry AL. Use of Folate-Based and Other Fortification Scenarios Illustrates Different Shifts for Tails of the Distribution of Serum 25-Hydroxyvitamin D Concentrations. J Nutr. 2015 Jul;145(7):1623-9. doi: 10.3945/jn.115.211185. PMID: 25972526.25972526
29 Dawson-Hughes B, Mithal A, Bonjour JP, . IOF position statement: vitamin D recommendations for older adults. Osteoporos Int. 2010 Jul;21(7):1151-4. doi: 10.1007/s00198-010-1285-3. PMID: 20422154.20422154
30 Cosman F, de Beur SJ, LeBoff MS, . Clinician’s guide to prevention and treatment of osteoporosis. Osteoporos Int. 2014 Oct;25(10):2359-81. doi: 10.1007/s00198-014-2794-2. PMID: 25182228.25182228
31 International Osteoporosis Foundation. New Vitamin D recommendations for older men and women. Nyon, Switzerland: International Osteoporosis Foundation; 2015. https://www.iofbonehealth.org/new-vitamin-d-recommendations-older-men-and-women. Accessed January 27, 2017.
32 Gutierrez OM, Farwell WR, Kermah D, . Racial differences in the relationship between vitamin D, bone mineral density, and parathyroid hormone in the National Health and Nutrition Examination Survey. Osteoporos Int. 2011 Jun;22(6):1745-53. doi: 10.1007/s00198-010-1383-2. PMID: 2084808120848081.
33 Cauley JA, Danielson ME, Boudreau R, . Serum 25-hydroxyvitamin D and clinical fracture risk in a multiethnic cohort of women: the Women’s Health Initiative (WHI). J Bone Miner Res. 2011 Oct;26(10):2378-88. doi: 10.1002/jbmr.449 [doi]. PMID: 21710614.21710614
34 Ginde AA, Liu MC, Camargo CA, Jr. Demographic differences and trends of vitamin D insufficiency in the US population, 1988-2004. Arch Intern Med. 2009 Mar 23;169(6):626-32. doi: 10.1001/archinternmed.2008.604. PMID: 19307527.19307527
35 Cauley JA, Lui LY, Ensrud KE, . Bone mineral density and the risk of incident nonspinal fractures in black and white women. JAMA. 2005 May 4;293(17):2102-8. doi: 10.1001/jama.293.17.2102. PMID: 15870413.15870413
36 Holick MF. Vitamin D deficiency. N Engl J Med. 2007 Jul 19;357(3):266-81. doi: 10.1056/NEJMra070553. PMID: 17634462.17634462
37 Wallace TC, Reider C, Fulgoni VL, 3rd. Calcium and vitamin D disparities are related to gender, age, race, household income level, and weight classification but not vegetarian status in the United States: Analysis of the NHANES 2001-2008 data set. J Am Coll Nutr. 2013;32(5):321-30. doi: 10.1080/07315724.2013.839905. PMID: 24219375.24219375
38 National Institutes of Health. Calcium. Dietary Supplement Fact Sheet. Bethesda, MD: Office of Dietary Supplements, National Institutes of Health; 2013. https://ods.od.nih.gov/factsheets/Calcium-HealthProfessional/#h6. Accessed January 30, 2017.
39 Morin SN, Lix LM, Majumdar SR, . Temporal trends in the incidence of osteoporotic fractures. Curr Osteoporos Rep. 2013 Dec;11(4):263-9. doi: 10.1007/s11914-013-0168-x. PMID: 2407848524078485.
40 Burge R, Dawson-Hughes B, Solomon DH, . Incidence and economic burden of osteoporosis-related fractures in the United States, 2005-2025. J Bone Miner Res. 2007 Mar;22(3):465-75. doi: 10.1359/jbmr.061113. PMID: 17144789.17144789
41 Ensrud KE, Schousboe JT. Clinical practice. Vertebral fractures. N Engl J Med. 2011 Apr 28;364(17):1634-42. doi: 10.1056/NEJMcp1009697. PMID: 21524214.21524214
42 Brauer CA, Coca-Perraillon M, Cutler DM, . Incidence and mortality of hip fractures in the United States. JAMA. 2009 Oct 14;302(14):1573-9. doi: 10.1001/jama.2009.1462. PMID: 19826027.19826027
43 Pike C, Birnbaum HG, Schiller M, . Direct and indirect costs of non-vertebral fracture patients with osteoporosis in the US. Pharmacoeconomics. 2010;28(5):395-409. doi: 10.2165/11531040-000000000-00000. PMID: 20402541.20402541
44 U.S. Department of Agriculture. Total Nutrient Intakes: Percent Reporting and Mean Amounts of Selected Vitamins and Minerals from Food and Beverages and Dietary Supplements, by Gender and Age, What We Eat in America, NHANES 2011-2012. Washington, DC: U.S. Department of Agriculture; 2014. www.ars.usda.gov/nea/bhnrc/fsrg. Accessed January 30, 2017.
45 Hoy MK, Goldman JD. Calcium intake of the U.S. population: What We Eat in America, NHANES 2009-2010 Food Surveys Research Group. Dietary Data Brief 13. Washington, DC: United States Department of Agriculture September 2014. https://www.ars.usda.gov/northeast-area/beltsville-md/beltsville-human-nutritionresearch-center/food-surveys-research-group/docs/wweia-data-briefs/
46 Pfeiffer CM, Schleicher RL, Johnson CL, . Assessing vitamin status in large population surveys by measuring biomarkers and dietary intake – two case studies: folate and vitamin D. Food Nutr Res. 2012;56:10.3402/fnr.v56i0.5944. doi: 10.3402/fnr.v56i0.5944. PMID: PMC3321254.
47 Taylor CL, Patterson KY, Roseland JM, . Including food 25-hydroxyvitamin D in intake estimates may reduce the discrepancy between dietary and serum measures of vitamin D status. J Nutr. 2014 May;144(5):654-9. doi: 10.3945/jn.113.189811. PMID: 24623845.24623845
48 Taylor CL, Carriquiry AL, Bailey RL, . Appropriateness of the probability approach with a nutrient status biomarker to assess population inadequacy: a study using vitamin D. Am J Clin Nutr. 2013 Jan;97(1):72-8. doi: 10.3945/ajcn.112.046094. PMID: 23097269.23097269
49 Jain RB. Recent Vitamin D Data from NHANES: Variability, Trends, Deficiency and Sufficiency Rates, and Assay Compatibility Issues. J Adv Nutr Hum Metab. 2016;2:e1208. doi: 10.14800/janhm.1208.
50 Chrysant SG, Chrysant GS. Controversy regarding the association of high calcium intake and increased risk for cardiovascular disease. J Clin Hypertens (Greenwich). 2014 Aug;16(8):545-50. doi: 10.1111/jch.12347 [doi]. PMID: 24890035.24890035
51 Silver DS. Calcium and vitamin D controversies. Rheum Dis Clin North Am. 2011 Aug;37(3):351-63, v. doi: S0889-857X(11)00032-9 [pii]; 10.1016/j.rdc.2011.07.005 [doi]. PMID: 22023896.22023896
52 Kantor ED, Rehm CD, Du M, . Trends in Dietary Supplement Use Among US Adults From 1999-2012. JAMA. 2016 Oct 11;316(14):1464-74. doi: 10.1001/jama.2016.14403. PMID: 27727382.27727382
53 LeBlanc ES, Zakher B, Daeges M, . Screening for vitamin D deficiency: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015 Jan 20;162(2):109-22. ; 10.7326/M14-1659 [doi]. PMID: 25419719.25419719
54 LeFevre ML, U.S. Preventive Services Task Force. Screening for vitamin D deficiency in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015 Jan 20;162(2):133-40. doi: 10.7326/m14-2450. PMID: 25419853.25419853
55 Nelson HD, Haney EM, Chou R, . U.S. Preventive Services Task Force evidence syntheses, formerly systematic evidence reviews. Screening for Osteoporosis: Systematic Review to Update the 2002 U.S. Preventive Services Task Force Recommendation. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
56 U.S. Preventive Services Task Force. Screening for osteoporosis: US Preventive Services Task Force recommendation statement. Ann Intern Med. 2011 Mar 1;154(5):356-64. doi: 10.7326/0003-4819-154-5-201103010-00307. PMID: 21242341.21242341
57 Fortmann SP, Burda BU, Senger CA, . Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville MD; 2013.
58 Moyer VA, U.S. Preventive Services Task Force. Vitamin, mineral, and multivitamin supplements for the primary prevention of cardiovascular disease and cancer: U.S. Preventive services Task Force recommendation statement. Ann Intern Med. 2014 Apr 15;160(8):558-64. doi: 10.7326/m14-0198. PMID: 24566474.24566474
59 Michael YL, Whitlock EP, Lin JS, . Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010 Dec 21;153(12):815-25. doi: 10.7326/0003-4819-153-12-201012210-00008. PMID: 21173416.21173416
60 U.S. Preventive Services Task Force. Draft Update Summary: Falls Prevention in Older Adults: Interventions. Rockville, MD: USPSTF Program Office; 2015. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryDraft/falls-prevention-in-older-adults-interventions1?ds=1&s=Falls%20Prevention. Accessed January 25, 2017.
61 Guirguis-Blake JM, Michael YL, Perdue LA, . Interventions to Prevent Falls in Older Adults: A Systematic Review for the U.S. Preventive Services Task Force Evidence Synthesis No. 159. AHRQ Publication No. 17-05232-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2018.
62 US Preventive Services Task Force. Interventions to prevent falls in community-dwelling older adults: US Preventive Services Task Force recommendation statement. JAMA. 2018;319(16):1-9.
63 United Nations Development Programme. Human Development Reports. Global Launch of 2015 Human Development Report. Human Development Report Office; 2015. http://hdr.undp.org/en/2015-report. Accessed December 5, 2016.
64 Higgins JP, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011 Oct 18;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
65 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville MD: Agency for Healthcare Research and Quality; September 2010. http://effectivehealthcare.ahrq.gov/
66 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177-88. PMID: 3802833.3802833
67 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration; 2011. www.handbook.cochrane.org. Accessed 24 Aug, 2016.
68 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267-70. doi: 10.7326/M13-2886. PMID: 24727843.24727843
69 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov
70 U.S. Preventive Services Task Force. Final Research Plan for Vitamin D, Calcium, or Combined Supplementation for the Primary Prevention of Fractures in Adults: Preventive Medication. Rockville, MD: U. S. Preventive Services Task Force; June 2016. https://www.uspreventiveservicestaskforce.org/Page/Document/final-researchplan/vitamin-d-calcium-or-combined-supplementation-for-the-primary-prevention-offractures-in-adults-preventive-medication
71 Jackson RD, LaCroix AZ, Gass M, . Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006 Feb 16;354(7):669-83. doi: 10.1056/NEJMoa055218. PMID: 16481635.16481635
72 Komulainen MH, Kroger H, Tuppurainen MT, . HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas. 1998 Nov 30;31(1):45-54. PMID: 10091204.10091204
73 Recker RR, Hinders S, Davies KM, . Correcting calcium nutritional deficiency prevents spine fractures in elderly women. J Bone Miner Res. 1996 Dec;11(12):1961-6. doi: 10.1002/jbmr.5650111218 [doi]. PMID: 8970899.8970899
74 Riggs BL, O, Fallon WM, Muhs J, . Long-term effects of calcium supplementation on serum parathyroid hormone level, bone turnover, and bone loss in elderly women. J Bone Miner Res. 1998 Feb;13(2):168-74. doi: 10.1359/jbmr.1998.13.2.168. PMID: 9495509.9495509
75 Dawson-Hughes B, Harris SS, Krall EA, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 1997 Sep 4;337(10):670-6. doi: 10.1056/nejm199709043371003. PMID: 9278463.9278463
76 Lips P, Graafmans WC, Ooms ME, . Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med. 1996 Feb 15;124(4):400-6. PMID: 8554248.8554248
77 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 2003 Mar 1;326(7387):469. doi: 10.1136/bmj.326.7387.469. PMID: 12609940.12609940
78 Scragg R, Stewart AW, Waayer D, . Effect of monthly high-dose vitamin d supplementation on cardiovascular disease in the vitamin d assessment study: A randomized clinical trial. JAMA Cardiology. 2017 doi: 10.1001/jamacardio.2017.0175.
79 Khaw KT., Stewart AW, Waayer D, . Effect of monthly high-dose vitamin D supplementation on falls and non-vertebral fractures: secondary and post-hoc outcomes from the randomised, double-blind, placebo-controlled ViDA trial. The Lancet Diabetes & Endocrinology. doi: 10.1016/S2213-8587(17)30103-1.
80 Chung M, Lee J, Terasawa T, . Correction: Vitamin D with or without calcium supplementation for prevention of cancer and fractures. Ann Intern Med. 2014;161(8):615. doi: 10.7326/L14-5020-7.
81 Li M, Xia WB, Xing XP, . Benefit of infusions with ibandronate treatment in children with osteogenesis imperfecta. Chin Med J (Engl). 2011 Oct;124(19):3049-53. PMID: 22040553.22040553
82 Lyons RA, Johansen A, Brophy S, . Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int. 2007 Jun;18(6):811-8. doi: 10.1007/s00198-006-0309-5. PMID: 17473911.17473911
83 Law M, Withers H, Morris J, . Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing. 2006 Sep;35(5):482-6. doi: 10.1093/ageing/afj080. PMID: 16641143.16641143
84 Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 2010 May 12;303(18):1815-22. doi: 10.1001/jama.2010.594. PMID: 20460620.20460620
85 Smith H, Anderson F, Raphael H, . Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology (Oxford). 2007 Dec;46(12):1852-7. doi: 10.1093/rheumatology/kem240. PMID: 17998225.17998225
86 Peacock M, Liu G, Carey M, . Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab; 2000. p. 3011-9.10999778
87 Glendenning P, Zhu K, Inderjeeth C, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012 Jan;27(1):170-6. doi: 10.1002/jbmr.524. PMID: 21956713.21956713
88 Reid IR, Mason B, Horne A, . Randomized controlled trial of calcium in healthy older women. Am J Med. 2006 Sep;119(9):777-85. doi: S0002-9343(06)00336-6 [pii]; 10.1016/j.amjmed.2006.02.038 [doi]. PMID: 16945613.16945613
89 Bolland MJ, Barber PA, Doughty RN, . Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 2008 Feb 2;336(7638):262-6. doi: bmj.39440.525752.BE [pii]; 10.1136/bmj.39440.525752.BE [doi]. PMID: 18198394.18198394
90 Prince RL, Devine A, Dhaliwal SS, . Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med. 2006 Apr 24;166(8):869-75. ; 10.1001/archinte.166.8.869 [doi]. PMID: 16636212.16636212
91 Lewis JR, Calver J, Zhu K, . Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res. 2011 Jan;26(1):35-41. doi: 10.1002/jbmr.176 [doi]. PMID: 20614474.20614474
92 Reid IR, Ames R, Mason B, . Randomized controlled trial of calcium supplementation in healthy, nonosteoporotic, older men. Arch Intern Med. 2008 Nov 10;168(20):2276-82. ; 10.1001/archinte.168.20.2276 [doi]. PMID: 19001206.19001206
93 Reid IR, Ames RW, Evans MC, . Long-term effects of calcium supplementation on bone loss and fractures in postmenopausal women: a randomized controlled trial. Am J Med. 1995 Apr;98(4):331-5. doi: 10.1016/S0002-9343(99)80310-6. PMID: 7709944.7709944
94 Ruml LA, Sakhaee K, Peterson R, . The effect of calcium citrate on bone density in the early and mid-postmenopausal period: a randomized placebo-controlled study. Am J Ther. 1999 Nov;6(6):303-11. PMID: 11329114.11329114
95 Reid IR, Ames RW, Evans MC, . Effect of calcium supplementation on bone loss in postmenopausal women. N Engl J Med. 1993 Feb 18;328(7):460-4. doi: 10.1056/nejm199302183280702. PMID: 8421475.8421475
96 Jackson RD, Lacroix AZ, Cauley JA, . The women’s health initiative calcium–vitamin D trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003 10//;13(9, Supplement):S98-S106. doi: http://dx.doi.org/10.1016/S10472797(03)00046-2.14575942
97 Bolland MJ, Grey A, Gamble GD, . Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women’s Health Initiative (WHI) limited-access data set. Am J Clin Nutr. 2011 Oct;94(4):1144-9. doi: ajcn.111.015032 [pii] 10.3945/ajcn.111.015032 [doi]. PMID: 21880848.21880848
98 Prentice RL, Pettinger MB, Jackson RD, . Health risks and benefits from calcium and vitamin D supplementation: Women’s Health Initiative clinical trial and cohort study. Osteoporos Int. 2013 Feb;24(2):567-80. doi: 10.1007/s00198-012-2224-2 [doi]. PMID: 23208074.23208074
99 Robbins JA, Aragaki A, Crandall CJ, . Women’s Health Initiative clinical trials: interaction of calcium and vitamin D with hormone therapy. Menopause. 2014 Feb;21(2):116-23. doi: 10.1097/GME.0b013e3182963901 [doi]. PMID: 23799356.23799356
100 Porthouse J, Cockayne S, King C, . Randomised controlled trial of supplementation with calcium and cholecalciferol (vitamin D3) for prevention of fractures in primary care. Br Med J. 2005(7498):1003-6. PMID: CN-00569278.15860827
101 Grant AM, Avenell A, Campbell MK, . Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005 May 7-13;365(9471):1621-8. doi: 10.1016/s0140-6736(05)63013-9. PMID: 15885294.15885294
102 Harwood RH, Sahota O, Gaynor K, . A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. 2004 Jan;33(1):45-51. PMID: 14695863.14695863
103 Pfeifer M, Begerow B, Minne HW, . Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000 Jun;15(6):1113-8. doi: 10.1359/jbmr.2000.15.6.1113. PMID: 10841179.10841179
104 Chapuy MC, Arlot ME, Duboeuf F, . Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. 1992(23):1637-42. doi: 10.1056/NEJM199212033272305. PMID: CN-00088609.1331788
105 Chapuy MC, Pamphile R, Paris E, . Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002(3):257-64. doi: 10.1007/s001980200023. PMID: CN-00379937.11991447
106 Flicker L, MacInnis RJ, Stein MS, . Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. J Am Geriatr Soc. 2005 Nov;53(11):1881-8. doi: 10.1111/j.1532-5415.2005.00468.x. PMID: 16274368.16274368
107 Salovaara K, Tuppurainen M, Karkkainen M, . Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res. 2010 Jul;25(7):1487-95. doi: 10.1002/jbmr.48. PMID: 20200964.20200964
108 Lappe JM, Travers-Gustafson D, Davies KM, . Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 2007 Jun;85(6):1586-91. PMID: 17556697.17556697
109 Lappe J, Watson P, Travers-Gustafson D, . Effect of vitamin D and calcium supplementation on cancer incidence in older women: a randomized clinical trial. JAMA. 2017 Mar 28;317(12):1234-43. doi: 10.1001/jama.2017.2115. PMID: 28350929.28350929
110 Zhu K, Devine A, Dick IM, . Effects of calcium and vitamin D supplementation on hip bone mineral density and calcium-related analytes in elderly ambulatory Australian women: a five-year randomized controlled trial. J Clin Endocrinol Metab. 2008 Mar;93(3):743-9. doi: 10.1210/jc.2007-1466. PMID: 18089701.18089701
111 Hin H, Tomson J, Newman C, . Optimum dose of vitamin D for disease prevention in older people: bEST-D trial of vitamin D in primary care. Osteoporos Int; 2017. p. 1-11.
112 LaCroix AZ, Kotchen J, Anderson G, . Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women’s Health Initiative calcium-vitamin D randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2009 May;64(5):559-67. doi: 10.1093/gerona/glp006. PMID: 19221190.19221190
113 Wactawski-Wende J, Kotchen JM, Anderson GL, . Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006 Feb 16;354(7):684-96. doi: 10.1056/NEJMoa055222. PMID: 16481636.16481636
114 Wallace RB, Wactawski-Wende J, O’Sullivan MJ, . Urinary tract stone occurrence in the Women’s Health Initiative (WHI) randomized clinical trial of calcium and vitamin D supplements. Am J Clin Nutr. 2011 Jul;94(1):270-7. doi: ajcn.110.003350 [pii]; 10.3945/ajcn.110.003350 [doi]. PMID: 21525191.21525191
115 Aloia JF, Talwar SA, Pollack S, . A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 2005 Jul 25;165(14):1618-23. doi: 10.1001/archinte.165.14.1618. PMID: 16043680.16043680
116 Bolland MJ, Grey A, Avenell A, . Calcium supplements with or without vitamin D and risk of cardiovascular events: reanalysis of the Women’s Health Initiative limited access dataset and meta-analysis. BMJ. 2011;342:d2040. PMID: 21505219.21505219
117 Blondon M, Rodabough RJ, Budrys N, . The effect of calcium plus vitamin D supplementation on the risk of venous thromboembolism. From the Women’s Health Initiative Randomized Controlled Trial. Thromb Haemost. 2015 May;113(5):999-1009. ; 10.1160/TH14-05-0478 [doi]. PMID: 25672892.25672892
118 Donneyong MM, Hornung CA, Taylor KC, . Risk of heart failure among postmenopausal women: a secondary analysis of the randomized trial of vitamin D plus calcium of the women’s health initiative. Circ Heart Fail. 2015 Jan;8(1):49-56. doi: CIRCHEARTFAILURE.114.001738 [pii] 10.1161/CIRCHEARTFAILURE.114.001738 [doi]. PMID: 25398967.25398967
119 Komulainen M, Kroger H, Tuppurainen MT, . Prevention of femoral and lumbar bone loss with hormone replacement therapy and vitamin D3 in early postmenopausal women: a population-based 5-year randomized trial. J Clin Endocrinol Metab. 1999 Feb;84(2):546-52. doi: 10.1210/jcem.84.2.5496. PMID: 10022414.10022414
120 Cherniack EP, Florez HJ, Hollis BW, . The response of elderly veterans to daily vitamin D3 supplementation of 2,000 IU: a pilot efficacy study. J Am Geriatr Soc. 2011 Feb;59(2):286-90. doi: 10.1111/j.1532-5415.2010.03242.x. PMID: 21288233.21288233
121 Tang JY, Fu T, Leblanc E, . Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer: post hoc analyses of the women’s health initiative randomized controlled trial. J Clin Oncol. 2011 Aug 1;29(22):3078-84. doi: JCO.2011.34.5967 [pii]; 10.1200/JCO.2011.34.5967 [doi]. PMID: 21709199.21709199
122 Brunner RL, Wactawski-Wende J, Caan BJ, . The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women’s Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutr Cancer. 2011;63(6):827-41. doi: 10.1080/01635581.2011.594208 [doi]. PMID: 21774589.21774589
123 Whitlock EP, Eder M, Thompson JH, . An approach to addressing subpopulation considerations in systematic reviews: the experience of reviewers supporting the U.S. Preventive Services Task Force. Syst Rev. 2017 Mar 02;6(1):41. doi: 10.1186/s13643-017-0437-3. PMID: 28253915.28253915
124 Creighton University. Calcium and Vitamin D Malnutrition in Elderly Women. In: ClinicalTrials.gov [Internet]. Washington, DC: NIH RePORTER. [cited 2006 July 12]. https://www.clinicaltrials.gov/ct2/show/NCT00352170?term=NCT00352170&rank=1. NLM Identifier: NCT00352170.
125 Chung M, Tang AM, Fu Z, . Calcium intake and cardiovascular disease risk: an updated systematic review and meta-analysis. Ann Intern Med. 2016 Dec 20;165(12):856-66. doi: 10.7326/M16-1165. PMID: 27776363.27776363
126 Reid IR, Bristow SM, Bolland MJ. Cardiovascular complications of calcium supplements. J Cell Biochem. 2015 Apr;116(4):494-501. doi: 10.1002/jcb.25028. PMID: 25491763.25491763
127 Mao PJ, Zhang C, Tang L, . Effect of calcium or vitamin D supplementation on vascular outcomes: a meta-analysis of randomized controlled trials. Int J Cardiol. 2013 Oct 30;169(2):106-11. doi: 10.1016/j.ijcard.2013.08.055. PMID: 24035175.24035175
128 Bolland MJ, Avenell A, Baron JA, . Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ. 2010;341:c3691. doi: 10.1136/bmj.c3691. PMID: 20671013.20671013
129 Wang L, Manson JE, Sesso HD. Calcium intake and risk of cardiovascular disease: a review of prospective studies and randomized clinical trials. Am J Cardiovasc Drugs. 2012 Apr 1;12(2):105-16. doi: 10.2165/11595400-000000000-00000. PMID: 22283597.22283597
130 Manson JE, Allison MA, Carr JJ, . Calcium/vitamin D supplementation and coronary artery calcification in the Women’s Health Initiative. Menopause. 2010 Jul;17(4):683-91. doi: 10.1097/gme.0b013e3181d683b5. PMID: 20551849.20551849
131 Finkelstein JS. Calcium plus vitamin D for postmenopausal women--bone appetit? N Engl J Med. 2006 Feb 16;354(7):750-2. doi: 10.1056/NEJMe068007. PMID: 16481643.16481643
132 Bolland MJ, Grey A. A case study of discordant overlapping meta-analyses: vitamin D supplements and fracture. PLoS One. 2014;9(12):e115934. doi: 10.1371/journal.pone.0115934. PMID: 25551377.25551377
133 Avenell A, Mak JC, O’Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database Syst Rev. 2014 Apr 14(4):CD000227. doi: 10.1002/14651858.CD000227.pub4. PMID: 24729336.24729336
134 Weaver CM, Alexander DD, Boushey CJ, . Calcium plus vitamin D supplementation and risk of fractures: an updated meta-analysis from the National Osteoporosis Foundation. Osteoporos Int. 2016 Jan;27(1):367-76. doi: 10.1007/s00198-015-3386-5. PMID: 26510847.26510847
135 Weaver CM, Dawson-Hughes B, Lappe JM, . Erratum and additional analyses re: Calcium plus vitamin D supplementation and the risk of fractures: an updated metaanalysis from the National Osteoporosis Foundation. Osteoporos Int. 2016 Aug;27(8):2643-6. doi: 10.1007/s00198-016-3699-z. PMID: 27401092.27401092
136 Bolland MJ, Avenell A, Grey A, . Errors in NOF meta-analyses of calcium and vitamin D supplements. Osteoporos Int. 2016 Aug;27(8):2637-9. doi: 10.1007/s00198-015-3466-6. PMID: 26992924.26992924
137 Lappe JM, Davies KM, Travers-Gustafson D, . Vitamin D status in a rural postmenopausal female population. J Am Coll Nutr. 2006 Oct;25(5):395-402. PMID: 17031008.17031008