# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Mei Chung, PhD, Joann Manson, MD, DrPH, and two additional anonymous reviewers; five Federal partner reviewers; and RTI International—University of North Carolina EPC staffCarol Woodell, BSPH, Miriam Tardif-Douglin, B. Lynn Whitener, DrPH, Daniel Jonas, MD, MPH, Janice Handler, and Loraine Monroe.