# 4 Discussion

## Summary of Evidence

Table 6 provides a summary of findings and applicability organized by KQ and then by intervention (vitamin D alone, calcium alone, or vitamin D with calcium). In addition to a summary of effect estimates, this table also includes an assessment of consistency and precision of the effect estimate(s), body of evidence limitations, and study quality, which we used to assign a strength of evidence rating for each intervention and outcome.

Table 6 Summary Of Evidence For Fracture Prevention And Harms Of Supplementation With Vitamin D, Calcium, Or Combined Supplementation

Intervention | No. of Studies and Design (k); No. of Participants (N) | Summary of Findings | Consistency Precision | Reporting Bias | Body of Evidence Limitations | Applicability | Overall Quality | EPC Assessment of Strength of Evidence
KQ 1—Benefits related to prevention of fractures
Vitamin D alone | k=4 RCTs; N=10,606 | Over 3.3 to 5 years: Total Fracture (1 RCT; N=2,686): ARD, -2.26% (95% CI, -4.53% to 0.00%) RR^*^, 0.78 (95% CI, 0.61 to 0.99) Hip (3 RCTs; N=5,416; I^2^=0%): Pooled ARD, -0.01% (95% CI, -0.80% to 0.78%) Pooled RR, 1.08 (95% CI, 0.79 to 1.48) Nonvertebral (2 RCTs, N=5,340): Smaller study (n=232): ARD, -3.45% (95% CI, -11.55% to 4.66%) RR, 0.64 (95% CI, 0.29 to 1.42) Larger study (n=5,108): ARD, 0.77% (95% CI, -0.51% to 2.04%) Adjusted HR, 1.19 (95% CI, 0.94 to 1.50) Clinical vertebral (1 RCT, N=2,686): ARD, -0.75% (95% CI, -1.73% to 0.23%) RR, 0.63 (95% CI, 0.35 to 1.14) Two studies used in sensitivity analyses reported increases in incidence (one fracture type has a significant increase), one study reported nonsignificant decrease. | Consistent/imprecise | Undetected | Studies not powered for fracture outcomes; variability in populations and outcome specification and ascertainment; not enough studies to evaluate the influence of dose, route, or frequency on incidence. | Three of the four studies included men, studies conducted outside U.S. but likely applicable to U.S. settings, doses include 300 IU and 400 IU per day, 100,000 IU every 4 months, and 100,000 IU every month (after an initial 200,000 IU loading dose) | Fair | Low for no benefit
Calcium alone | k=2 RCTs; N=339 | Over 4 years: Nonvertebral (1 RCT, N=236): ARD, -1.01% (95% CI, -8.58% to 6.56%) RR, 0.90 (95% CI, 0.41 to 1.96) Morphometric vertebral (2 RCTs, N=339): ARDs, 7.26% (95% CI, -9.84% to 24.36%) and -0.97% (95% CI, -7.57% to 5.63%) RRs, 1.34 (95% CI, 0.68 to 2.64) and 0.87 (95 % CI, 0.35 to 2.19) Studies used in sensitivity analyses reported mostly nonsignificant increases and decreases in various fracture outcomes. | Inconsistent/imprecise | Detected^†^ | Studies not powered for fracture outcomes; limited fracture outcomes reported; not enough studies to evaluate the influence of dose, route, or frequency on incidence. | Post-menopausal women in U.S., doses included 1,200 mg and 1,600 mg per day | Fair | Insufficient
Vitamin D with calcium | k=2 RCTs; N=36,727 | Over 3 to 7 years: Total fracture (1 RCT; N=36,282): ARD, -0.35% (95% CI, -1.02% to 0.31%) HR, 0.96 (95% CI, 0.91 to 1.02) Hip (2 RCTs, N=36,671): Larger trial (N=36,282)^‡^: ARD, -0.14% (95% CI, -0.34% to 0.07%) HR, 0.88 (95% CI, 0.72 to 1.08) Nonvertebral fractures (1 RCT, N=389): ARD, -6.99% (95% CI, -12.71% to -1.27%) RR, 0.46 (95% CI, 0.23 to 0.90) Clinical vertebral (1 RCT, N=36,282): ARD, -0.09% (95% CI, -0.30% to 0.12%) HR, 0.90 (95% CI, 0.74 to 1.10) Study used in sensitivity analyses reported nonsignificant increases and decreases in various fracture outcomes. | Inconsistent/imprecise | Detected^†^ | Not enough studies to evaluate the influence of dose, route, or frequency on incidence; participants allowed to take personal vitamin D and calcium supplements during the trial in the larger of the two trials. | Post-menopausal women in U.S.; the smaller of the two trials included men; vitamin D doses were 400 IU and 700 IU per day, calcium doses were 500 mg and 1,000 mg per day. | Fair | Low for no benefit^§^
KQ 2—Harms of supplementation
All-cause mortality
Vitamin D alone | k=4 RCTs; N=10,599 | Over 3.3 to 5 years: Pooled ARD, -0.74% (95% CI, -1.80% to 0.32%; I^2^=19.6%) Pooled RR, 0.91 (95% CI, 0.82 to 1.01; I^2^=0%) Studies used in sensitivity analysis reported a similar nonsignificant decrease in incidence. | Consistent/imprecise | Undetected | Studies not pow ered to assess all-cause mortality. | Older men and Post-menopausal women non in-U.S. countries though likely applicable to U.S.; doses were 300 IU and 400 IU per day and 100,000 IU every month or 4 months. | Fair | Low for no harm
Calcium alone | k=1 RCT; N=290 | Over 2 years: ARD^ǁ^, 0.01% (95% CI, -2.29% to 2.32%) RR^ǁ^, 1.01 (95% CI, 0.09 to 11.06) Studies used in sensitivity analysis reported nonsignificant increases and decreases in incidence. | Unknown consistency (single study)/very imprecise^ǁ^ | Undetected | Study not powered to assess all-cause mortality; no reporting of how mortality ascertained. | Predominantly white men age 40 years and older in New Zealand though likely applicable to U.S., doses include 600 mg and 1,200 mg per day. | Fair | Insufficient
Vitamin D with calcium | k=2 RCTs; N=38,479 | Over 4 years (smaller trial, n=2,197): ARD, -0.19% (95% CI, -0.90% to 0.52%) RR, 0.77 (95% CI, 0.29 to 2.07) Over 7 years (larger trial, n=36,282): ARD, -0.36% (95% CI, -0.78% to 0.05%) HR, 0.91 (95% CI, 0.83 to 1.01) Study used in sensitivity analysis reported a nonsignificant increased incidence. | Consistent/imprecise | Undetected | Studies not powered to assess all-cause mortality; participants allowed to take personal vitamin D and calcium supplements in larger trial. | Post-menopausal women in U.S.; vitamin D dose 400 or 2,000 IU per day, calcium dose 1,000 to 1,500 mg per day. | Fair | Low for no harm
Incident kidney stones
Vitamin D alone | No eligible studies n main analysis | NA | NA | NA | NA | NA | NA | Insufficient
Calcium alone | k=3 RCTs; N=1,259 | Over 2 to 4 years: Pooled ARD, 0.00% (95% CI, -0.88% to 0.87%; I^2^=0%) Pooled RR, 0.68 (95% CI, 0.14 to 3.36; I^2^=0%) Nonsignificant increases and decreases in studies used in sensitivity analysis. | Consistent/imprecise | Undetected | Studies not powered to assess incident kidney stones; limited information on outcome specification and ascertainment. | Post-menopausal women in U.S. and New Zealand, doses ranging from 600 mg to 1,600 mg per day. | Fair | Low for no harm
Vitamin D with calcium | k=3 RCTs; N=39,213 | Pooled ARD, 0.33% (95% CI, 0.05% to 0.60%; I^2^=0%) Pooled RR, 1.18 (95% CI, 1.04 to 1.35; I^2^=0%) No events reported in either study group by study used in sensitivity analysis. | Consistent/precise (primarily considering the largest of 2 trials)^¶^ | Undetected | Studies not powered to assess incident kidney stones; participants allowed to take personal vitamin D and calcium supplements during in largest trial. | Post-menopausal women in U.S.; vitamin D dose 400 IU, 1,000 IU and 2,000 IU per day, calcium dose 1,000 mg and 1,400 to 1,500 mg per day. | Fair | Moderate for harm
Incident CVD
Vitamin D alone | k=3 RCTs; N=8,021 | Over 3.3 to 5 years in the two larger trials (n=2,686 and n=5,108)^#^ : Myocardial infarction: ARD, -0.72% (95% CI, -3.56% to 2.12%) RR, 0.94 (95% CI, 0.77 to 1.15) and ARD, -0.12% (95% CI, -0.71% to 0.47%) HR, 0.90 (95% CI, 0.54 to 1.50) Cerebrovascular disease/Stroke: ARD, 0.27% (95% CI, -1.74% to 2.29%) RR, 1.02 (95% CI, 0.77 to 1.36) and ARD, -0.04% (95% CI, -0.60% to 0.51%) HR, 0.95, (95% CI, 0.55 to 1.62) Nonsignificant increases and decreases in incidence in studies used in sensitivity analysis. | Consistent/imprecise | Undetected | Only one study powered for CVD events; varying control event rates suggest heterogeneity in populations, outcome specifications, and ascertainment methods. | Post-menopausal women and men in U.S., U.K., and New Zealand; doses include 300 IU per day and 100,000 IU every 1 to 4 months. | Fair | Low for no harm
Calcium alone | k=1 RCT; N=290 | Over 2 years: Myocardial infarction: 600 mg dose: ARD, 1.02% (95% CI, -1.75% to 3.80%) RR, 3.03 (95% CI, 0.12 to 73.49) 1,200 mg dose: ARD, 2.15% (95% CI, -1.38% to 5.68%) RR, 5.32 (95% CI, 0.26 to 109.35) Mostly nonsignificant increases in incidence in studies used in sensitivity analysis. | Unknown consistency (single study)/Very imprecise^**^ | Undetected | Study not powered for CVD events. | Predominantly white men age 40 and older in New Zealand though likely applicable to U.S., doses include 600 mg and 1,200 mg per day. | Fair | Insufficient
Vitamin D with calcium | k=1 RCT; N=36,282 | Over 7 years: Myocardial infarction: ARD, 0.11% (95% CI, -0.20% to 0.41%) HR, 1.03 (95% CI, 0.90 to 1.19) Stroke: ARD, -0.09% (95% CI, -0.38% to 0.20%) HR, 0.95 (95% CI, 0.82 to 1.10) VTE: ARD, -0.16% (95% CI, -0.44% to 0.12%) HR, 0.92 (95% CI, 0.79 to 1.07) Heart failure hospitalization: ARD, -0.11% (95% CI, -0.40% to 0.18%) HR, 0.95 (95% CI, 0.82 to 1.09) Nonsignificant decrease in incidence in study used in sensitivity analysis, but estimates were very imprecise. | Unknown consistency (single study)/precise | Undetected | Study not powered for CVD events; participants allowed to take personal vitamin D and calcium supplements during the trial in the larger of the two trials. | Post-menopausal women in U.S.; vitamin D dose 400 IU per day, calcium dose 1,000 mg per day. | Fair | Low for no harm
Incident cancer
Vitamin D alone | k=2 RCTs; N=2,918 | Over 5 years: Any incident cancer: ARDs, 1.08% (95% CI, -1.50% to 3.66%) and -0.82% (-4.63% to 2.99%) RRs, 1.09 (95% CI, 0.86 to 1.36) and 0.68 (95% CI, 0.12 to 4.02) Nonsignificant increases and decreases in incidence in studies used in sensitivity analyses. | Inconsistent/Imprecise | Undetected | Studies not powered for cancer outcomes; no validation of self-reported cancers. | Older men and Post-menopausal women; doses include 300 IU per day and 100,000 IU every 4 months | Fair | Insufficient
Calcium alone | k=1 RCT; N=733 | Over 4 years: Any incident nonskin cancer: ARD, -3.12% (-6.56% to 0.31%) RR, 0.55 (95% CI, 0.29 to 1.03) Nonsignificant increase in incidence in study used in sensitivity analysis, but estimates very imprecise. | Unknown consistency (single study)/Imprecise | Undetected | Study not powered for cancer outcomes. | Post-menopausal women in the U.S. without a recent history of cancer, dose 1,400 to 1,500 mg per day | Good | Insufficient
Vitamin D with calcium | k=3 RCTs; N=39,213 | Over 4 to 7 years: Total (nonskin cancer) Pooled ARD, -1.48% (95% CI, -3.32% to 0.35%; I^2^=70.9%) Pooled RR, 0.73 (95% CI, 0.49 to 1.10; I^2^=75.8%) Nonsignificant decrease in incidence in study used in sensitivity analysis, but estimates very imprecise. | Inconsistent/Precise (primarily considering the largest of the trials) | Undetected | Largest study not powered for cancer outcomes; participants allowed to take personal vitamin D and calcium supplements during the trials. | Post-menopausal women in U.S.; vitamin D dose 400 IU/d, 1,000 IU/d, 2,000 IU/d, calcium dose 1,000 mg/d and 1,400 to 1,500 mg/d. | Fair | Low for no harm

* Adjusted estimate reported by the study; unadjusted estimate based on raw data in article was 0.80 (95% CI, 0.63 to 1.00).

† We identified one RCT that was registered with a primary study aim of evaluating the impact of calcium alone and vitamin D with calcium supplementation on fracture incidence. According to the studyʼs corresponding author, alendronate became available during the study and about 20 percent of the study population was started on it; the trial found null findings with respect to fracture incidence and were not published. (Personal communication with Joan Lappe 12/22/2016).

‡ Only one hip fracture (in control group) occurred in the smaller of the two trials.^75^

§ Though findings between trials were inconsistent, we primarily relied on the larger trial (WHI CaD Trial) to derive the strength of evidence assessment.

ǁ Reflects effect estimates of the 600 mg or 1,200 mg calcium dose compared with placebo. This trial is considered very imprecise because the outcome was very rare; only one participant in each active study group died.

¶ The smaller trial (N=734) was considered very imprecise because the outcome was very rare; only one participant in each study group had kidney stones.^108^

# The smallest trial (N=232) reported one myocardial infarction and one CABG in treatment group; no events in control group.^72^

** This trial is considered very imprecise because the outcome was rare; no participants in the control group had any events, one participant in the 600 mg group had an event and two participants in the 1,200 mg group had an event.^92^

Abbreviations: ARD=absolute risk difference; CABG=coronary artery bypass graft; CI=confidence interval; CVD=cardiovascular disease; d=day; EPC=Evidence-Based Practice; HR=hazard ratio; IU=international units; KQ=Key Question; mg=milligram; N or No=Number; NA=Not Applicable; RCT =randomized, controlled trial; RR=relative risk ratio; U.S.=United States; VTE=venous thromboembolism.

### Evidence for Effect of Supplementation on Fracture Prevention

Among the community-dwelling populations without prior history of fractures or known vitamin deficiency or osteoporosis included in this review, we rated the strength of evidence as low for no benefit of supplementation with vitamin D alone or vitamin D with calcium on fracture prevention over 3–7 years. This is consistent with the findings of the prior review and is not surprising given that only one new study was identified. Findings were imprecise and confidence intervals in all but one study included the null effect and the absolute differences in incidence reported may not be clinically meaningful. Few studies were powered for fractures as a primary end point, and even those that were (i.e., the WHI CaD Trial) were powered based on an effect size that was nearly twice as large as what was observed in the trial. Although the primary intent-to-treat analysis in the WHI CaD Trial was a null effect, some consider the bone density changes observed, the favorable per-protocol analyses of adherent participants, and some of the favorable subgroup analyses among nonusers of supplements at baseline and among older participants as evidence of a favorable effect on bone health.^71^ We did not consider any subgroup analyses findings in our assessment of the strength of evidence because of the known methodologic limitations and challenges associated with interpreting subgroup findings.^123^

We found limited evidence to draw conclusions regarding the impact of calcium alone on fracture prevention and rated the strength of evidence as insufficient. We found only two eligible studies (N=339). Only one reported a clinical fracture outcome in addition to incident morphometric vertebral fractures; the other reported only morphometric vertebral fractures. Small sample sizes and relatively rare event rates in the studies led to imprecise effect estimates.

The body of evidence on vitamin D alone is applicable to men and postmenopausal women, while the body of evidence for vitamin D with calcium and for calcium alone was limited to postmenopausal women. Daily doses of vitamin D ranged from 300 to 700 IU; one study used a 100,000 IU oral dose every 4 months (equivalent to 833 IU per day). Daily oral doses of calcium ranged from 500 to 1,600 mg. However, not enough eligible studies were identified to ascertain the influence of dose, route, or frequency on incident fractures.

We found some evidence of reporting bias for this KQ. One study (N=1,180) comparing calcium alone, vitamin D with calcium, or placebo was designed with fractures as a primary outcome and was completed in 2005, although no fracture outcomes have been published to date. Other study findings have been published.^108,^ ^124^ Per the study author, data from the study suggested no effect on fracture incidence; however, the study was not published because of concerns related to study contamination because of participant use of alendronate, which came to market during the study (personal communication with author). The identification of other unpublished studies with null findings would increase the certainty for drawing conclusions about the lack of effect of supplementation on fracture prevention.

### Evidence for Effect of Supplementation on Harms

This review focused primarily on four harms; all-cause mortality, kidney stones, CVD, and cancer. We were unable to ascertain the impact of dose, duration, or frequency on these harms because not enough eligible studies were available. Though cohort and case-control studies of supplementation were eligible for KQ 2 outcomes in this review, we excluded those identified through our search for poor quality because of many of the methodologic limitations also noted by others.^125,^ ^126^ Further, we did not consider studies evaluating the association between serum vitamin D levels and all-cause mortality, kidney stones, CVD, or cancer incidence as this has been previously synthesized.^15^ Thus, the evidence for harms that we summarized on behalf of the USPSTF comes from randomized controlled trials.

The evidence for the effect of supplementation with vitamin D alone or with calcium on all-cause mortality over 3–7 years suggests no clinically meaningful harm. The absolute risk differences ranged from -1.9 percent to 0.1 percent, but findings were imprecise; thus, we assigned a low strength of evidence to this finding. This body of evidence is applicable to men and postmenopausal women. We found the evidence for calcium alone to be limited for assessing impact on all-cause mortality. The single study available suggests no effect on mortality, but was very imprecise, and only included men. Thus, the strength of evidence for calcium alone on this outcome was rated as insufficient.

The evidence for the impact of supplementation on incident kidney stones was mixed. We identified no eligible studies of vitamin D alone that reported this outcome, resulting in an insufficient strength of evidence rating. The evidence for calcium alone suggests no increased incidence of kidney stones over 2–4 years, although findings are imprecise. Further, this body of evidence was limited by lack of information on how kidney stone outcomes were ascertained; thus, we assigned a low strength of evidence to this finding. The body of evidence on vitamin D with calcium comes from three RCTs. One of the trials (the WHI CaD Trial) was large and provided reasonably precise estimates of a small harm, and when pooled with two smaller studies with nonsignificant differences, this harm persisted. %%%Thus, we assigned a moderate strength of evidence for harm.

The evidence for the effect of supplementation with vitamin D alone or with calcium suggests no clinically meaningful harm with respect to CVD outcomes over 4–7 years. The body of evidence related to vitamin D alone included three RCTs that were consistent, but the estimates of effect were imprecise. The body of evidence for vitamin D with calcium was limited to a single study in women (WHI CaD Trial) with a sufficient sample size and event rate for precise estimates. Thus, we assigned a low strength of evidence for no harm for vitamin D alone or with calcium interventions. Findings from one of the two post hoc analyses of the WHI CaD Trial suggested that trial participants assigned to supplementation with vitamin D and calcium who were not taking personal supplements at the time of randomization had a marginally increased risk of cardiovascular events relative to those who were taking personal supplements at the time of randomization.^116^ However, the post hoc analysis by the WHI CaD study authors did not report similar findings,^98^ possibly because of slight differences in the way in which outcomes were specified between the two analyses.

We found the evidence limited for assessing the effect of calcium alone on CVD outcomes. The single study suggested no effect over 2 years but was limited by imprecise estimates and minimal information about outcome specification and ascertainment; thus, we rated this body of evidence as insufficient. The role of dietary and supplemental calcium on intermediate CVD outcomes (i.e., vascular calcification) and clinical CVD outcomes has been the subject of recent debate, with several analyses and meta-analyses published related to this issue in the past several years.^125-130^ Most of the meta-analyses and systematic reviews on this topic included broader study populations and settings (e.g., institutionalized elderly, participants with prior history of fracture) than specified in our review. These analyses have found mixed results, some suggesting a small increased risk for CVD^126,^ ^128^ and others suggesting no effect (either harm or benefit)^125,^ ^129^ or inconclusive findings.^127^ Several of these reviews included observational study designs. Of particular concern in using observational evidence to assess this relationship is that osteoporosis (a common indication for calcium supplement) and CVD risk factors overlap (e.g., smoking, physical activity), leading to high potential for confounding when looking at the association between calcium use and CVD events.

Last, we found the evidence for the impact of vitamin D alone and calcium alone to be limited for drawing conclusions related to the impact of supplementation on cancer incidence; thus, we rated these bodies of evidence as insufficient. Two RCTs of vitamin D alone reported inconsistent and imprecise findings; only a single study reported the impact of calcium alone and its findings were imprecise. The evidence for vitamin D with calcium supplementation over 4–7 years suggests no increased cancer incidence, but results were somewhat inconsistent; thus, we assigned a low strength of evidence to this finding. These findings are only applicable to postmenopausal women.

### Limitations of the Evidence

Most studies were not powered for the fracture or harm outcomes considered in this review; thus, small sample sizes and low event rates resulted in imprecise effect estimates. Some studies, notably the WHI CaD Trial, allowed for use of personal calcium and vitamin D supplements during the study; thus, these trials could be characterized as trials of provider-directed supplementation, and some have suggested this design feature as an explanation for the null intention-to-treat analysis findings reported by the WHI CaD Trial.^131^

Heterogeneity in outcome specification is another limitation of this body of evidence. The specific types of fractures that were considered as contributing to “total fracture” included both traumatic and osteoporotic in most studies, and the specific sites contributing to total fractures varied across studies. Author queries were required to determine whether some studies reporting vertebral fractures were reporting clinical or morphometric fractures. Studies evaluating harms varied in specificity of definition or rigor of harm outcome ascertainment. Because harms were rarely the main study aim, little information was provided regarding how harms were defined, ascertained, or validated. Some studies relied on self-report, some on adverse event reporting during study monitoring; others relied on secondary data sources (registries, claims, death certificates) to identify cases. Although some evidence on men exists, the majority of this body of evidence is applicable to postmenopausal women, and few studies include populations that are racially representative of the U.S. population. Finally, only a few studies evaluated doses more than 800 IU per day. The evidence on calcium included doses ranging from 400 mg to 1,600 mg per day.

Because this review was narrower in scope than other published reviews of vitamin D (with or without calcium), the conclusions differ somewhat from the conclusions drawn from reviews with a broader or different scope. Bolland and Grey discuss the issue of discordant results from different meta-analyses on the same topic using vitamin D supplementation and fracture as an example.^132^ In their analysis, differences in trial selection, outcome definitions used, and analytic approaches explain the majority of differences in findings. Across a body of evidence of 25 trials, they found strong statements concluding both benefit and no benefit. Thus, it is important to consider the scope of the populations and interventions included when drawing conclusions from the body of evidence in this review to avoid inappropriate comparisons to reviews with a different scope. We contrast our findings with two recent systematic reviews below.

The 2014 Cochrane review evaluated vitamin D and vitamin D analogues for preventing fractures and, similar to our review, found no benefit for vitamin D alone; however, they concluded that vitamin D with calcium may prevent fracture.^133^ The study populations considered in the Cochrane review included participants with osteoporosis and institutionalized participants and secondary prevention populations. The fracture benefits overall appear to be largely attributable to benefits among the high-risk populations, with little to no benefit in lower-risk populations (1 fewer hip fracture per 1,000 community-dwelling adults per year [95% CI, 0 to 2]). Like our review, the Cochrane review concluded that vitamin D with calcium was associated with increased gastrointestinal and renal disease, but did not adversely affect the risk of death.

The 2016 systematic review and meta-analysis of calcium and vitamin D supplementation conducted on behalf of the National Osteoporosis Foundation (NOF) included eight trials.^134-136^ Two were conducted in institutional settings, two were exclusively secondary prevention trials, and the study population of one trial had more than 50 percent of participants with a prior fracture; thus, all these studies were out of scope for our update review. Of the remaining three trials in the NOF analysis, we used one in our sensitivity analyses because it had between 20 and 50 percent of subjects with a history of prior fracture.^107^ The other two trials, Dawson-Hughes et al^75^ and the WHI CaD trial,^71^ were included in our review; however, the NOF analysis used data from WHI CaD subgroups related to adherence to assigned pills and personal supplement use, not data from the intent-to-treat analysis. The NOF analysis reported an overall RR for total fracture incidence of 0.86 (95% CI, 0.75 to 0.98) and for hip fractures of 0.61 (95% CI, 0.46 to 0.82).

## Limitations of the Review

This review has several limitations. The review was scoped to focus on community-dwelling populations not known to have vitamin D deficiency or existing metabolic bone disease (e.g., osteoporosis), a high risk for falls, or prior history of fracture, for applicability to unselected primary care populations. Although some patients at higher fracture risk may be included in this population, our review does not directly address the effect of supplementation on higher risk, selected populations, including those in institutional settings. This review was largely focused on supplementation for the primary prevention of fracture, yet studies included participants with and without a prior history of osteoporotic fracture. When studies did not report the proportion of subjects with a history of prior osteoporotic fracture, we contacted study authors to determine whether such data were available; in most cases data were not available. Thus, we included these studies in the review because baseline characteristics in these studies were similar to characteristics reported in the studies that were largely focused on primary prevention.

We limited our review to oral or injectable vitamin D and oral calcium preparations that are available as dietary supplements. We did not consider vitamin D analogues or formulations typically dispensed with a prescription for the treatment of disease. Our review was limited to fracture outcomes for KQ 1; thus, studies that only reported the impact on intermediate bone outcomes (such as bone turnover markers or bone mineral density) or falls would not have been included. However, the USPSTF has a separate evidence review related to interventions to prevent falls that included vitamin D as an eligible intervention. Our literature search for KQ 2 was focused on the harms we prespecified; however, other harms that were reported in eligible studies were captured.

## Future Research Needs

RCTs that enroll unselected primary care populations with study aims powered to assess fracture outcomes and protocols designed to minimize contamination would address the major limitations of the current body of evidence. Because fractures are relatively uncommon in unselected populations, RCTs with sample sizes of similar magnitude as the WHI CaD Trial would likely be needed to conclude with high certainty that no effect of supplementation on fracture exists. Similarly, for harms, RCTs with larger sample sizes and valid and reliable outcome ascertainment methods are needed to conclude with high certainty that no important harms exist. We are aware of seven ongoing trials of vitamin D supplementation; study details are provided in Appendix G. These trials may offer additional evidence related to the impact of vitamin D on mortality and incident cancer; however; none are powered for fractures as a primary study end point.

We identified no ongoing trials of calcium supplementation. Because of the controversy related to calcium supplementation and CVD outcomes, a single good-quality RCT powered for primary cardiovascular end points conducted in healthy community-dwelling adults would be influential. Future research involving calcium supplementation should consider designs that exclude existing users of supplements from enrollment or that prespecify analyses based on use of supplements at baseline.

Analyses that assess the burden of fractures among unselected populations and the relative importance of fracture prevention in these populations relative to other health needs may help to clarify the focus of future supplementation research in this population. Future research in this population could involve higher doses of vitamin D or vitamin D analogues.

## Conclusion

In unselected, community-dwelling populations without known osteoporosis or vitamin D deficiency, the evidence does not support a finding of fewer fractures with vitamin D supplementation alone or with calcium; the evidence for supplementation with calcium alone is limited. The evidence suggests that supplementation with vitamin D alone does not increase all-cause mortality or cardiovascular events, but the evidence is limited for other harms. The evidence suggests that supplementation with calcium alone does not increase the incidence of kidney stones, but the evidence is limited for other harms. The evidence suggests that vitamin D with calcium does not increase all-cause mortality, cardiovascular events, or cancer incidence, but it is associated with an increase in the incidence of kidney stones.