# 3 Results

## Literature Search

We identified 3,131 unique records and assessed 291 full-text articles for eligibility (Figure 2). We excluded 265 studies for various reasons detailed in Appendix C. Many studies could be excluded for multiple reasons; however, we report only one.

Figure 2 Literature Search Flow Diagram

^a^Five RCTs (in 7 publications) that were excluded for ineligible study population were used in sensitivity analyses (the study populations in these studies included between 20 and 50% of participants with prior or prevalent fracture).

^b^Eight RCTs (in 9 publications) and 22 cohort or case-control studies (in 26 publications) were excluded for poor quality. Seven of the poor quality RCTs were used in sensitivity analyses.

^c^Ten RCTs (in 13 publications) were used in sensitivity analyses for KQ1; 4 were excluded from the main analyses because of ineligible population, 5 were excluded because of poor quality, and 1 was excluded for both ineligible population and poor quality.

^d^Eleven RCTs (in 15 publications) were used in sensitivity analyses for KQ2; 4 were excluded from the main analyses because of ineligible population, 6 were excluded because of poor quality, and 1 was excluded for both ineligible population and poor quality.

Literature Search Flow Diagram Figure 2 is a preferred reporting of systematic review and meta-analysis (PRISMA) tree that summarizes the search and selection of articles. There were 16 studies identified from prior USPSTF reviews, 3,187 new references identified through database searching, and 64 additional citations identified through reference lists and other sources. After duplicates were removed, the title and abstracts of 3,131 references were screened for potential inclusion. Of these, 2,840 were excluded and 291 were deemed appropriate for full-text review to determine eligibility. After full-text review, 265 records were excluded: 29 were nonoriginal research, 41 for ineligible intervention or exposure, 55 for ineligible population, 1 for ineligible setting, 45 for ineligible outcome, 18 for ineligible study design, 3 for ineligible comparator, 2 for ineligible timing, 1 for ineligible country or region, 6 were study protocols with no outcomes, 29 were systematic reviews used to identify relevant studies, and 35 were excluded for poor overall study quality. Of the 55 records excluded for ineligible population, 5 trials (in 7 publications) with a study population that included 20% to 50% of participants with prior or prevalent fractures were used in sensitivity analyses. The 35 records excluded for poor quality included 8 trials (in 9 publications) and 22 cohort or case-control studies (in 26 publications). Of these, 7 poor-quality trials were used in sensitivity analyses. The 11 good- or fair-quality trials (from 26 publications) not excluded for the aforementioned reasons are included in this review. Among them, 8 trials (from 13 publications) are used in the main analysis for KQ1. An additional 10 trials (in 13 publications) were used in the sensitivity analysis for KQ1: 4 were excluded from the main analyses because of ineligible population, 5 because of poor quality, and 1 because of both ineligible population and poor quality. Nine good- or fair-quality trials (from 22 publications) are used in the main analysis for KQ2. An additional 11 trials (in 15 publications) were used in the sensitivity analysis for KQ2: 4 were excluded from the main analyses because of ineligible population, 6 because of poor quality, and 1 because of both ineligible population and poor quality.

Eight RCTs (in 13 publications) were relevant to the benefits of supplementation on fracture prevention (KQ 1), and nine RCTs (in 22 publications) were relevant to the harms of supplementation (KQ 2). Ten RCTs that were excluded were used in sensitivity analyses for KQ 1 and 11 RCTs that were excluded were used in sensitivity analyses for KQ 2. Individual study characteristics and detailed findings of studies included in the main and sensitivity analyses are in Appendix D. Study quality assessments for all RCTs are in Appendix E Tables 1–6, and quality assessments for the observational studies identified as eligible for KQ 2 but excluded for poor quality are in Appendix E Tables 7–14. Pooled estimates generated by random effects models using the restricted maximum likelihood estimator were not substantively different from results using the method of DerSimonian and Laird, and are therefore not shown.

## Results by KQ

### KQ1 Direct Evidence for Supplementation With Vitamin D or Calcium Alone or Vitamin D Combined With Calcium for the Prevention of Fractures or Reduction in Fracture-Related Morbidity and Mortality

#### Summary of Results

Eight good- or fair-quality RCTs that randomized 47,672 participants examined the effect of supplementation with vitamin D alone, calcium alone, or vitamin D with calcium on fracture prevention. One RCT (Women’s Health Initiative Calcium and Vitamin D [WHI CaD] trial^71^) enrolled 36,282 women; the other trials enrolled only women (3 RCTs,^72-74^ 571 total participants) or both women and men (4 RCTs,^75-79^ 10,819 total participants). Three studies stated that the effect on incident fracture was the study aim;^71,^ ^76,^ ^77^ however, only one study (WHI CaD trial) used fractures as the primary end point to determine required sample size.^71^ Aims in the other studies included evaluating changes in BMD or biochemical measures of bone metabolism. Table 1 and Figures 3-5 summarize study characteristics and findings from these RCTs. All but one^77^ reported statistically nonsignificant differences in fracture incidence between supplementation and placebo groups over 3–7 years, with ARDs ranging from -6.99 percent to 7.26 percent, and RRs ranging from 0.36 to 1.34. Most estimates were imprecise. We did not identify any eligible studies evaluating the impact of supplementation on fracture-related morbidity or mortality, and too few studies were available to assess the impact of dose or dosing interval on fracture incidence.

Table 1 Results Of RCTs Evaluating The Impact Of Vitamin D, Calcium, Or Combined Supplementation For The Primary Prevention Of Fractures

Author (Year) | No. of Participants | Population | Intervention, Comparator | Followup (Years) | Fracture Type | No. (%) With Event: Control Group | No. (%) With Event: Intervention Group | Summary Effect ARD (95%CI) RR or HR (95% CI) | Study Quality
Vitam in D Compared With Placebo or Control
Komulainen et al, 1998^72^ | 232^*^ | Community-dwelling women ages 52 to 61 years between 6 and 24 months postmenopause | 300 IU oral vitamin D_3_ with 93 mg calcium^†^ daily, 93 mg calcium^†^ daily | Mean 4.3 (range 0 to 5.9) | Hip | 2 (1.7) | 1 (0.9) | ARD, -0.86% (-3.77% to 2.04%)^‡^ RR, 0.50 (0.05 to 5.44)^‡^ | Fair
Komulainen et al, 1998^72^ | 232^*^ | Community-dwelling women ages 52 to 61 years between 6 and 24 months postmenopause | 300 IU oral vitamin D_3_ with 93 mg calcium^†^ daily, 93 mg calcium^†^ daily | Mean 4.3 (range 0 to 5.9) | Non-vertebral | 15 (12.9) | 11 (9.5) | ARD, -3.45% (-11.55% to 4.66%)^‡^ RR, adjusted for baseline femoral neck BMD and previous fractures, 0.64 (0.29 to 1.42) | Fair
Lips et al, 1996^76^ | 2,578 | Healthy adults 70 years or older (74% women) recruited from general practitioners or from apartment houses or homes for the elderly^§^ | 400 IU oral vitamin D_3_ daily, placebo daily | Median 3.5 | Hip | 48 (3.7) | 58 (4.5) | ARD, 0.76% (-0.77% to 2.30%)^‡^ Unadjusted HR, 1.18 (0.81 to 1.71) | Fair
Lips et al, 1996^76^ | 2,578 | Healthy adults 70 years or older (74% women) recruited from general practitioners or from apartment houses or homes for the elderly^§^ | 400 IU oral vitamin D_3_ daily, placebo daily | Median 3.5 | Peripheralǁ | 74 (5.8) | 77 (6.0) | ARD, 0.21% (-1.60% to 2.03%)^‡^ Unadjusted HR, 1.03 (0.75 to 1.40) | Fair
Trivedi et al, 2003^77^ | 2,686 | Community dwelling adults 65 to 85 years (24% women) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Total^¶^ | 149 (11.1) | 119 (8.8) | ARD, -2.26% (-4.53% to 0.00%)^‡^ Age-adjusted RR, 0.78 (0.61 to 0.99)^#^ | Fair
Trivedi et al, 2003^77^ | 2,686 | Community dwelling adults 65 to 85 years (24% women) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Hip | 24 (1.8) | 21 (1.6) | ARD, -0.23% (-1.20% to 0.74%)^‡^ Age-adjusted RR, 0.85 (0.47 to 1.53)^**^ | Fair
Trivedi et al, 2003^77^ | 2,686 | Community dwelling adults 65 to 85 years (24% women) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Vertebral (clinical) | 28 (2.1) | 18 (1.3) | ARD, -0.75% (-1.73% to 0.23%)^‡^ Age-adjusted RR, 0.63 (0.35 to 1.14) | Fair
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,108 | Community dwelling adults 50 to 84 years (42% women) recruited from general practices | 200,000 IU vitamin D_3_ initial dose followed by 100,000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | Non-vertebral | 136 (5.3) | 156 (6.1) | ARD, 0.77% (-0.51% to 2.04%)^‡^ Adjusted HR, 1.19 (0.94 to 1.50) | Good
Calcium Compared With Placebo
Recker et al, 1996^73^ | 103 | Community-dwelling women age 60 years or older who were ambulatory and living independently; only data for the subgroup of subjects without prevalent vertebral fracture at baseline were included in this review | 1,200 mg oral calcium^††^ daily, placebo daily | Mean 4.3 (SD 1.1) | Vertebral (morpho-metric) | 13 (21.3) | 12 (28.6) | ARD, 7.26% (-9.84% to 24.36%)^‡^ RR, 1.34 (0.68 to 2.64)^‡^ | Fair
Riggs et al, 1998^74^ | 236 | Community-dwelling women ages 61 to 70 years who were postmenopausal for at least 10 years | 1,600 mg oral calcium^‡‡^ daily, placebo daily | Panned 4 | Vertebral (morpho-metric) | 9 (7.7) | 8 (6.7) | ARD, -0.97% (-7.57% to 5.63%)^‡^ RR, 0.87 (0.35 to 2.19)^‡^ | Fair
Riggs et al, 1998^74^ | 236 | Community-dwelling women ages 61 to 70 years who were postmenopausal for at least 10 years | 1,600 mg oral calcium^‡‡^ daily, placebo daily | Panned 4 | Non-vertebral | 12 (10.3) | 11 (9.2) | ARD, -1.01% (-8.58% to 6.56%)^‡^ RR, 0.90 (0.41 to 1.96)^‡^ | Fair
Vitamin D With Calcium Compared With Placebo
Dawson-Hughes et al, 1997^75^ | 389ǁǁ | Community-dwelling adults age 65 years or older (55% women) | 700 IU vitamin D_3_ with 500 mg calcium^§§^ daily, placebo daily | Panned 3 | Hip | 1 (0.5) | 0 (0) | ARD, -0.50% (-1.88% to 0.89%)^‡^ RR, 0.36 (0.01 to 8.78)^‡^ | Fair
Dawson-Hughes et al, 1997^75^ | 389ǁǁ | Community-dwelling adults age 65 years or older (55% women) | 700 IU vitamin D_3_ with 500 mg calcium^§§^ daily, placebo daily | Panned 3 | Non-vertebral^¶¶^ | 26 (12.9) | 11 (5.9) | ARD, -6.99% (-12.71% to -1.27%)^‡^ RR, 0.46 (0.23 to 0.90) | Fair
WHI Calcium and Vitamin D Trial, 2006^71^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 years participating in either the WHI Dietary Modification or Hormone Therapy trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^‡‡^ daily, placebo daily | Mean 7.0 (SD 1.4) | Total^##^ | 2,158 (11.9) | 2,102 (11.6) | ARD, -0.35% (-1.02% to 0.31%)^‡^ HR, 0.96 (0.91 to 1.02) | Fair
WHI Calcium and Vitamin D Trial, 2006^71^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 years participating in either the WHI Dietary Modification or Hormone Therapy trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^‡‡^ daily, placebo daily | Mean 7.0 (SD 1.4) | Hip | 199 (1.1) | 175 (1.0) | ARD, -0.14% (-0.34% to 0.07%)^‡^ HR, 0.88 (0.72 to 1.08) | Fair
WHI Calcium and Vitamin D Trial, 2006^71^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 years participating in either the WHI Dietary Modification or Hormone Therapy trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^‡‡^ daily, placebo daily | Mean 7.0 (SD 1.4) | Vertebral (clinical) | 197 (1.1) | 181 (1.0) | ARD, -0.09% (-0.30% to 0.12%)^‡^ HR, 0.90 (0.74 to 1.10) | Fair

Note: fractures were not the primary study aim for most included studies; studies identified with italics are the only studies that indicated fracture incidence as a primary study aim.

* This study randomized a total of 464 women; only the 232 women randomized to vitamin D or placebo were included in this review.

† Participants in both study groups received 93 mg of elemental calcium as lactate.

‡ Calculated based on raw data provided in published article.

§ Participants recruited from practitioners lived independently, participants recruited from apartments/homes for the elderly received some care (but less than they would receive in a nursing home per study report).

ǁ Includes fractures of the humerus, distal radius, ankle, foot, leg, and fractures other than hip or spine. These fractures were based on self-report.

¶ Includes fractures at any site.

# The unadjusted, calculated RR was 0.80 (95% CI, 0.63 to 1.00). The RR was lower among women than in men and neither were statistically significant (adjusted RR, 0.68, [95% CI, 0.46 to 1.01, in women]; adjusted RR, 0.83, [95% CI, 0.61 to 1.13, in men]).

** The adjusted RR for women was 0.98 (95% CI, 0.41 to 2.36) and for men was 0.76 (95% CI, 0.35 to 1.67).

†† Elemental calcium as carbonate.

‡‡ Elemental calcium as citrate.

§§ Elemental calcium as citrate malate.

ǁǁ Although 445 participants were randomized, analyses were based on 389 participants with followup data.

¶¶ When outcomes were limited to nonvertebral fractures classified as osteoporotic, the RR, was 0.40 (95% CI, 0.2 to 0.8).

## Total fractures were defined as all fractures at any site other than ribs, sternum, skull, face, fingers, toes, and cervical vertebrae.

Abbreviations: ARD=absolute risk difference; BMD=bone mineral density; CI=confidence interval; HR=hazard ratio; No.=number; RCT= randomized, controlled trials; RR=relative risk; WHI=Womenʼs Health Initiative.

Figure 3 Impact of Vitamin D Supplementation on the Prevention of Fractures

Note: fractures were not the primary study aim for most included studies; only Lips et al and Trivedi et al indicated fractur e incidence as a primary study aim.

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; Cntl=control or placebo; d=days; IU=international units; m=months; n or N=number of participants; RR=relative risk ratio; UK=United Kingdom; US=United States

Note: fractures were not the primary study aim for any included studies.

* Represents N analyzed, which may differ from the N randomized in some studies.

† This study had three study groups: placebo, 600 mg, and 1,200 mg; this figure reflects the comparison between each active comparator and placebo separately.

‡ The total N with available data for this outcome was different from the other outcomes analyzed in this study.

^1^ This study is excluded from the metaanalysis because of 0 events in both groups.

Abbreviations: CI=confidence interval; Cntl=placebo; d=day; mg=milligram; MOF=major osteoporotic fracture (defined as all fractures except t hose of head, hands, feet and ankles and those resulting from major trauma); n or N=number of participants; RR=relative risk ratio; US=United States; y=year.

Impact of Vitamin D Supplementation on the Prevention of Fractures Figure 3 displays a forest plot of the relative risks of developing various types of incident fractures after receiving vitamin D-only supplementation vs. placebo or control. The relative risk for developing hip fracture following treatment compared with placebo was 1.20 with a 95 percent confidence interval of 0.83 to 1.75 in Lips et al, 1996. The relative risk for developing hip fracture following treatment compared with placebo was 0.87 with a 95 percent confidence interval of 0.49 to 1.56 in Trivedi et al, 2003. The relative risk for developing hip fracture following treatment compared with placebo was 0.50 with a 95 percent confidence interval of 0.05 to 5.44 in Komulainen et al, 1998. The relative risk for developing hip fracture following treatment compared with placebo was 1.26 with a 95 percent confidence interval of 0.64 to 2.47 in Sanders et al, 2010. The relative risk for developing hip fracture following treatment compared with placebo was 1.50 with a 95 percent confidence interval of 1.02 to 2.19 in Smith et al, 2007. The relative risk for developing peripheral fracture following treatment compared with placebo was 1.04 with a 95 percent confidence interval of 0.76 to 1.41 in Lips et al, 1996. The relative risk for developing total fracture following treatment compared with placebo was 0.80 with a 95 percent confidence interval of 0.63 to 1.00 in Trivedi et al, 2003. The relative risk for developing total fracture following treatment compared with placebo was 1.23 with a 95 percent confidence interval of 0.99 to 1.54 in Sanders et al, 2010. The relative risk for developing total fracture following treatment compared with placebo was 0.94 with a 95 percent confidence interval of 0.40 to 2.24 in Glendenning et al, 2003. The relative risk for developing clinical vertebral fracture following treatment compared with placebo was 0.64 with a 95 percent confidence interval of 0.36 to 1.15 in Trivedi et al, 2003. The relative risk for developing clinical vertebral fracture following treatment compared with placebo was 1.24 with a 95 percent confidence interval of 0.76 to 2.03 in Sanders et al, 2010. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 0.73 with a 95 percent confidence interval of 0.35 to 1.53 in Komulainen et al, 1998. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.22 with a 95 percent confidence interval of 0.95 to 1.57 in Sanders et al, 2010. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.09 with a 95 percent confidence interval of 0.93 to 1.28 in Smith et al, 2007. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.43 with a 95 percent confidence interval of 0.66 to 3.11 in Peacock et al, 2000. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.14 with a 95 percent confidence interval of 0.91 to 1.43 in Khaw et al, 2017. The relative risk for developing upper extremity fracture following treatment compared with placebo was 1.23 with a 95 percent confidence interval of 0.85 to 1.77 in Smith et al, 2007. The relative risk for developing clinical and morphometric vertebral fracture following treatment compared with placebo was 1.49 with a 95 percent confidence interval of 0.77 to 2.90 in Peacock et al, 2000.

Figure 4 Impact of calcium supplementation on the prevention of fractures

Note: fractures were not the primary study aim for any included studies.

* Represents N analyzed, which may differ from the N randomized in some studies.

† This study had three study groups: placebo, 600 mg, and 1,200 mg; this figure reflects the comparison between each active comparator and placebo separately.

‡ The total N with available data for this outcome was different from the other outcomes analyzed in this study.

| This study is excluded from the metaanalysis because of 0 events in both groups.

Abbreviations: CI=confidence interval; Cntl=placebo; d=day; mg=milligram; MOF=major osteoporotic fracture (defined as all fractures except those of head, hands, feet and ankles and those resulting from major trauma); n or N=number of participants; RR=relative risk ratio; US=United States; y=year

Impact of calcium supplementation on the prevention of fractures Figure 4 displays a forest plot of the relative risks of developing various types of incident fractures after receiving calcium-only supplementation vs. placebo or control. The relative risk for developing total fracture following treatment (daily dosage of 600 mg) compared with placebo was 0.62 with a 95 percent confidence interval of 0.21 to 1.83 in Reid et al, 2008. The relative risk for developing total fracture following treatment (daily dosage of 1,000 mg) compared to placebo was 0.40 with a 95 percent confidence interval of 0.08 to 1.98 in Reid et al, 1995. The relative risk for developing total fracture following treatment (daily dosage of 1,000 mg) compared to placebo was 0.91 with a 95 percent confidence interval of 0.73 to 1.14 in Reid et al, 2006. The relative risk for developing total fracture following treatment (daily dosage of 1,200 mg) compared to placebo was 0.87 with a 95 percent confidence interval of 0.69 to 1.10 in Prince et al, 2006. The relative risk for developing total fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 0.50 with a 95 percent confidence interval of 0.69 to 1.10 in Reid et al, 2008. The relative risk for developing hip fracture following treatment (daily dosage of 1,000 mg) compared with placebo was 3.43 with a 95 percent confidence interval of 1.27 to 9.26 in Reid et al, 2006. The relative risk for developing hip fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 1.83 with a 95 percent confidence interval of 0.68 to 4.93 in Prince et al, 2006. The relative risk for developing major osteoporotic fracture following treatment (daily dosage of 1,000 mg) compared with placebo was 0.87 with a 95 percent confidence interval of 0.69 to 1.11 in Reid et al, 2006. The relative risk for developing nonvertebral fracture following treatment (daily dosage of 1,600 mg) compared with placebo was 0.90 with a 95 percent confidence interval of 0.41 to 1.96 in Riggs et al, 1998. The relative risk for developing nonvertebral fracture following treatment (daily dosage of 750 mg) compared to placebo was 1.18 with a 95 percent confidence interval of 0.52 to 2.68 in Peacock et al, 2000. The relative risk for developing nonvertebral fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 0.88 with a 95 percent confidence interval of 0.67 to 1.16 in Prince et al, 2006. The relative risk of developing clinical vertebral fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 0.97 with a 95 percent confidence interval of 0.63 to 1.51 in Prince et al, 2006. The relative risk of developing clinical and morphometric vertebral fracture following treatment (daily dosage of 750 mg) compared with placebo was 0.58 with a 95 percent confidence interval of 0.24 to 1.40 in Peacock et al, 2000. The relative risk of developing clinical and morphometric vertebral fracture following treatment (daily dosage of 1,000 mg) compared with placebo was 0.72 with a 95 percent confidence interval of 0.44 to 1.16 in Reid et al, 2006. The relative risk of developing morphometric vertebral fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 1.34 with a 95 percent confidence interval of 0.68 to 2.64 in Recker et al, 1996. The relative risk of developing morphometric vertebral fracture following treatment (daily dosage of 1,600 mg) compared with placebo was 0.87 with a 95 percent confidence interval of 0.35 to 2.19 in Riggs et al, 1998. The relative risk of developing morphometric vertebral fracture following treatment (daily dosage of 1,200 mg) compared with placebo was 0.92 with a 95 percent confidence interval of 0.63 to 1.35 in Prince et al, 2006. Ruml et al, 1999 was excluded from the analysis but shown on the figure as having reported 0 events of morphometric vertebral fracture in both treatment and placebo arms.

Figure 5 Impact of Vitamin D With Calcium Supplementation on the Prevention of Fractures

Note: fractures were not the primary study aim for most included studies; only the WHC indicated fracture incidence as a primary study aim.

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: Calc=calcium; CI=confidence interval; Cntl=placebo; d=day; IU=international units; mg=milligram; MOF=major osteoporotic fract ure (defined as clinical vertebral, hip, forearm, and proximal humerus); n or N=number of participants; RR=relative risk ratio; US=United States; Vit D=vitamin D; WHI=Women’s Heal th Initiative; y=year.

Impact of vitamin D with calcium supplementation on the prevention of fractures Figure 5 displays a forest plot of the relative risks of developing various types of incident fractures after receiving calcium-only supplementation vs. placebo or control. The relative risk for developing total fracture following treatment compared with placebo was 0.97 with a 95 percent confidence interval of 0.92 to 1.03 in the WHI trial. The relative risk for developing total fracture following treatment compared with placebo was 0.84 with a 95 percent confidence interval of 0.63 to 1.13 in Salovaara et al, 2010. The relative risk for developing hip fracture following treatment compared with placebo was 0.88 with a 95 percent confidence interval of 0.72 to 1.07 in the WHI trial. The relative risk for developing hip fracture following treatment compared with placebo was 0.36 with a 95 percent confidence interval of 0.01 to 8.78 in Dawson-Hughes et al, 1997. The relative risk for developing hip fracture following treatment compared with placebo was 2.03 with a 95 percent confidence interval of 0.37 to 11.06 in Salovaara et al, 2010. The relative risk for developing major osteoporotic fracture following treatment compared with placebo was 0.82 with a 95 percent confidence interval of 0.55 to 1.22 in Salovaara et al, 2010. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 0.46 with a 95 percent confidence interval of 0.23 to 0.90 in Dawson-Hughes et al, 1997. The relative risk for developing nonvertebral fracture following treatment compared to placebo was 0.88 with a 95 percent confidence interval of 0.64 to 1.20 in Salovaara et al, 2010. The relative risk of developing clinical vertebral fracture following treatment compared with placebo was 0.92 with a 95 percent confidence interval of 0.75 to 1.12 in the WHI trial. The relative risk of developing clinical vertebral fracture following treatment compared with placebo was 0.70 with a 95 percent confidence interval of 0.30 to 1.64 in Salovaara et al, 2010. The relative risk of developing lower arm/wrist fracture following treatment compared with placebo was 1.01 with a 95 percent confidence interval of 0.90 to 1.13 in the WHI trial.

#### Vitamin D Compared With Placebo: Study Characteristics

We identified one new good-quality RCT (Khaw, Scragg et al,^78,^ ^79^) in addition to the three fairquality RCTs that were included in the prior review (Trivedi et al,^77^ Lips et al,^76^ and Komulainen et al^72^). In the prior review, Komulainen et al^72^ was considered a vitamin D with calcium intervention, as both the active treatment and placebo group received a modest dose of supplemental calcium. The authors of the prior review published an erratum after the USPSTF’s 2013 recommendation that corrected the study’s classification to the appropriate intervention and comparator (vitamin D compared with placebo) and revised the meta-analysis.^2,^ ^80^ We used the revised classification of this study in this update review.

Three RCTs included both men and women; Khaw, Scragg et al^78,^ ^79^ randomized 5,110 participants age 50 to 84 years (42% women) in New Zealand, Trivedi et al^77^ randomized 2,686 participants age 65 to 85 years (24% women) in the United Kingdom, and Lips et al^76^ randomized 2,578 participants age 70 years or older (74% women) in The Netherlands. Komulainen et al^72^ randomized 232 postmenopausal women age 52 to 61 years in Finland.^72,^ ^76^ Studies evaluated oral vitamin D_3_ compared with placebo over 3.3 to 5 years; two evaluated daily 300 or 400 IU doses,^72,^ ^76^ one evaluated 100,000 IU every 4 months,^77^ and one evaluated an initial loading dose of 200,000 IU followed by monthly doses of 100,000 IU.^78,^ ^79^ The comparator group was a placebo control in all but one study.^72^ The baseline serum vitamin D level among participants in the Khaw, Scragg et al study was 63 nmol/L. The median serum vitamin D level at baseline for both study groups in Lips et al was in the severe deficiency range (vitamin D group median 26 nmol/L, placebo group median 27 nmol/L), but this study did not use serum vitamin D as a study entry criterion. Baseline serum vitamin D was not reported by Trivedi et al or by Komulainen et al.

Incident fracture outcomes ascertained across studies included total fractures (traumatic or osteoporotic) at any site, hip fractures, clinical or morphometric vertebral fractures, nonvertebral fractures, and peripheral fractures (distal radius, humerus, ankle, foot, leg). Three studies confirmed fractures through practitioner verification, medical or hospital record review, radiographic review, or claims.^72,^ ^78,^ ^79,^ ^81^ Trivedi et al relied on death certificate causes and ascertainment through subject questionnaires, which the study authors considered valid and reliable given the proportion of study participants who were physicians.^77^

Two RCTs included in the prior review (Lyons et al ^82^ and Law et al^83^) were not eligible for this update because they were conducted among institutionalized participants. We identified four RCTs for use in sensitivity analysis.^84-87^ One good-quality RCT by Sanders et al was included in the prior review that informed the 2013 USPSTF Recommendation, but we excluded it from our main analysis because 35 percent of the study population had a history of fracture and the trial enrolled subjects with a higher risk for fracture.^84^ This trial was conducted among 2,258 community-dwelling Australian women age 70 years or older and compared an annual oral dose of 500,000 IU of vitamin D_3_ (approximate daily equivalent of 1,370 IU) with placebo. We also used an RCT conducted by Peacock et al in a sensitivity analysis; it was excluded from the initial 2007 review and was not used in any subsequent updates.^86^ This study compared 600 IU of vitamin D_3_ with placebo over 4 years among 438 community-dwelling U.S. residents (72% women). This study was not eligible for our main analysis because although all subjects were described as independently mobile, only 60 percent were characterized as free living and because we assessed it as poor quality based on a high risk of bias due to missing data and poor outcome measurement specification. Glendenning et al randomized women in Australia age 70 years and older to oral 150,000 IU vitamin D_3_ at baseline, 3 months, and 6 months (approximate daily equivalent 1,667 IU) or placebo. Fracture outcomes were self-reported in an adverse event diary.^87^ This study was rated poor quality because of measurement bias and the short period of followup (9 months). Last, we used an RCT conducted by Smith et al that was not included in the original 2007 AHRQ Evidence Report because findings were available only in abstract format at the time. This fair-quality RCT compared an annual 300,000 IU dose of vitamin D_2_ (approximate daily equivalent 822 IU) with placebo for 1–3 years among 9,400 men and women over age 75 years in the United Kingdom. This study was not eligible for our main analysis because more than 20 percent of subjects had a history of nonvertebral fracture.

#### Vitamin D Compared With Placebo: Findings

The impact of vitamin D alone compared with placebo on incident fracture is summarized in Table 1; findings for studies also considered in sensitivity analyses are depicted in Figure 3.

##### Total Fractures

One RCT, Trivedi et al, reported a total fracture incidence of 8.8 percent in the vitamin D group and 11.1 percent in the placebo group over 5 years (unadjusted ARD, -2.26% [95% CI, -4.53% to 0.00%], age-adjusted RR, 0.78 [95% CI, 0.61 to 0.99]).^77^ The unadjusted, calculated RR was 0.80 (95% CI, 0.63 to 1.00). In sensitivity analysis, Sanders et al reported a total fracture incidence of 13.7 percent in the vitamin D group and 11.1 percent in the placebo group over 3 years (ARD, 2.59% [95% CI, -0.12% to 5.31%]; HR, 1.26 [95% CI, 0.99 to 1.59]), a finding that was inconsistent with Trivedi et al^84^ with respect to direction of effect; though both studies were imprecise and included the null effect. The other study used in sensitivity analysis, Glendenning et al,^87^ reported an ARD of -0.17% (95% CI, -2.69% to 2.35%) and RR, 0.94 (95% CI, 0.40 to 2.24). Both Sanders et al and Glendenning et al used considerably higher doses than Trivedi et al.

##### Hip Fractures

The three RCTs that reported on incident hip fracture all reported numeric differences that were statistically not significant.^72,^ ^76,^ ^77^ The incidence of hip fracture in the treatment groups was 4.5 percent, 1.6 percent, and 0.9 percent and in the respective placebo or control groups was 3.7 percent, 1.8 percent, and 1.7 percent. Compared with placebo or control, the pooled estimates of effect for incident hip fracture among the vitamin D groups over 3 to 5 years showed no difference (pooled ARD, -0.01% [95% CI, -0.80% to 0.78%; I^2^=0%,]; pooled RR, 1.08, [95% CI, 0.79 to 1.48; I^2^=0.0%]; 3 RCTs, N=5,496 participants, Appendix F Figures 1 and 2). A somewhat increased incidence was observed with the addition of two studies used in a sensitivity analysis (pooled RR, 1.24 [95% CI, 0.98 to 1.55]; I^2^=0.0%, 5 RCTs, N=17,192 participants).^84,^ ^85^

##### Nonvertebral Fractures

Khaw, Scragg et al^78,^ ^79^ reported a numeric but statistically nonsignificant increase in nonvertebral fracture incidence; the incidence was 6.1 percent in the vitamin D group and 5.3 percent in the placebo group over a median of 3.3 years (ARD 0.77%, [95% CI, -0.51% to 2.04%], adjusted HR, 1.19 [95% CI, 0.94 to 1.50]). Komulainen et al^72^ reported a numeric but statistically nonsignificant decrease in nonvertebral fracture incidence; the incidence was 9.5 percent in the vitamin D group and 12.9 percent in the control group over 4.3 years (ARD, 3.45% [95% CI, -11.55% to 4.66%]; adjusted RR, 0.64 [95% CI, 0.29 to 1.42]). We used three additional studies^84-86^ in a sensitivity analysis to generate a pooled estimate. The pooled ARD was 0.75 percent (95% CI, 0.02% to 1.48%; I^2^=0%, 5 RCTs, 17,303 participants, Appendix F Figure 3) and the pooled RR was 1.13 (95% CI, 1.01 to 1.26; I^2^=0%, Appendix F Figure 4).

##### Clinical Vertebral Fractures

One study, Trivedi et al,^77^ reported a numeric but statistically nonsignificant decrease in incidence of clinical vertebral fractures; 1.3 percent in the vitamin D group and 2.1 percent in the placebo group over 5 years (ARD, -0.77% [95% CI, -1.73% to 0.23%]; age-adjusted RR, 0.63 [95% CI, 0.35 to 1.14]). In sensitivity analysis, Sanders et al reported a numeric but statistically nonsignificant increase in clinical vertebral fractures (ARD, 0.61% [95% CI, -0.75% to 1.96%]; RR, 1.24 [95% CI, 0.76 to 2.03]); this study was not eligible because 35 percent of its study population had a prior history of fracture.^84^

##### Peripheral Fractures

One study, Lips et al,^76^ reported a numeric but statistically nonsignificant increase in incidence of peripheral fractures; 6.0 percent in the vitamin D group and 5.8 percent in the placebo group over 3.5 years (ARD, 0.21% [95% CI, -1.60% to 2.03%]; unadjusted HR, 1.03 [95% CI, 0.75 to 1.40]).

#### Calcium Compared With Placebo: Study Characteristics

Two fair-quality RCTs examined the effect of calcium alone on fracture prevention among women age 60 years or older.^73,^ ^74^ Both studies were conducted in the United States and were considered new to this update because the impact of calcium alone on fracture prevention was not included in the prior review. Recker et al randomized participants to 1,200 mg calcium carbonate or placebo over 4.3 years; for this review, we included data only from the subset of 103 participants without prevalent spine fractures at enrollment.^73^ In this RCT, the baseline serum vitamin D level among randomized participants was 65.0 nmol/L in the placebo group and 62.5 nmol/L in the calcium group. Riggs et al randomized 236 participants to 1,600 mg calcium citrate or placebo over 4 years.^74^ In this RCT, the baseline serum vitamin D level of participants was 74.1 nmol/L in the placebo group, and 75.9 nmol/L in the calcium group. Both studies reported the impact of calcium compared with placebo on morphometric vertebral fractures defined by radiologic criteria; Riggs et al also reported the impact on nonvertebral fractures.

Two fair-quality RCTs conducted among women in New Zealand and Australia were used in a sensitivity analysis.^88-91^ These two studies were not eligible for the main analysis because the proportion of participants with a prior fracture was between 20 and 49 percent. Reid et al randomized 1,417 participants to 1,000 mg of calcium citrate or placebo over 5 years.^88,^ ^89^ Approximately 29 percent of participants had a fracture resulting from minimal trauma after age 40. Prince et al randomized 1,460 participants to 1,200 mg calcium carbonate.^90,^ ^91^ In this study, the proportion of study participants with a history of fracture because of minimal trauma after age 50 years ranged from 25 to 32 percent.

Four poor-quality studies were also used in sensitivity analysis.^86,^ ^92-94^ These studies compared doses of elemental calcium ranging from 600 mg to 1,200 mg over 2 to 4 years versus placebo. One study conducted in New Zealand included only men^92^; the other three were conducted in New Zealand^93^ and the United States^86,^ ^94^ among postmenopausal women. We assessed these studies as poor quality because of high risk of bias due to overall or differential attrition^86,^ ^93,^ ^94^ or outcome measure specification and ascertainment.^86,^ ^92,^ ^95^

#### Calcium Compared With Placebo: Findings

The impact of calcium alone compared with placebo on incident fracture is summarized in Table 1; findings that also include studies considered in sensitivity analysis are depicted by outcome in Figure 4.

##### Total Fractures

No studies included in our main analysis reported on incident total fracture. We considered four studies in a sensitivity analysis.^88,^ ^90,^ ^92,^ ^93^ Using these studies, the pooled ARD was -2.39% (95% CI, -4.72% to -0.06%; I^2^=0%; 4 RCTs; 3,483 participants; Appendix F Figure 5) and the pooled RR was 0.87 (95% CI, 0.74 to 1.02; I^2^=0%; Appendix F Figure 6).

##### Hip Fractures

No studies included in our main analysis reported on incident hip fracture. We considered two fair-quality studies in a sensitivity analysis that did not meet our population criteria for eligibility. One study, Reid et al,^88^ reported a statistically significant increase in hip fracture incidence (ARD, 1.65% [95% CI, 0.40% to 2.89%]; RR, 3.43 [95% CI, 1.27 to 9.26]). The other study, Prince et al,^90^ reported a numeric but statistically nonsignificant increase in incidence (ARD, 0.68% [95% CI, -0.42% to 1.78%]; RR, 1.83 [95% CI, 0.68 to 4.93]).

##### Nonvertebral Fractures

One study, Riggs et al,^74^ reported a numeric but statistically nonsignificant decrease in incident nonvertebral fractures; 9.2 percent incidence in the calcium group and 10.3 percent in the placebo group over 4 years (ARD, -1.01% [95% CI, -8.58% to 6.56%]; RR, 0.90 [95% CI, 0.41 to 1.96]. In a sensitivity analysis, we pooled this study with two additional RCTs (Prince et al^90^ and Peacock et al^86^) and found a numeric but statistically nonsignificant decrease (pooled ARD, -0.94% [95% CI, -3.72% to 1.84%]; I^2^=0%; 3 RCTs, 1,883 participants, Appendix F Figure 7; pooled RR, 0.91 [95% CI, 0.71 to 1.16]; I^2^=0%; Appendix F Figure 8).

##### Vertebral Fractures

No included studies in our main analysis reported on clinical vertebral fractures. We considered one study that did not meet population eligibility criteria in sensitivity analysis for this outcome.^90^ In this study, Prince et al reported a numeric but statistically nonsignificant decrease in incidence (ARD, -0.14% [95% CI, -2.43% to 2.16%]; HR, 0.98 [95% CI, 0.63 to 1.54]).

Two included studies reported on incident morphometric vertebral fractures over 4 years; point estimates were inconsistent with respect to increasing or decreasing incidence.^73,^ ^74^ Recker et al reported an incidence of 28.6 percent in the calcium group and 21.3 percent in the placebo group (ARD, 7.26% [95% CI, -9.84% to 24.36%]; RR, 1.34 [95% CI, 0.68 to 2.64]).^73^ Riggs et al reported an incidence of 6.7 percent in the calcium group and 7.7 percent in the placebo group (ARD, -0.97% [95% CI, -7.57% to 5.63%]; RR, 0.87 [95% CI, 0.35 to 2.19]).^74^ In a sensitivity analysis, we pooled these studies with two additional RCTs (Prince et al^90^ [did not meet population criteria] and Ruml et al^94^ [poor quality]). The pooled ARD and RR estimates with these studies were consistent for no effect (Appendix F Figures 9 and 10).

Last, we considered two additional studies in sensitivity analysis that reported a combined vertebral fracture outcome that included both clinical and morphometric fractures (these fractures were not reported separately in these studies). Findings from these studies demonstrated somewhat larger effect sizes compared with the studies previously discussed; however, they were not statistically significant. The poor-quality study by Peacock et al had a RR of 0.58 (95% CI, 0.24 to 1.40), and the fair-quality Reid et al^88^ study reported an HR of 0.72 (95% CI, 0.44 to 1.18).^86,^ ^88^

#### Vitamin D With Calcium Compared With Placebo: Study Characteristics

Two fair-quality RCTs examined the effect of vitamin D with calcium on fracture prevention.^71,^ ^75^ Both were included in the prior review. No new studies were identified for inclusion, although we identified several subgroup analyses related to one of the included RCTs. The first RCT, Dawson-Hughes et al, reported findings from 445 healthy participants age 65 or older (55% women) randomized to daily 700 IU oral vitamin D_3_ with 500 mg calcium citrate or placebo for 3 years.^75^ The WHI CaD trial randomized 36,282 U.S. women ages 50 to 79 years to daily 400 IU oral vitamin D^3^ with 1,000 mg calcium carbonate or placebo for 7 years.^71,^ ^96^ Participants enrolled in this trial were recruited from the participants in the WHI dietary modification trial and hormone therapy trials. Approximately 43.5 percent were using calcium and vitamin D supplements at baseline; personal use of supplements was allowed during the trial and approximately 84 percent of participants who reported use of supplements at baseline also reported use on their last questionnaire.^97^

Neither trial selected participants for enrollment based on serum vitamin D levels; however, both measured serum vitamin D at baseline. In the WHI CaD Trial, the mean serum vitamin D level was 49 nmol/L.^71,^ ^96^ The mean serum level among men in the Dawson-Hughes et al study was 83 nmol/L in both the treatment and placebo groups and for women was 61 nmol/L in the placebo group and 72 nmol/L in the treatment group.^75^ The WHI CaD Trial reported the impact of vitamin D with calcium on incident hip and clinical vertebral fractures (excluding cervical fractures) and on total fractures other than ribs, sternum, skull, face, fingers, toes, and cervical vertebra.^71^ Dawson-Hughes et al reported the impact of vitamin D with calcium on incident nonvertebral fractures, which included face, clavicle, shoulder, humerus, forearm, hand, ribs, pelvis, hip, leg, and foot. Both studies verified fractures with medical records or operative or radiology reports.

The main WHI publication and three publications (new to this review) reported subgroup analyses from the WHI trial. The main WHI publication reported on subgroup analyses related to age, race/ethnicity, weight, smoking status, sunlight exposure, hormone therapy use, and use of calcium supplements at baseline.^71^ Prentice et al published subgroup analyses related to the use of personal supplements at baseline,^98^ Robbins et al reported subgroup analyses related to hormone therapy use,^99^ and Bolland et al reported subgroup analyses related to personal use of calcium or vitamin D supplements.^97^

Seven RCTs included in the prior review were not included in this update. Porthouse et al,^100^ Grant et al,^101^ and Harwood et al^102^ were excluded from this update because either all or a majority of the enrolled study population had a prior history of fracture. Pfeifer et al was excluded from this update because participants were selected based on a baseline serum vitamin D level less than 50 nmol/L, which is in the deficiency range.^103^ Two studies by Chapuy et al^104,^ ^105^ and Flicker et al^106^ were excluded because they were conducted among institutionalized populations. We used one poor-quality RCT by Salovaara et al that was included in the prior review in sensitivity analysis.^107^ In addition to poor quality, this study was not eligible for our main analysis because approximately one third of enrolled participants had a prior history of fracture. This study, which was conducted in Finland, randomized 3,432 women ages 65 to 71 years to daily 800 IU oral vitamin D_3_ with 1,000 mg elemental calcium or control (no placebo) over 3 years.

#### Vitamin D With Calcium Compared With Placebo: Findings

The impact of vitamin D combined with calcium on incident fracture is summarized in Table 1; findings that also include studies considered in a sensitivity analysis are depicted by outcome in Figure 5.

##### Total Fracture

The WHI CaD Trial reported a numeric but statistically nonsignificant decrease in total fracture incidence.^71^ The incidence was 11.6 percent in the vitamin D with calcium group and 11.9 percent in the placebo group (ARD, -0.35% [95% CI, -1.02% to 0.31%]; HR, 0.96 [95% CI, 0.91 to 1.02]). Similar findings were reported by the one RCT (Salovaara et al^107^) used in sensitivity analysis; the total fracture incidence was 4.9 percent in the vitamin D with calcium group and 5.8 percent in the control group over 3 years (ARD, -0.92% [95% CI, -2.49% to 0.64%]; adjusted HR, 0.83 [95% CI, 0.61 to 1.12]).

##### Hip Fracture

Two included studies reported numeric but statistically nonsignificant decreases in hip fracture incidence.^71,^ ^75^ Dawson-Hughes et al reported only one hip fracture (in the placebo group) over the duration of study followup.^75^ In the WHI CaD Trial, the incidence of hip fracture was 1.0 percent in the vitamin D and calcium group and 1.1 percent in the placebo group at 7 years (ARD, -0.14% [95% CI, -0.34% to 0.07%]; HR, 0.88 [95% CI, 0.72 to 1.08]).^71^ One RCT (Salovaara et al^107^) considered in sensitivity analysis reported a numeric but statistically nonsignificant increase over 3 years (ARD, 0.13% [95% CI, -0.17% to 0.43%]; RR, 2.03 [95% CI, 0.37 to 11.06]). The pooled estimates including this study was similar to the estimates from the WHI CaD Trial.

##### Nonvertebral Fracture

One study, Dawson-Hughes et al, reported a statistically significant decrease in the incidence of nonvertebral fractures.^75^ The incidence was 5.9 percent in the the vitamin D with calcium group and 12.9 percent in the placebo group (ARD, -7.0% [95% CI, -12.7% to -1.3%]; RR, 0.50 [95% CI, 0.2 to 0.9]). When limited to only fractures considered to be osteoporotic (i.e., not resulting from major trauma), the RR was 0.40 (95% CI, 0.2 to 0.8). In sensitivity analysis, one RCT (Salovaara et al^107^) reported a numeric but statistically nonsignificant decrease in nonvertebral fractures over 3 years (ARD, -0.6% [95% CI, -2.1% to 0.9%]; adjusted HR, 0.87 [95% CI, 0.63 to 1.19]).

##### Vertebral Fracture

One study, the WHI CaD Trial, reported a numeric but statistically nonsignificant decrease in incident clinical vertebral fractures (exclusive of cervical vertebral fractures).^71^ The incidence was 1.0 and 1.1 in the treatment and placebo groups, respectively (ARD, -0.09% [95% CI,0.30% to 0.12%]; HR, 0.90 [95% CI, 0.74 to 1.10]). In sensitivity analysis, one RCT (Salovaara et al^107^) reported similar findings (ARD, -0.24% [95% CI, -0.81% to 0.33%]; adjusted HR, 0.67 [95% CI, 0.29 to 1.58]).

#### Subgroup Results

No studies reported subgroup findings by dose or dosing interval; some studies reported subgroup findings by age, sex, or other patient characteristics.

For Vitamin D alone, two studies reported subgroup results.^76,^ ^77^ Lips et al reported effect estimates for hip fracture incidence for the subset of study participants recruited from apartment homes for the elderly and for participants age 80 years or older. Results from both subgroup analyses were consistent with the overall analysis; no statistically significant differences in fracture incidence between treatment and placebo groups.^76^ Trivedi et al reported effects on total, hip, and vertebral fracture incidence by sex.^74^ Whereas the age-adjusted RR for total fracture incidence was 0.78 (95% CI, 0.61 to 0.99) the age-adjusted RR for women was 0.68 (95% CI, 0.46 to 1.01) and was 0.83 (95% CI, 0.61 to 1.13) for men. For hip fracture, the overall ageadjusted RR was 0.85 (95% CI, 0.47 to 1.53) and was 0.98 (95% CI, 0.41 to 2.36) for women and 0.76 (95% CI, 0.35 to 1.67) for men. For clinical vertebral fractures, the overall age-adjusted RR was 0.63 (95% CI, 0.35 to 1.14) with an age-adjusted RR of 0.65 (95% CI, 0.18 to 2.30) among women and 0.62 (95% CI, 0.32 to 1.22) among men.

For calcium alone, no studies reported findings by subpopulations.

For vitamin D with calcium, only the WHI Ca D trial reported findings by subpopulation. Fifteen subgroup analyses based on participant characteristics were reported in the main WHI study publication.^71^ We summarize those relevant to age, prior history of falls, use of hormone therapy, and personal use of supplements at baseline. However, we note that randomization was only stratified by age and clinical center, not by the other participant characteristics for which subgroup analyses were reported.

A borderline statistically significant treatment effect by age was reported for hip fracture (p=0.05). Women age 50 to 59 had an increased risk of hip fracture (HR, 2.17 [95% CI, 1.13 to 4.18]); women age 60 to 69 and women age 70 to 79 had a risk similar to the overall main trial effect, which was not significant. Similarly, a treatment effect was reported based on number of falls in the 12 months prior baseline (p=0.05); an increasing risk of fracture among treatment group compared with placebo groups was seen with increasing number of falls in the 12 months prior to baseline. Participants with no history of falls who were assigned to vitamin D with calcium had a slightly reduced risk of fracture relative to participants assigned to placebo (HR, 0.74 ([95% CI, 0.56 to 0.98]); whereas participants with one, two, or three or more falls had an increasing likelihood of fracture with increasing number of falls if assigned to treatment relative to placebo participants, but the confidence intervals for the point estimates in these subgroups did not exclude a null effect. No interaction of treatment effect was observed for race or ethnic group, weight or body mass index, smoking status, or sunlight exposure.

WHI study authors also report several subgroup analyses related to hormone therapy use. ^71,^ ^99^ In the main trial report, a borderline statistically significant interaction between treatment assignment in WHI Hormone Therapy trial and vitamin D with calcium treatment assignment was observed (p=0.07).^71^ Participants assigned to active hormone therapy had a statistically significant reduced risk for hip fracture (HR, 0.58 [95% CI, 0.37 to 0.93]) while participants assigned to placebo hormone therapy had a numeric but statistically nonsignificant increase in hip fracture when assigned to vitamin D with calcium compared with placebo (HR, 1.15 [95% CI, 0.81 to 1.63]).^71^ In a followup analysis, this interaction was evaluated across all 68,132 randomized participants in WHI clinical trials and this finding persisted (p for treatment interaction=0.01).^99^ However, no interaction between hormone therapy use and vitamin D with calcium treatment allocation and incident total fractures (p=0.97) or clinical vertebral fractures (p=0.79) was identified. Further, the main trial report indicated that when the analysis included both active hormone therapy assignment and personal hormone use, the trend towards a treatment interaction for hip fracture was no longer present.^71^

Because the WHI CaD Trial allowed for personal use of supplements throughout the trial, considerable debate about whether the trial supplementation would have a different impact on naïve users of supplements has been postulated. The main WHI trial publication reported an HR for hip fracture of 0.70 (95% CI, 0.51 to 0.98) for nonusers of calcium supplements at baseline, an HR of 0.87 (95% CI, 0.61 to 1.24) among those taking less than 500 mg per day, and an HR of 1.22 (95% CI, 0.83 to 1.79) among those taking 500 mg or more per day (p for interaction=0.11).^71^ In a separate analysis using the WHI CaD limited access data set, Bolland et al estimated effects for users and nonusers of vitamin D and calcium supplements at baseline.

This analysis found similar hip and total fracture incidences among these two subgroups; no statistically significant interactions were identified (p=0.72 for total fracture and p=0.65 for hip fracture).^97,^ ^98^ Similar findings were reported by the WHI study authors in an article published subsequent to the main trial findings.^98^

### KQ2 Direct Evidence for the Harms of Supplementation With Vitamin D or Calcium Alone or Vitamin D Combined With Calcium

#### Summary of Results

Nine RCTs that randomized 51,375 participants reported on the effect of supplementation with vitamin D alone, calcium alone, or vitamin D with calcium on all-cause mortality, incident kidney stones, cardiovascular disease (CVD), or cancer. The evidence is dominated by the WHI CaD Trial,^71^ which enrolled 36,282 women; the others enrolled only women (4 RCTs; 3,844 participants),^72,^ ^74,^ ^108,^ ^109^ only men (1 RCT),^92^ or both women and men (3 RCTs).^76-79^ Study characteristics and findings are summarized in Tables 2–5. Although studies reported on our KQ 2-specified outcomes, these outcomes were primary end points in only two studies. Studies reported statistically nonsignificant and imprecise effects over 3–7 years for all-cause mortality, incident cancer, and CVD.^108^ No studies evaluated the impact of vitamin D alone on kidney stone incidence. Calcium alone did not increase the incidence of kidney stones over 2 to 4 years (pooled ARD, 0.0% [95% CI, -0.9% to 0.9%]; pooled RR, 0.68 [95% CI, 0.14 to 3.4]; I^2^=0%, 3 RCTs, 1,292 participants), but vitamin D with calcium was associated with increased incidence over 4 to 7 years (pooled ARD, 0.3% [95% CI, 0.1% to 0.6%]; RR, 1.2 [95% CI, 1.04 to 1. 4]; I^2^=0%, 3 RCTs, 39,659 participants).

Table 2 Results Of RCTs Evaluating The Impact Of Vitamin D, Calcium, Or Combined Supplementation On All-Cause Mortality

Author (Year) | No. of Participants | Population | Intervention, Com parator | Followup (Years) | No. (%) With Event: Control Group | No. (%) With Event: Intervention Group | Summary Effect ARD (95%CI); RR or HR (95% CI) | Study Quality
Vitam in D Com pared With Placebo/Control
Komulainen et al, 1998^72^ | 232^*^ | Community-dwelling women ages 52 to 61 years between 6 and 24 months postmenopause | 300 IU oral vitamin D_3_ with 93 mg calcium^†^ daily, 93 mg calcium^†^ daily | Mean 4.3 (range 0 to 5.9) | 1 (0.9) | 0 (0) | ARD, -0.87% (-3.26% to 1.52%)^‡^ RR, 0.34 (0.01 to 8.31)^‡^ | Fair
Lips et al, 1996^76^ | 2,578 | Healthy adults age 70 years or older (74% women) recruited from general practitioners or from apartment houses or homes for the elderly^§^ | 400 IU oral vitamin D_3_ daily, placebo daily | Median 3.5 | 306 (23.8) | 282 (21.8) | ARD, -1.93% (-5.17% to 1.31%)^‡^ RR, 0.92 (0.80 to 1.06)^‡^ | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% women) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | 247 (18.4) | 224 (16.7) | ARD, -1.76% (-4.64% to 1.11%)^‡^ Age-adjusted RR, 0.88 (0.74 to 1.06) | Fair
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,108 | Community-dwelling adults 50 to 84 years (42% women) recruited from general practices | 200.000 IU vitamin D_3_ initial dose followed by 100.000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | 65 (2.6) | 58 (2.3) | ARD, -0.33% (-1.16% to 0.51%)^‡^ RR, 0.87 (0.61 to 1.24) | Good
Calcium Compared With Placebo
Reid et al, 2008^92^ | 290ǁ | Healthy, predominantly white men age 40 years and older | 600 mg oral calcium^¶^ daily, placebo daily | Panned 2 | 1 (1.0) | 1 (1.0) | ARD, -0.02% (-2.65% to 2.61%)^‡^ RR, 0.98 (0.06 to 15.48)^‡^ | Fair
Reid et al, 2008^92^ | 290ǁ | Healthy, predominantly white men age 40 years and older | 1,200 mg oral calcium^¶^ daily, placebo daily | Panned 2 | 1 (1.0) | 1 (1.1) | ARD, 0.05% (-2.67% to 2.77%)^‡^ RR,1.05 (0.07 to 16.57)^‡^ | Fair
Vitamin D With Calcium Compared With Placebo
WHI Calcium and Vitamin D Trial, 2013^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 years participating in either the WHI Dietary Modification or Hormone Therapy trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^#^ daily, placebo daily | Mean 7.0 (SD 1.4) | 807 (4.5) | 744 (4.1) | ARD, -0.36% (-0.78% to 0.05%)^‡^ HR, 0.91 (0.83 to 1.01) | Fair
Lappe et al, 2017^109^ | 2,197^**^ | Community-dwelling postmenopausal women older than age 55 years | 1,500 mg^#^ oral calcium with 2,000 IU vitamin D_3_ daily, placebo daily | Panned 4 | 9 (0.8%) | 7 (0.6%) | ARD, -0.19% (-0.90% to 0.52%)^‡^ RR, 0.77 (0.29 to 2.07)^‡^ | Fair

* This study randomized a total of 464 women; only the 232 women randomized to vitamin D or placebo were included in this review.

† Participants in both study groups received 93 mg of elemental calcium as lactate.

‡ Calculated based on raw data provided in published article.

§ Participants recruited from practitioners lived independently; participants recruited from apartments/homes for the elderly received some care (but less than they would receive in a nursing home).

ǁ Although 323 participants were randomized, analyses are based on 290 participants with followup data available.

¶ Elemental calcium dose as citrate.

# Elemental calcium as carbonate.

** Although 2,303 were randomized, analyses are based on 2,197 participants with followup data available.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; HR=hazard ratio; No.=number; RCT=randomized, controlled trial; RR=relat ive risk; WHI=Womenʼs Health Initiative.

Table 3 Results Of RCTs Evaluating The Impact Of Vitamin D, Calcium, Or Combined Supplementation On Incident Kidney Stones

Author (Year) | No. of Participants | Population | Intervention, Comparator | Followup (Years) | No. (%) With Event: Control Group | No. (%) With Event: Intervention Group | Summary Effect ARD, (95%CI); RR or HR (95% CI) | Study Quality
Vitam in D Compared With Placebo/Control
None | -- | -- | -- | -- | -- | -- | -- | --
Calcium Compared With Placebo
Lappe et al, 2007^108^ | 733^*^ | Community-dwelling postmenopausal women age 55 years or older | 1,400 mg^†^ or 1,500 mg^‡^ oral calcium daily, placebo daily | Panned 4 | 1 (0.4)) | 3 (0.7) | ARD, 0.33% (-0.69% to 1.35%)^§^ RR, 1.94 (0.20 to 18.57)^§^ | Fair
Reid et al, 2008^92^ | 290^ǁ^ | Community-dwelling healthy men age 40 years or older | 600 mg^†^ oral calcium daily, placebo daily | Panned 2 | 1 (1.0) | 0 (0) | ARD, -1.01% (-3.77% to 1.75%)^§^ RR, 0.34 (0.01 to 8.17)^§^ | Fair
Reid et al, 2008^92^ | 290^ǁ^ | Community-dwelling healthy men age 40 years or older | 1,200 mg^†^ oral calcium daily, placebo daily | -- | -- | 0 (0) | ARD, -1.01% (-3.81% to 1.79%)^§^ RR, 0.35 (0.01 to 8.60)^§^ | Fair
Riggs et al, 1998^74^ | 236 | Community-dwelling women ages 61 to 70 years who were postmenopausal for at least 10 years | 1,600 mg^†^ oral calcium daily, placebo daily | Panned 4 | 1(0.9) | 0 (0) | ARD, -0.85% (-3.18% to 1.47%)^§^ RR, 0.33 (0.01 to 7.97)^§^ | Fair
Vitamin D With Calcium Compared With Placebo
Lappe et al, 2007^108^ | 734^*^ | Community-dwelling postmenopausal women older than age 55 years | 1,400 mg^†^ or 1,500 mg^‡^ oral calcium daily and 1,000 IU vitamin D_3_, placebo daily | Panned 4 | 1 (0.4) | 1 (0.2) | ARD, -0.12% (-0.93% to 0.69%)^§^ RR, 0.65 (0.04 to 10.28)^§^ | Fair
Lappe et al, 2017^109^ | 2,197^¶^ | Community-dwelling postmenopausal women older than age 55 years | 1,500 mg^‡^ oral calcium with 2,000 IU vitamin D_3_ daily, placebo daily | Panned 4 | 10 (0.9%) | 16 (1.5%) | ARD, 0.54% (-0.36% to 1.44%)^§^ RR, 1.59 (0.72 to 3.49)^§^ | Fair
WHI Calcium and Vitamin D Trial, 2013^71^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 years participating in either the WHI Dietary Modification or Hormone Therapy trials | 400 IU oral vitamin D_3_ with 1,000 mg^‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | 381 (2.1) | 449 (2.5) | ARD, 0.37% (0.06% to 0.67%)^§^ RR, 1.17 (1.03 to 1.34) | Fair

* One woman was excluded from the study after entry because of hypoparathyroidism after thyroidectomy and daily use of 50,000 IU of vitamin D (reported in Lappe et al, 2006).^137^ This study randomized 288 women to placebo, 445 women to calcium alone, and 446 women to vitamin D with calcium.^108^

† Elemental calcium dose as citrate.

‡ Elemental calcium as carbonate.

§ Calculated based on raw data provided in published article.

ǁ Although 323 participants were randomized, analyses are based on 290 participants with followup data available.

¶ Although 2,303 participants were randomized, analyses are based on 2,197 participants with followup data available.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; HR=hazard ratio; No.=number; RCT=randomized, controlled trial; RR=relat ive risk; WHI=Womenʼs Health Initiative.

Table 4 Results Of RCTs Evaluating The Impact Of Vitamin D, Calcium, Or Combined Supplementation On Incident Cardiovascular Outcomes

Author (Year) | No. of Participants | Population | Intervention, Comparator | Followup (Years) | Outcome Event | No. (%) With Event: Control Group | No. (%) With Event: Intervention Group | Summary Effect ARD (95%CI); RR or HR (95% CI) | Study Quality
Vitam in D Com pared With Placebo/Control
Komulainen et al, 1998^72,^ ^119^ | 232^*^ | Community-dwelling women ages 52 to 61 years between 6 and 24 months postmenopause | 300 IU oral vitamin D_3_ daily with 93 mg calcium^†^ daily, 93 mg calcium^†^ daily | Mean 4.3 (range 0 to 5.9) | Myocardial infarction or CABG | 0 (0) | 2(1.8) | ARD, 1.79% (-1.18% to 4.75%)^‡^ RR, 5.13 (0.25 to 105.73)^‡^ | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% women; 27.4% of placebo group and 29.3% of vitamin D group had CVD at baseline) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Ischemic heart disease | 233 (17.4) | 224 (16.7) | ARD, -0.72% (-3.56% to 2.12%)^‡^ Age-adjusted RR, 0.94 (0.77 to 1.15) | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% women; 27.4% of placebo group and 29.3% of vitamin D group had CVD at baseline) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Cerebrovascular disease | 101 (7.5) | 105 (7.8) | ARD, 0.27% (-1.74% to 2.29%)^‡^Age-adjusted RR, 1.02 (0.77 to 1.36) | Fair
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,110 | Community-dwelling adults 50 to 84 years (42% women) recruited from general practices | 200.000 IU vitamin D_3_ initial dose followed by 100.000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | Myocardial infarction | 31 (1.2) | 28 (1.1) | ARD, -0.12% (-0.71% to 0.47%)^‡^ HR, 0.90 (0.54 to 1.50) | Good
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,110 | Community-dwelling adults 50 to 84 years (42% women) recruited from general practices | 200.000 IU vitamin D_3_ initial dose followed by 100.000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | Stroke | 27 (1.1) | 26 (1.0) | ARD -0.04% (-0.60% to 0.51%)^‡^ HR, 0.95 (0.55 to 1.62) | Good
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,110 | Community-dwelling adults 50 to 84 years (42% women) recruited from general practices | 200.000 IU vitamin D_3_ initial dose followed by 100.000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | VTE | 15 (0.6) | 11 (0.4) | ARD -0.16% (-0.55% to 0.23%)^‡^HR, 0.74 (0.34 to 1.61) | Good
Khaw, Scragg et al, 2017^78,^ ^79^ | 5,110 | Community-dwelling adults 50 to 84 years (42% women) recruited from general practices | 200.000 IU vitamin D_3_ initial dose followed by 100.000 IU monthly, initial placebo and every month | Median 3.3 (range 2.5 to 4.2) | Heart failure | 57 (2.2) | 69 (2.7) | ARD, 0.46% (-0. 39% to 1.31%)^‡^ HR, 1.19 (0.84 to 1.68) | Good
Calcium Compared With Placebo
Reid et al, 2008^92^ | 290^ǁ^ | Community-dwelling healthy men age 40 years or older | 600 mg oral calcium^§^ daily, placebo daily | Panned 2 | Myocardial Infarction | 0 (0) | 1 (1.0) | ARD, 1.02% (-1.75% to 3.80%)^‡^ RR, 3.03 (0.12 to 73.49)^‡^ | Fair
Reid et al, 2008^92^ | 290^ǁ^ | Community-dwelling healthy men age 40 years or older | 1,200 mg oral calcium^§^ daily, placebo daily | Panned 2 | Myocardial Infarction | 0 (0) | 2 (2.2) | ARD, 2.15% (-1.38% to 5.68%)^‡^ RR, 5.32 (0.26 to 109.35)^‡^ | Fair
Vitam in D Com bined With Calcium Com pared With Placebo
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Myocardial infarction^#^ | 390 (2.2) | 411 (2.3) | ARD, 0.11% (-0.20% to 0.41%)^‡^ HR, 1.03 (0.90 to 1.19) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Coronary heart disease^#^ | 475 (2.6) | 499 (2.8) | ARD, 0.12% (-0.21% to 0.45%)^‡^ HR, 1.03 (0.90 to 1.17) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Stroke^#^ | 377 (2.1) | 362 (2.0) | ARD, -0.09% (-0.38% to 0.20%)^‡^ HR, 0.95 (0.82 to 1.10) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | VTE (idiopathic or secondary)^**^ | 348 (1.9) | 320 (1.8) | ARD, -0.16% (-0.44% to 0.12%)^‡^ HR, 0.92 (0.79 to 1.07) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Deep vein thrombosis^**^ | 256 (1.4) | 246 (1.4) | ARD, -0.06% (-0.30% to 0.18%)^‡^ HR, 0.97 (0.82 to 1.16) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Pulmonary embolism^**^ | 149 (0.8) | 135 (0.7) | ARD, -0.08% (-0.26% to 0.10%)^‡^ HR, 0.92 (0.73 to 1.16) | Fair
WHI Calcium and Vitamin D Trial, 2006^71,^ ^98^ | 36,282 | Community-dwelling postmenopausal women ages 50 to 79 participating in either the WHI Detary Modification or Hormone Therapy Trials | 400 IU oral vitamin D_3_ with 1,000 mg calcium^¶^ daily versus placebo | Mean 7.0 (SD 1.4) | Heart failure hospitalization^††^ | 381 (2.1) | 363 (2.0) | ARD, -0.11% (-0.40% to 0.18%)^‡^ HR, 0.95 (0.82 to 1.09) | Fair

* This study randomized a total of 464 women; only the 232 women randomized to vitamin D or placebo were included in this review.

† Participants in both study groups received 93 mg of elemental calcium as lactate.

‡ Calculated based on raw data provided in published article.

§ Elemental calcium as citrate.

ǁ Although 323 participants were randomized, analyses are based on 290 participants with followup data available.

¶ Elemental calcium as carbonate.

# The outcomes reported here are those reported by the WHI Calcium and Vitamin D Trial investigators as published in Prentice et al.^98^ Post hoc subgroup analyses by the study investigators and by other investigators (who used the limited access data set) reported findings based on baseline use of personal calcium supplements at baseline. Among women not taking personal supplements at baseline, WHI Calcium and Vitamin D Trial investigators reported HR, 1.11 (95% CI, 0.90 to 1.37) for myocardial infarction; HR, 1.03 (95% CI, 0.85 to 1.25) for coronary heart disease; and HR, 1.12 (95% CI, 0.90 to 1.39) for stroke.^98^ Bolland et al^116^ reported HR, 1.22 (95% CI, 1.00 to 1.5) for clinical myocardial infarction, which excluded silent myocardial infarctions detected on serial ECG monitoring conducted as part of study monitoring; and HR, 1.17 (95% CI, 0.95 to 1.44) for stroke.

** As reported by Blondon et al^117^; this outcome includes deep vein thrombosis and pulmonary embolism events.

†† As reported by Donneyang et al^118^; sample size used was 35,983 because of exclusion of participants with history of heart failure at the time of enrollment from the analysis. Subgroup analysis by baseline risk of heart failure as defined by American College of Cardiology criteria (presence of HTN, DM, coronary heart disease, or CVD): low-risk subgroup: HR, 0.63 (95% CI, 0.46 to 0.87), high-risk subgroup HR, 1.06 (95% CI, 0.90 to 1.24).

Abbreviations: ARD=absolute risk difference; CI=confidence interval; CABG=coronary artery bypass graft; CVD=cardiovascular disease; DM=diabetes mellitus; ECG=electrocardiogram; HR=hazard ratio; HTN=hypertension; RCT=randomized, controlled trials; RR=relative risk; VTE=venous thromboembolism; WHI=Womenʼs Health Initiative.

Table 5 Results of RCTs Evaluating the Association Between Vitamin D, Calcium, or Combined Supplementation and Incident Cancer

Author (Year) | No. of Participants | Population | Intervention, Comparator | Followup (Years) | Outcome Event | No. (%) With Event: Control Group | No. (%) With Event: Intervention Group | Summary Effect ARD, (95%CI), RR, or HR, (95% CI) | Study Quality
Vitam in D Compared With Placebo/Control
Komulainen et al, 1998^72,^ ^119^ | 232^*^ | Community-dwelling women ages 52 to 61 years between 6 and 24 months postmenopause | 300 IU oral vitamin D_3_ with 93 mg calcium^†^ daily, 93 mg calcium^†^ daily | Mean 4.3 (range 0 to 5.9) | Incident cancer^‡^ | 3 (2.6) | 2 (1.8) | ARD, -0.82% (-4.63% to 2.99%)^§^ RR, 0.68 (0.12 to 4.02)^§^ | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% w omen) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Any incident cancer | 173 (12.9) | 188 (14.0) | ARD, 1.08% (-1.50% to 3.66%)^§^ Age-adjusted RR, 1.09 (0.86 to 1.36) | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% w omen) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Any incident cancer, excluding skin | 130 (9.7) | 144 (10.7) | ARD, 1.01% (-1.28% to 3.30%)^§^ Age-adjusted RR, 1.11 (0.86 to 1.42) | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% w omen) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Incident colon cancer | 27 (2.0) | 28 (2.1) | ARD, 0.07% (-1.00% to 1.14%)^§^ Age-adjusted RR, 1.02 (0.60 to 1.74) | Fair
Trivedi et al, 2003^77^ | 2,686 | Community-dwelling adults ages 65 to 85 years (24% w omen) | 100,000 IU oral vitamin D_3_ every 4 months, placebo every 4 months | Panned 5 | Incident respiratory cancer | 15 (1.1) | 17 (1.3) | ARD, 0.15% (-0.68% to 0.97%)^§^ Age-adjusted RR, 1.12 (0.56 to 2.25) | Fair
Calcium Compared With Placebo
Lappe et al, 2007^108^ | 733^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Total nonskin cancers^**^ | 20 (6.9) | 17 (3.8) | ARD, -3.12% (-6.56% to 0.31%)^§^ RR, 0.55 (0.29 to 1.03)^§^ | Good
Lappe et al, 2007^108^ | 733^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Breast cancer | 8 (2.8) | 6 (1.4) | ARD, -1.43% (-3.61% to 0.75%)^§^ RR, 0.49 (0.17 to 1.4)^§^ | Good
Lappe et al, 2007^108^ | 733^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Colon cancer | 2 (0.7) | 0 (0) | ARD, -0.69% (-1.81% to 0.42%)^§^ RR, 0.13 (0.01 to 2.69)^§^ | Good
Vitamin D With Calcium Compared With Placebo
Lappe et al, 2007^108^ | 734^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,000 IU vitamin D_3_ with 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Incident cancer, excluding skin^**^ | 20 (6.9) | 13 (2.9) | ARD, -4.03% (-7.35% to -0.70%)^§^ RR, 0.42 (0.21 to 0.83)^§^ | Good
Lappe et al, 2007^108^ | 734^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,000 IU vitamin D_3_ with 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Incident breast cancer | 8 (2.8) | 5(1.1) | ARD, -1.66% (-3.79% to 0.48%)^§^ RR, 0.40 (0.13 to 1.22)^§^ | Good
Lappe et al, 2007^108^ | 734^ǁ^ | Community-dwelling postmenopausal women age 55 years or older without prevalent cancer or a history of cancer within the prior 10 years | 1,000 IU vitamin D_3_ with 1,400 mg^¶^ or 1,500 mg^#^ calcium daily, placebo daily | Panned 4 | Incident colon cancer | 2 (0.7) | 1 (0.2) | ARD, -0.47% (-1.52% to 0.58%)^§^ RR, 0.32 (0.03 to 3.54)^§^ | Good
WHI Calcium and Vitamin D Trial, 2006^††^ | 36,282^**^ | Postmenopausal women ages 50 to 79 years who were participating in the WHI Diet Modification and/or Postmenopausal Hormone Therapy Trials | 400 IU vitamin D_3_ with 1,000 mg^‡‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | Total excluding non-melanoma skin cancer | 1,411 (7.8) | 1,366 (7.5) | ARD, -0.28% (-0.82% to 0.27%)^§^ HR, 0.96 (0.89 to 1.04) | Fair
WHI Calcium and Vitamin D Trial, 2006^††^ | 36,282^**^ | Postmenopausal women ages 50 to 79 years who were participating in the WHI Diet Modification and/or Postmenopausal Hormone Therapy Trials | 400 IU vitamin D_3_ with 1,000 mg^‡‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | Colorectal cancer | 154 (0.9) | 168 (0.9) | ARD, 0.07% (-0.12% to 0.27%)^§^ HR, 1.06 (0.85 to 1.32)^§§^ | Fair
WHI Calcium and Vitamin D Trial, 2006^††^ | 36,282^**^ | Postmenopausal women ages 50 to 79 years who were participating in the WHI Diet Modification and/or Postmenopausal Hormone Therapy Trials | 400 IU vitamin D_3_ with 1,000 mg^‡‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | Breast cancer | 546 (3.0) | 528 (2.9) | ARD, -0.11% (-0.46% to 0.24%)^§^ HR, 0.96 (0.85 to 1.08) | Fair
WHI Calcium and Vitamin D Trial, 2006^††^ | 36,282^**^ | Postmenopausal women ages 50 to 79 years who were participating in the WHI Diet Modification and/or Postmenopausal Hormone Therapy Trials | 400 IU vitamin D_3_ with 1,000 mg^‡‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | Non-melanoma skin cancer | 1,655 (9.1) | 1,683 (9.3) | ARD, 0.12% (-0.48% to 0.71%)^§^ HR, 1.02 (0.95 to 1.07) | Fair
WHI Calcium and Vitamin D Trial, 2006^††^ | 36,282^**^ | Postmenopausal women ages 50 to 79 years who were participating in the WHI Diet Modification and/or Postmenopausal Hormone Therapy Trials | 400 IU vitamin D_3_ with 1,000 mg^‡‡^ calcium daily, placebo daily | Mean 7.0 (SD 1.4) | Melanoma skin cancer | 94 (0.5) | 82 (0.5) | ARD, -0.07% (-0.21% to 0.07%)^§^ HR, 0.86 (0.64 to 1.16) | Fair
Lappe et al, 2017^109^ | 2,197^ǁǁ^ | Community-dwelling postmenopausal women older than age 55 years | 1,500 mg^‡^ oral calcium with 2,000 IU vitamin D_3_ daily, placebo daily | Panned 4 | Total excluding non-melanoma skin cancer | 64 (5.8%) | 45 (4.1%) | ARD, -1.76% (-3.58% to 0.05%)^§^ RR, 0.70 (0.48 to 1.01) ^§^ | Fair
Lappe et al, 2017^109^ | 2,197^ǁǁ^ | Community-dwelling postmenopausal women older than age 55 years | 1,500 mg^‡^ oral calcium with 2,000 IU vitamin D_3_ daily, placebo daily | Panned 4 | Breast cancer | 23 (2.1%) | 16 (1.5%) | ARD, -0.65% (-1.75% to 0.46%)^§^ RR, 0.69 (0.37 to 1.30) | Fair
Lappe et al, 2017^109^ | 2,197^ǁǁ^ | Community-dwelling postmenopausal women older than age 55 years | 1,500 mg^‡^ oral calcium with 2,000 IU vitamin D_3_ daily, placebo daily | Panned 4 | Colorectal cancer | 4 (0.4%) | 4 (0.4%) | ARD, 0.00% (-0.51% to 0.50%)^§^ RR, 0.99 (0.25 to 3.96) ^§^ | Fair

* This study randomized a total of 464 women; only the 232 women randomized to vitamin D or placebo were included in this review.

† Participants in both study groups received 93 mg of elemental calcium as lactate.

‡ Described as malignancies and reported as serious adverse events.^119^

§ Calculated based on raw data provided in published article.

ǁ One woman was excluded from the study after entry because of hypoparathyroidism after thyroidectomy and daily use of 50,000 IU of vitamin D (reported in Lappe et al, 2006).^137^ This study randomized 288 women to placebo, 445 women to calcium alone, and 446 women to vitamin D with calcium.^108^

¶ Elemental calcium dose as citrate.

# Elemental calcium as carbonate.

** Investigators also performed an analysis of total nonskin cancers that developed after the first year of followup: the denominators were 266 (placebo), 416 (calcium alone), and 403 (vitamin D plus calcium) as opposed to the 288, 445, and 446 women who were randomized to those groups, respectively. Results were similar to those from the ITT analysis.

†† Findings reported from the WHI Calcium and Vitamin D Trial in the following publications: Jackson et al, 2003,^96^ Jackson et al, 2006^71^ Wactawski-Wende et al, 2006,^113^ Tang et al, 2011,^121^ Brunner et al, 2011,^122^ Bolland et al, 2011,^97^ Prentice et al, 2012.^98^

‡‡ This is the total number randomized in the WHI Calcium and Vitamin D Trial; however, cancer outcomes were not the primary trial endpoint and some analyses reporting incident cancer outcomes were based on a smaller sample size because participants with a recent history of cancer were excluded from the analyses of incident cancer outcomes.

§§ The HR reported by Wactawski-Wende et al^113^ was slightly different (1.08; 95% CI, 0.86 to 1.34) than that reported in Prentice et al^98^; however, counts of invasive colorectal cancer cases were reported the same in both.

ǁǁ Although 2,303 participants were randomized, analyses are based on 2,197 participants with followup data.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; HR=hazard ratio; ITT=intent to treat; No.=number; RR=relative risk; WHI=WomenʼsHealth Initiative.

#### All-Cause Mortality

Seven RCTs examined the effect of supplementation with vitamin D alone, calcium alone, or vitamin D with calcium on all-cause mortality.^71,^ ^72,^ ^76-79,^ ^92,^ ^109^ Findings are summarized in Table 2.

##### Vitamin D Compared With Placebo: Study Characteristics

One new, good-quality RCT (Khaw, Scragg et al^78,^ ^79^ and three fair-quality RCTs (Trivedi et al,^110^ Komulainen et al,^72^ Lips et al^76^) all previously described reported on the effect of vitamin D alone on all-cause mortality. These studies examined doses of vitamin D that included 300 or 400 IU daily or 100,000 IU every month or 4 months over 3.3–5 years. They were conducted in New Zealand, United Kingdom, Finland, and The Netherlands, and three of the four studies included men. Three of the four studies were included in the prior review but all-cause mortality was not an outcome synthesized in the prior review. We identified two studies for use in sensitivity analyses. One study (Sanders et al^84^) was included in the prior review but was not eligible for the main analysis in this update because 35 percent of the study population had a history of fracture and the trial focused on enrolling subjects with a high risk for fracture. Another study (Hin et al^111^) was published since the last review but was not eligible for this update because 30 percent of the study population had a history of prior fracture.

Khaw, Scragg et al and Trivedi et al determined mortality outcomes using death certificates.^77,^ ^111^ Komulainen et al did not specifically describe how mortality was determined.^72^ Lips et al determined mortality outcomes by asking participants’ general practitioners or caretakers to immediately report deaths when they occurred and verifying all deaths with general practitioners.^76^

##### Vitamin D Compared With Placebo: Findings

All studies reported numeric but statistically nonsignificant decreases in all-cause mortality between vitamin D and placebo groups. The pooled ARD was -0.74% (95% CI, -1.80% to 0.32%; I^2^=19.6%; 4 RCTs; 10,599 participants) and the pooled RR was 0.91 (95% CI, 0.82 to 1.01; I^2^=0%). The results were similar when we included the two studies we identified for use in sensitivity analyses (Appendix F Figures 11 and 12).

##### Calcium Compared With Placebo: Study Characteristics

Reid et al, previously described, examined the effect of calcium alone on all-cause mortality.^92^ This study randomized 323 healthy men age 40 years or older in New Zealand to 1,200 mg calcium citrate, 600 mg calcium citrate, or placebo over 2 years. The investigators did not provide detail about how mortality was ascertained.

We also included two fair-quality RCTs conducted in New Zealand and Australia in a sensitivity analysis.^88-91^ These studies were not eligible for the main analysis because a third of the study populations had a history of prior fractures. Bolland and Reid et al^88,^ ^89^ compared 1,000 mg of oral calcium citrate with placebo over 5 years among 1,417 postmenopausal women age 55 or older and Prince and Lewis et al^90,^ ^91^ compared 1,200 mg of oral calcium carbonate with placebo over 4.5 years among 1,460 healthy, vitamin D-sufficient, women over age 70.

##### Calcium Compared With Placebo: Findings

Reid et al reported one death in each of the placebo, 600 mg calcium, and 1,200 mg calcium groups among the 290 participants with data at followup; effect estimates were not statistically significant and were imprecise.^92^ The two RCTs included in a sensitivity analysis also reported statistically nonsignificant findings, though point estimates were on opposite sides of the null effect.^88-91^ The pooled ARD including these studies was -0.15% (95% CI, -1.40% to 1.10%; I^2^ = 0%; 3 RCTs, 3,240 participants) and the pooled RR was 0.95 (95% CI, 0.68 to 1.32; I^2^ = 0%) (Appendix F Figures 13 and 14).

##### Vitamin D With Calcium Compared With Placebo: Study Characteristics

We identified one new trial reporting all-cause mortality for this update. Lappe et al^109^ examined the effect of 2,000 IU of vitamin D_3_ plus 1,500 mg of calcium carbonate daily compared with placebo for 4 years in 2,197 women (mean age 65 years).^109^ The WHI CaD Trial, included in the prior review, also reported all-cause mortality.^96,^ ^98,^ ^112,^ ^113^ Ascertainment methods were not described in Lappe et al^109^ while in the WHI CaD trial, mortality was ascertained by contacting participants’ previously identified proxy informants, National Death Index searches, and obituary notices.^112^ In addition to effect estimates reported in the main WHI CaD Trial publication, a post hoc subgroup analysis by Bolland et al used the WHI limited access data set to report effect on all-cause mortality among participants who were using personal calcium or vitamin D supplements at baseline compared with those who were not.^97^

We also used the RCT conducted by Salovaara et al, described in a previous section, in a sensitivity analysis.^107^ This study was not eligible for our main analysis because it was rated as poor quality and because approximately one-third of study participants had a prior history of fracture.

##### Vitamin D With Calcium Compared With Placebo: Findings

No significant differences in all-cause mortality were reported by either study. Lappe et al^109^ reported 7 (0.6%) deaths in the vitamin D with calcium group and 9 (0.8%) deaths in the placebo group over 4 years (ARD -0.19% [95% CI, -0.90% to 0.52%]; RR, 0.77 [95% CI, 0.29 to 2.07]. The WHI CaD Trial reported 744 (4.1%) deaths in the vitamin D with calcium group and 807 (4.5%) deaths in the placebo group over 7 years (ARD, -0.36% [95% CI, -0.78% to 0.05%]; HR, 0.91 [95% CI, 0.83 to 1.01]).^98^ In post hoc analyses using the WHI limited access dataset, Bolland et al reported no statistically significant interaction between use of personal supplements at baseline and treatment allocation (p for interaction=0.44).^97^ The one trial used in a sensitivity analysis reported a numeric but statistically nonsignificant increase in all-cause mortality (RR, 1.17 [95% CI, 0.56 to 2.45]).^107^

#### Kidney Stones

Five RCTs examined the effect of supplementation with calcium alone or vitamin D combined with calcium on incident kidney stones.^71,^ ^74,^ ^92,^ ^108,^ ^109,^ ^113,^ ^114^ No RCTs evaluating the effects of vitamin D alone on incident kidney stones were included in the prior review, and we identified no new eligible studies for this update. A summary of the findings is in Table 3.

##### Vitamin D Compared With Placebo: Study Characteristics

No RCTs evaluating the effects of vitamin D alone on incident kidney stones were identified. We identified three RCTs for use in a sensitivity analysis. Two were excluded from the main analysis because of poor quality related to high attrition and lack of specification about ascertainment of kidney stone outcomes.^86,^ ^115^ The third study was excluded because more than 20 percent of its study population had prevalent fractures or prior history of fractures at baseline.^110^ The studies in the sensitivity analysis examined between 120 and 408 participants from the United States and Australia over 3–5 years, and evaluated daily doses of vitamin D ranging from 600 to 2,000 IU. In one study, kidney stones were ascertained through a self-report diary; in the other two studies, the methods of ascertaining stones were not described.

##### Vitamin D Compared With Placebo: Findings

In the sensitivity analysis, no kidney stones developed among any participants in any of the three studies.^86,^ ^110,^ ^115^

##### Calcium Compared With Placebo: Study Characteristics

Three fair-quality RCTs examined the effect of calcium alone on incident kidney stones.^74,^ ^92,^ ^108^ Lappe et al^108^ and Riggs et al^74^ enrolled postmenopausal women (mean age 66 to 67 years) in the United States; Reid et al^92^ enrolled healthy men from New Zealand who were age 40 years or older (mean age 56). In these studies, participants were randomized to oral calcium (600 to 1,600 mg daily) or placebo for 2–4 years. Reid et al ascertained kidney stones by self-report at each visit. The other studies did not describe how kidney stones were ascertained. The mean baseline serum 25-hydroxyvitamin D level among all women in the Lappe et al^108^ trial was 71.8 nmol/L.

We considered five studies in a sensitivity analysis.^73,^ ^86,^ ^88,^ ^90,^ ^91,^ ^93,^ ^95^ Three^73,^ ^86,^ ^93,^ ^95^ were excluded from the main analysis for poor quality because they did not specify how kidney stones were ascertained and had high attrition. Two were excluded from the main analysis because more than 20 percent of the study population had a history of fractures at baseline.^88-91^ The studies in the sensitivity analysis examined the effects of daily 750–1,200 mg of calcium compared with placebo for 4–5 years. In these studies, kidney stone ascertainment was either by self-report or not described by study authors.

##### Calcium Compared With Placebo: Findings

In the three included studies,^74,^ ^92,^ ^108^ which randomized 1,292 participants, six kidney stones occurred overall, three among those randomized to calcium and three in those assigned to placebo (Table 3). The pooled ARD for incident kidney stones was 0.00% (95% CI, -0.88% to 0.87%) and the pooled RR was 0.68 (95% CI, 0.14 to 3.36, I^2^=0%, 3 RCTs, 1,259 participants) for calcium compared with placebo over 2–4 years of use. We added five additional studies in a sensitivity analysis.^73,^ ^86,^ ^88,^ ^90,^ ^91,^ ^93,^ ^95^ Overall, a numeric but statistically nonsignificant decrease in incidence remained, though the magnitude of the relative decrease was attenuated because of mixed effects found among studies used in sensitivity analysis (Appendix F Figures 15 and 16).

##### Vitamin D Combined With Calcium Compared With Placebo: Study Characteristics

The 2007 RCT by Lappe et al^108^ and the WHI CaD Trial,^71,^ ^96,^ ^113,^ ^114^ both rated as fair-quality for this outcome, were conducted in postmenopausal women in the United States and were included in the previous review. We identified one new fair-quality RCT, also conducted by Lappe et al for this update.^109^ Lappe et al^108^ examined the effect of 1,000 IU of vitamin D with 1,400–1,500 mg of oral calcium compared with placebo for 4 years in 734 women (mean age 67 years).^108^ The WHI CaD Trial examined 36,282 postmenopausal women ages 50 to 79 years (mean age 62 years) who were randomized to 400 IU of oral vitamin D_3_ with 1,000 mg of calcium daily or placebo for 7 years. Lappe et al^109^ examined the effect of 2,000 IU of vitamin D_3_ plus 1,500 mg of calcium carbonate daily compared with placebo for 4 years in 2,197 women (mean age 65 years).^109^ In the WHI CaD Trial, kidney or bladder stones were self-reported at semiannual study visits or identified from a review of medical records for any subjects hospitalized for 48 hours or more. Lappe et al did not describe how kidney stones were ascertained in either the 2007 or 2017 trial.

We used one fair-quality study by Zhu & Prince et al in a sensitivity analysis; it was not eligible for the main analysis because more than 20 percent of its study population had a history of fracture due to minimal trauma since age 50.^90,^ ^110^ This study, which was conducted in Australia, recruited relatively healthy and ambulatory women over the age of 70 years. The first 120 sequential participants of a larger trial were enrolled in this substudy and randomized to either 1,200 mg of calcium carbonate, 1,200 mg of calcium carbonate with 1,000 IU vitamin D_2_, or daily placebo for 5 years.^110^ The mean baseline serum 25-hydroxyvitamin D concentration was 68 nmol/L. Kidney stones were ascertained by a self-report adverse event diary.

##### Vitamin D Combined With Calcium Compared With Placebo: Findings

Lappe et al^108^ reported one kidney stone in the vitamin D and calcium combined group (0.2%) and one in the placebo group (0.4%) for an ARD of -0.12% (95% CI, -0.93% to 0.69%) and RR of 0.65 (95% CI, 0.04 to 10.28) for participants randomized to vitamin D and calcium compared with placebo.^108^ Lappe et al^109^ reported 16 (1.5%) kidney stones in the vitamin D and calcium group and 10 (0.9%) in the placebo group for an ARD of 0.54% (95% CI, -0.36% to 1.44%) and RR of 1.59 (95% CI, 0.72 to 3.49).^109^ In the WHI CaD Trial, a statistically significant increase in incidence was observed; 449 women (2.5%) in the vitamin D with calcium group developed kidney or bladder stones compared with 381 women (2.1%) in the placebo group (ARD, 0.37% [95% CI, 0.06 to 0.67]; RR, 1.17 [95% CI, 1.03 to 1.34]).^71,^ ^96,^ ^113,^ ^114^ The pooled ARD and RR showed a statistically significant increase in incidence (pooled ARD 0.33% [95% CI, 0.06% to 0.60%]; pooled RR, 1.18 [95% CI, 1.04 to 1.35]; I^2^=0%, 3 RCTs, 39,213 participants) (Appendix F Figures 17 and 18). No kidney stones occurred in either the placebo or treatment group of the one study considered in sensitivity analysis.^110^

#### Cardiovascular Disease

Five RCTs examined the effect of supplementation with vitamin D alone,^72,^ ^77-79^ calcium alone,^92^ or vitamin D with calcium^71,^ ^98,^ ^116-118^ on CVD outcomes. Findings are summarized in Table 4.

##### Vitamin D Compared With Placebo: Study Characteristics

We identified one new, good-quality RCT that examined the effect of supplementation with vitamin D alone on CVD outcomes.^78,^ ^79^ In addition, we included two fair-quality RCTs from the prior review.^72,^ ^77^ Both RCTs have been previously described in detail under KQ 1. Briefly, Khaw, Scragg et al^78,^ ^79^ randomized 5,110 men and women ages 50 to 84 to an initial dose of 200,000 IU followed by 100,000 IU every month for a median of 3.3 years. Trivedi et al^77^ randomized 2,037 men and 649 women ages 65 to 85 years in the United Kingdom to 100,000 IU of oral vitamin D_3_ or placebo every 4 months over 5 years. Komulainen et al^72^ randomized 232 postmenopausal women age 52 to 61 years in Finland to 300 IU of vitamin D_3_ with 93 mg of calcium or to 93 mg of calcium alone and evaluated outcomes over a mean of 4.3 years.^72,^ ^76^ In all studies, treatment and control groups were balanced on the CVD risks that were measured at baseline. Khaw, Scragg et al ascertained outcomes through national data on cause of death and hospital discharges.^78,^ ^79^ Trivedi et al ascertained incidence of CVD using events reported on participant followup questionnaires or from causes listed on death certificates that were coded using an industry-standard classification system.^77^ Komulainen et al did not specify how CVD events were ascertained, but they were reported as serious adverse events and, thus, were likely captured as part of trial safety monitoring.^72,^ ^119^

We identified three RCTs for use in sensitivity analysis.^84,^ ^87,^ ^120^ The Sanders et al RCT (which we rated as fair quality for CVD outcomes) was included in the prior review for the USPSTF for fracture outcomes, but a synthesis of cardiovascular harm outcomes was not included.^84^ As described under KQ 1, this study was conducted in Australia and randomized women (median age 76 years) to an annual 500,000 IU dose of vitamin D_3_ or placebo for up to 5 years. It was not eligible for our main analysis because one third of its participants had a history of fracture since age 50. The other two studies considered in sensitivity analysis were excluded from the main analysis because of poor quality. These included the RCT by Cherniak et al,^120^ which was conducted among 46 U.S. male veterans age 70 years or older who were randomized to oral vitamin D_3_ 2,000 IU daily or placebo for 6 months and the RCT by Glendenning et al,^87^ which was a 9-month RCT of oral vitamin D_3_ 150,000 IU every 3 months versus placebo in 686 community-dwelling ambulatory women over age 70 years in Western Australia. Both studies were rated as poor quality because of measurement bias due to outcome specification and ascertainment and because they were conducted over relatively short periods of followup precluding a distinction between prevalent and incident cases.

##### Vitamin D Compared With Placebo: Findings

No statistically significant differences in incident cardiovascular or cerebrovascular outcomes were found for vitamin D compared with placebo; however, estimates were imprecise. Khaw, Scragg et al reported myocardial infarction over 3.3 years in 28 (1.1%) vitamin D group participants and in 31 (1.2%) placebo group participants (ARD, -0.12%, [95% CI, -0.71% to 0.47%]; HR, 0.90 [95% CI, 0.54 to 1.50]).^78^ Similar, nonsignificant findings were found for stroke, venous thromboembolism (VTE), and heart failure outcomes reported by this study. Trivedi et al reported incident ischemic heart disease over 5 years in 224 participants (16.7%) assigned to vitamin D versus 233 participants (17.4%) assigned to placebo (ARD, -0.72% [95% CI, -3.56% to 2.12%]; age-adjusted RR, 0.94 [95% CI, 0.77 to 1.15]).^77^ Among women, the ageadjusted RR was 0.79 (95% CI, 0.48 to 1.29) and among men was 0.98 (95% CI, 0.78 to 1.22). For incident cerebrovascular disease, 105 (7.8%) of participants in the vitamin D group versus 101 (7.5%) participants in the placebo group had events (ARD, 0.27% (95% CI, -1.74% to 2.29%); age-adjusted RR, 1.02 [95% CI, 0.77 to 1.36]). For this outcome, the age-adjusted RR for women was 1.19 (95% CI, 0.60 to 2.37) and was 0.99 (95% CI, 0.72 to 1.36) for men. CVD events in the other RCT (Komulainen et al^72^) were rare; in the vitamin D group, one woman had a myocardial infarction and one had a coronary bypass operation. No cardiovascular events were reported in the placebo group. We considered three additional trials in a sensitivity analysis (ARD range from -0.63% to 0.35%, RR range from 0.47 to 1.42), which reported nonsignificant findings for stroke and ischemic heart disease.

##### Calcium Compared With Placebo: Study Characteristics

One fair-quality RCT examined the association between supplementation with calcium alone and incident cardiovascular events. Reid et al randomized 323 predominantly white, healthy men age 40 years or older in New Zealand to daily oral placebo, 600 mg calcium citrate, or 1,200 mg calcium citrate.^92^ Study groups were balanced on baseline CVD risk factors except for smoking; the prevalence of smoking was higher in the placebo group (6%) than in the 600-mg per day (3%) and 1,200-mg per day (1%) calcium groups. Adverse events possibly influenced by calcium intake, including cardiovascular events, were prespecified in the trial protocol and asked about and recorded at each study visit.

We identified two RCTs^89,^ ^91^ for use in sensitivity analysis; both were excluded from the main analysis because the proportion of subjects with prevalent fracture at baseline was between 20 and 49 percent. Bolland and Reid et al^89^ reported on a 5-year RCT in 1,471 postmenopausal women in New Zealand randomized to 1,000 mg calcium citrate daily or placebo. Data on incident myocardial infarction or stroke were collected during assessment of adverse events at every study visit. Lewis & Prince et al reported cardiovascular outcomes over 5 years from an RCT conducted among 1,460 women age 70 years or older recruited from the general population in Western Australia and randomized to 1,200 mg calcium carbonate daily or placebo.^90,^ ^91^ Atherosclerotic deaths and first-time hospitalizations were retrieved from the Western Australian Data Linkage System and events were defined using industry-standard diagnosis codes.

##### Calcium Compared With Placebo: Findings

Of participants who reported taking the assigned study medication at the end of the study, Reid et al reported no CVD events in the placebo group, one event in the 600 mg calcium group (ARD, 1.02% [95% CI, -1.75% to 3.80%]; RR, 3.03 [95% CI, 0.12 to 73.49]), and two events in the 1,200 mg calcium group (ARD, 2.15% [95% CI, -1.38% to 5.68%]; RR, 5.32 [95% CI, 0.26 to 109.35]).^92^ The two studies considered in sensitivity analysis reported small numeric but statistically nonsignificant increases in incidence of myocardial infarction, stroke, or incident ischemic heart disease diagnosis (ARD range -0.81% to 1.43%; RR range 0.76 to 1.49).

##### Vitamin D and Calcium Compared With Placebo: Study Characteristics

Although the WHI CaD Trial was included in the prior review for the USPSTF, cardiovascular outcomes were not included in the synthesis. This fair-quality trial compared 400 IU of oral vitamin D_3_ with 1,000 mg of calcium carbonate among 36,282 postmenopausal U.S. women.^71,^ ^96,^ ^98^ Baseline CVD risk factors were balanced between groups. Of note, 51.9 percent of participants were users of hormone therapy at baseline, and 22.4 percent were allocated to the active hormone therapy group of the WHI Hormone Therapy Trial. Medical records related to self-reported myocardial infarction, stroke, and coronary revascularization were adjudicated centrally by physician adjudicators using standardized definitions.^71,^ ^96,^ ^98^ Silent myocardial infarctions were diagnosed using serial electrocardiograms during the WHI CaD Trial; we only considered clinical myocardial infarction events in our synthesis.

In addition to the outcomes reported in the main study publication, we identified four additional analyses of CVD outcomes from the WHI CaD Trial.^98,^ ^116-118^ Two were analyses to evaluate the effect of supplementation among subgroups of women defined by use of personal calcium and vitamin D supplements at baseline. Bolland et al used the WHI CaD Trial limited access dataset to evaluate the risk of cardiovascular events, comparing women who did (54% of trial participants) and did not take personal supplements at the time of randomization.^116^ In this analysis,^116^ CVD risks were balanced between the vitamin D with calcium group and the placebo group for the subgroup of participants that did not take personal calcium or vitamin D supplements and were similar to the baseline values reported by the main WHI CaD Trial.^71,^ ^96^ This analysis prespecified four cardiovascular end points and their combinations, which were slightly different from how CVD outcomes were specified in the main WHI trial.^116^ The WHI study authors also published findings from a subgroup analysis related to personal use of supplements at baseline.^98^

The other two WHI CaD analyses reported on the effect of supplementation on incident VTE outcomes^117^ and heart failure hospitalizations.^118^ Blondon et al reported on incident VTE events; for women enrolled in the WHI CaD and Hormone Therapy Trials, events were confirmed and adjudicated while events for women enrolled in the WHI CaD and Dietary Modification Trial were self-reported.^117^ In these analyses, relevant baseline characteristics, including history of VTE, history of CVD, history of cancer, current smoking, and WHI Hormone Therapy Trial participation, were balanced at baseline. Donneyong et al assessed incident heart failure by local and central (for a subset of subjects) physician adjudication of medical records for any hospitalization related to heart failure.^118^ This analysis excluded 299 WHI CaD participants with a diagnosis of heart failure at enrollment. The investigators included a comparison of low-risk and high-risk subgroups defined by American College of Cardiology criteria for risk of heart failure (presence of hypertension, diabetes mellitus, coronary heart disease [CHD], or vascular disease). Compared with the low-risk subgroup, the high-risk subgroup was on average older, less white, and had a higher prevalence of family history of CVD.

We identified one study for use in sensitivity analysis. The Zhu et al substudy^110^ enrolled the first 120 sequential participants of the main trial conducted by Prince and Lewis et al^90,^ ^91^ to one of three groups: calcium 1,200 mg; 1,000 IU vitamin D_2_ with 1,200 mg calcium; or placebo. CVD events were ascertained with adverse event diaries.

##### Vitamin D and Calcium Compared With Placebo: Findings

Incident CVD and stroke. In the WHI CaD Trial, no statistically significant differences were reported in cardiovascular outcomes including for participants assigned to vitamin D with calcium compared with placebo.^98^ For incident myocardial infarction (MI), 411 participants (2.3%) in the vitamin D and calcium group had an event and 390 participants (2.2%) in the placebo group had an event at 7 years (ARD, 0.11% [95% CI, -0.20% to 0.41%]; HR, 1.03; 95% CI, 0.90 to 1.19). Similar findings were reported for CHD and stroke (CHD ARD, 0.12% [95% CI, -0.21% to 0.45%]; HR, 1.03 [95% CI, 0.90 to 1.17]; stroke ARD, -0.09% [95% CI, -0.38% to 0.20%]; HR, 0.95 [95% CI, 0.82 to 1.10]).

In the one study considered in a sensitivity analysis, Zhu et al^110^ reported no statistically significant difference in incident ischemic heart disease or stroke in the vitamin D with calcium group compared with placebo; however, events were rare and estimates were imprecise.

VTE. No statistically significant differences in any VTE events (idiopathic or secondary deep vein thrombosis (DVT) or pulmonary embolus [PE]) in women taking vitamin D with calcium compared with placebo over 7 years (ARD, -0.16% (95% CI, -0.44% to 0.12%); HR, 0.92 [95% CI, 0.79 to 1.07]) were observed in the WHI CaD Trial.^117^ Similar findings were observed when study authors considered DVT and PE events individually. A statistically significant lower risk of idiopathic VTE in women taking vitamin D with calcium compared with placebo was observed (HR, 0.62; 95% CI, 0.42 to 0.92) but this finding was sensitive to whether VTE events occurring in participants taking hormone therapy were considered as idiopathic or secondary events. The HR would have been 0.82 (95% CI, 0.64 to 1.06) had VTE events in women on hormone therapy been considered idiopathic and not secondary events.

Heart failure. No statistically significant difference in heart failure hospitalizations was observed between the vitamin D with calcium group (2.0%) compared with placebo group (2.1%) (ARD, -0.11% [95% CI, -0.40% to 0.18%); HR, 0.95 [95% CI, 0.82 to 1.09]).^118^ In a subgroup analysis by baseline risk of heart failure, a statistically significant decrease in incident heart failure was seen for the low-risk subgroup (HR, 0.63 [95% CI, 0.46 to 0.87]) but not for the high-risk subgroup (HR, 1.06 [95% CI, 0.90 to 1.24)].

#### Cancer

Four RCTs examined the effect of supplementation with vitamin D alone,^72,^ ^77,^ ^119^ calcium alone,^108^ or vitamin D with calcium^71,^ ^96-98,^ ^113,^ ^121,^ ^122^ on incident cancer. Findings are summarized in Table 5.

##### Vitamin D Compared With Placebo: Study Characteristics

Two fair-quality RCTs (Trivedi et al^77^ and Komulainen et al^72^) examined the effect of vitamin D alone on cancer outcomes.^72,^ ^77,^ ^119^ Both were included in the prior review for the USPSTF^2^ for fracture outcomes, but only the trial by Trivedi et al^77^ was included in the synthesis of cancer outcomes.

Study characteristics have been previously described; briefly Trivedi et al evaluated 100,000 IU of oral vitamin D_3_ compared with placebo every 4 months over 5 years among 2,686 men and women ages 65 to 85 years in the United Kingdom; 24 percent of participants were women and 6 percent of participants reported a history of cancer, including skin cancer.^77^ Komulainen et al randomized 232 women age 52 to 6 1 years in Finland to 300 IU of oral vitamin D_3_ with 93 mg of elemental calcium daily or control (93 mg of elemental calcium daily only) and evaluated outcomes over a mean of 4.3 years.

Cancer outcomes included all incident cancers, all incident cancers excluding skin cancer, colon cancer, and respiratory cancer. Trivedi et al^77^ ascertained incident cancer from self-reported questionnaires and cause of death on death certificates, while Komulainen et al described malignancies as serious adverse events.^119^ Neither study described validation of cancer diagnoses by medical records or through clinical adjudicators.

We identified one good-quality RCT by Sanders et al^84^ and one poor-quality RCT by Glendenning et al,^87^ both conducted among women in Australia, for use in a sensitivity analysis. Sanders et al was excluded from our main analysis because 35 percent of the study participants had a history of fracture. This trial randomized 2,258 participants age 70 years and older to receive an annual dose of 500,000 IU of vitamin D_3_ or placebo over 3–5 years. Cancer outcomes were reported as adverse events.^84^ Glendenning et al was rated poor quality because of measurement bias and the short period of followup (9 months) may have resulted in ascertainment of prevalent rather than incident cancer. Participants were age 70 years and were randomized to oral 150,000 IU vitamin D_3_ at baseline, 3 months, and 6 months or placebo. Cancer diagnoses were self-reported in an adverse event diary.^87^

##### Vitamin D Compared With Placebo: Findings

Both included trials reported no statistically significant difference in the incidence of cancer between the placebo and vitamin D groups after 5 years. Trivedi et al reported incident cancer in 188 (14%) participants in the vitamin D group compared with 173 (13%) in the placebo group (ARD, 1.08% [95% CI, -1.50% to 3.66%; age-adjusted RR, 1.09 [95% CI, 0.86 to 1.36)]).^77^ Trivedi et al also reported no statistically significant difference in the incidence of colon cancer overall and no differences in effect between men and women for any of the reported cancer outcomes (Appendix D Table 3).^77^ Consistent with its younger study population, Komulainen et al reported a lower overall incidence of cancer: two cases (1.8%) in the vitamin D group and three cases (2.6%) in the placebo group (ARD, -0.82% [95% CI, -4.63% to 2.99%]; RR, 0.68 [95% CI, 0.12 to 4.02]).^119^ Findings from the studies used in sensitivity analysis (Sanders et al^84^ and Glendenning et al^87^) reported numeric but statistically nonsignificant decrease and increase in incidence, respectively.

##### Calcium Compared With Placebo: Study Characteristics

The RCT by Lappe et al described in a previous section examined the effect of calcium alone on cancer outcomes; it was rated as good quality for cancer outcomes.^108^ In this RCT, 733 postmenopausal women age 55 years or older in rural Nebraska were randomized to daily supplementation (either 1,400 mg calcium citrate or 1,500 mg of calcium carbonate) or placebo for 4 years. Women were excluded if they had a history of cancer within the prior 10 years. Incident cancers were a secondary end point in the trial; participants self-reported any cancer diagnoses at each study visit, and all reported cancers were verified with medical records. Investigators reported results for total nonskin cancers, breast cancer, and colon cancer.

We used the fair-quality study by Zhu & Prince et al previously described in a sensitivity analysis; it was not eligible for the main analysis because more than 20 percent of its study population had a history of fracture.^90,^ ^110^ Outcomes for self-reported total incident cancer, including and excluding skin cancer, were reported.^110^

##### Calcium Compared With Placebo: Findings

In the study by Lappe et al, 17 (3.8%) women who took calcium reported a nonskin cancer diagnosis compared with 20 (6.9%) women who took placebo (ARD, -3.12% [95% CI, -6.56% to 0.31%]; RR, 0.55 [95% CI, 0.29 to 1.03]).^108^The overall number of breast cancer cases and colon cancer cases was small; effect estimates were not statistically significant and were imprecise (Appendix D Table 3).^108^ The one RCT used in a sensitivity analysis reported a numeric but nonsignificant increase in incidence but estimates were very imprecise.^110^

##### Vitamin D With Calcium Compared With Placebo: Study Characteristics

One good-quality^108^ trial and two fair-quality trials^71,^ ^96-98,^ ^109,^ ^113,^ ^121,^ ^122^ evaluated the effect of vitamin D plus calcium supplementation on cancer outcomes. Two trials^71,^ ^108^ were included in the previous review for the USPSTF^2^; one^109^is new to this update.

Lappe et al^108^ evaluated 1,000 IU vitamin D_3_ with 1,400 or 1,500 mg of calcium daily and Lappe et al^109^ evaluated 2,000 IU vitamin D_3_ with 1,500 mg of calcium daily; both compared supplements with placebo over 4 years.^108,^ ^109^ The WHI CaD Trial, previously described, evaluated daily oral 400 IU vitamin D_3_ with 1,000 mg of calcium carbonate compared with placebo among 36,282 postmenopausal women age 50 to 79 years over 7 years.^71,^ ^96,^ ^98,^ ^113,^ ^121,^ ^122^ At baseline, 18 percent of women in the WHI CaD Trial had a family history of breast cancer and 16 percent had a family history of colorectal cancer. Eight percent of women were current smokers and 40 percent reported smoking in the past.^96^ All studies reported total, breast, and colon cancer and confirmed self-reported cancers by medical records. In addition, the WHI CaD Trial reported incident melanoma skin cancer and additional subgroup analyses among women without a history of cancer^122^ and among women with and without use of personal supplementation at baseline.^97^ Bolland et al also reported WHI subgroup analyses related to the personal use of supplements at baseline.^97^

The Zhu & Prince et al substudy, previously described, was also identified for use in a sensitivity analysis of vitamin D with calcium compared with placebo.^90,^ ^110^

##### Vitamin D With Calcium Compared With Placebo: Findings

Lappe et al^108^ reported statistically significant decreases in incident total nonskin cancers. In this study, 13 women (2.9%) who took vitamin D with calcium, compared with 20 (6.9%) who took placebo, developed incident nonskin cancer for an ARD of -4.03% (95% CI, -7.35% to -0.70%) and RR of 0.42 (95% CI, 0.21 to 0.83) over 4 years.^108^ The number of incident breast cancers and colon cancers was small and effect estimates were not significant and imprecise (Appendix D Table 3). These finding were not replicated in the Lappe et al^109^ study, which reported no significant differences in total, breast or colon cancer.^109^ In the WHI CaD Trial, 1,366 (7.5%) women had incident invasive cancer in the treatment group compared with 1,411 (7.8%) women in the placebo group (ARD, -0.28% [95% CI, -0.82% to 0.27%]; HR, 0.96 [95% CI, 0.89 to 1.04]).^98^ With respect to cancer types, the WHI CaD Trial reported no statistically significant differences between the supplementation and placebo groups for incident colorectal, breast, nonmelanoma skin cancer, or melanoma skin cancer (Appendix D Table 3).^121^ Pooled estimates from these three trials (39,213 participants) found no significant association between vitamin D with calcium and total cancer incidence (pooled RR, 0.73 [95% CI, 0.49 to 1.10], I^2^=75.8%; pooled ARD -1.48% [95% CI, -3.32% to 0.35%], I^2^=70.9%), breast cancer (pooled RR, 0.82 [95% CI, 0.56 to 1.19], I^2^=39.5%) or colon cancer (pooled RR, 1.07 [95% CI, 0.87 to 1.33], I^2^=0%) (Appendix F Figure 19 and 20).

The one study we used in sensitivity analysis reported a numeric but statistically nonsignificant decrease in incident cancer between the group who received vitamin D with calcium and the group who received placebo, but events were rare and estimates were imprecise (ARD, -6.57% [95% CI, -23.56% to 10.43%]; RR, 0.70 [95% CI, 0.28 to 1.79]).^110^

#### Subgroup Results

No studies of vitamin D alone or vitamin D with calcium reported subgroup findings by dose or dosing interval. As previously reported, one study of calcium alone (Reid et al ^92^) reported findings by dose. (600 mg calcium citrate or 1,200 mg calcium citrate versus placebo). No difference in all-cause mortality, CVD, or kidney stone incidence was observed for either dose compared with placebo though all estimates were very imprecise.

One study of vitamin D alone (Trivedi et al^77^ reported findings by sex. The overall RR for incident all-cause mortality was 0.90 (95% CI, 0.77 to 1.07) and was similar among women (RR 0.92 [95% CI, 0.54 to 1.55]) and men (RR 0.90 [95% CI, 0.76 to 1.07]). Similarly, this study reported no statistically significant effect on incident ischemic heart disease, cerebrovascular disease, or cancer among women or men, though all findings were imprecise (Appendix D Table 3).

Several subgroup analyses have been reported for vitamin D with calcium from the WHI CaD trial. In a 2011 publication using data from the WHI limited access dataset, Bolland et al^116^ reported a statistically significant interaction between treatment allocation and use or nonuse of personal calcium or vitamin D supplements at the time of randomization for the outcomes of clinical myocardial infarction (p=0.04) and for stroke (p=0.02). For clinical myocardial infarction, the HR comparing vitamin D and calcium-allocated group with the placebo group was 0.92 (95% CI, 0.75 to 1.13) among women who were users of supplements at baseline. Among women who were nonusers of supplements at baseline, the HR was 1.22 (95% CI, 1.00 to 1.50). For stroke, the HR was 0.83 (95% CI, 0.67 to 1.02) among users of supplements at baseline and 1.17 (95% CI, 0.95 to 1.44) among nonusers. These authors reported no statistically significant interaction for the outcomes of coronary revascularization or death from CHD from this subgroup analysis. In a 2013 publication, WHI investigators also reported on subgroup analyses related to CVD event. Among women not taking supplements at baseline, the HR for myocardial infarction was 1.11 (95% CI, 0.90 to 1.37) for women allocated to treatment, compared with control.^98^ Similar HRs were observed among baseline nonusers of supplements for CHD (HR, 1.03 [95% CI, 0.85 to 1.25]) and stroke (HR, 1.12 [95% CI, 0.90 to 1.39]). Differences in CVD outcome specification between the two subgroup analyses may explain the differences in findings.

With respect to cancer outcomes, Bolland et al reported statistically significant interactions between the CaD treatment allocation and use or nonuse of personal vitamin D or calcium supplementation at baseline for total incident cancer (p for interaction=0.003), invasive breast cancer (p for interaction=0.005), and invasive colorectal cancer (p for interaction=0.044).^97^ Overall, 57 percent of women reported no use of personal supplementation at baseline, and among these women, significantly fewer cases of incident total cancer and incident breast cancer occurred among those who received vitamin D with calcium compared with those who received placebo. For the women who reported supplement use at baseline, findings were similar to those main analysis in that no statistically significant differences between treatment and placebo groups were found.^97^ Findings were the same in a similar subgroup analysis subsequently reported by the WHI study authors.^98^

#### Other Adverse Events

Other adverse events reported by included studies are detailed in Appendix D Table 4. The most common adverse event reported was constipation. It was more common in treatment groups than placebo studies in some, but not all studies that reported this event. A few studies reported on serious adverse events other than those already discussed in KQ 2; these events were rare and were noted by study authors to be unrelated to study medication.