# 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and AHRQ Medical Officers developed the scope and KQs for this review. The analytic framework illustrates the KQs that guided the review (Figure 1).

Figure 1 Analytic Framework

† Measures of whole body calcium status do not exist; thus the indirect evidence pathway for calcium cannot be evaluated.

Analytic framework The framework begins on the left with the population of interest: generally healthy persons with no known disorders. To the right is an overarching arrow for the framework representing KQ1. It begins with the interventions of supplementation with vitamin D, alone or with calcium, on the left and ends with a box on the far right that represents the final health outcomes, fractures and fracture-related morbidity and mortality. A second horizontal arrow leads straight from the population of interest to the center of the framework, representing vitamin D status, and continues as a dotted arrow to the aforementioned final health outcomes box. A footnote at the bottom of the figure reads “measures of whole body calcium status do not exist; thus, the indirect evidence pathway for calcium cannot be evaluated.” From the arrow leading to intermediate outcomes, a third squiggly arrow descends to an oval circle with the text “Harms” to illustrate the focus of KQ2.

1. Does supplementation with vitamin D or calcium alone or vitamin D combined with calcium prevent fractures or reduce fracture-related morbidity and mortality? Do the benefits of supplementation vary by:
  a) dose or dosing interval?
  b) fracture type?
  c) subpopulation (including, but not limited to age, sex, or race/ethnicity)?
2. Are there harms of supplementation with vitamin D or calcium alone or vitamin D combined with calcium? Do the harms of supplementation vary by:
  a) dose or dosing interval?
  b) subpopulation (including, but not limited to age, sex, or race/ethnicity)?

In addition to our KQs, we also looked for evidence related to two contextual questions (CQs) relating to the association between vitamin D supplementation and changes in vitamin D serum levels, and the association between vitamin D serum levels and fracture outcomes. We do not show these questions in the analytic framework because they were not analyzed using the same systematic review process as the KQs. Findings related to the contextual questions are summarized in Appendix A.

## Data Sources and Searches

This update builds on the prior 2011 evidence review for the USPSTF,^2^ which itself was an update of a portion of a much larger AHRQ Evidence Report in support of NAM recommendations.^14,^ ^15^ The relationship among these evidence syntheses is depicted in Appendix B1.

We searched PubMed/MEDLINE, EMBASE, and the Cochrane Library for English-language articles. For the evaluation of vitamin D alone or vitamin D combined with calcium, we searched from January 1, 2011, through March 21, 2017, building on the literature published in the previous review for the USPSTF.^2^ For calcium alone, we searched from inception through March 21, 2017. We used Medical Subject Headings as search terms (when available) and keywords to describe relevant interventions, outcomes, and study designs. Complete search terms and limits are detailed in Appendix B2. We also searched the clinicaltrials.gov registry and the World Health Organization International Clinical Trials Registry Platform. To supplement the electronic database search, we screened relevant systematic reviews and reference lists of included articles. We conducted literature surveillance through December 31, 2017, using article alerts and targeted searches of relevant journals to identify major studies published in the interim that may affect conclusions.

## Study Selection

We developed inclusion and exclusion criteria for selecting studies based on populations, interventions, comparators, outcomes, timing, settings, and study designs; these are described in detail in Appendix B3. We included studies of unselected, community-dwelling adults with no known disorders of bone metabolism. We excluded studies that selected patients for enrollment based on low serum vitamin D levels or known deficiency (as defined by the study); known high risk of fracture or falls; prior history of osteoporotic fractures or prevalent fractures at baseline; and known low BMD, osteoporosis, or other medical conditions or medication use affecting bone metabolism. We included studies with up to 20 percent of such participants in our main analysis; studies with between 20 and 50 percent of such participants were considered in sensitivity analyses.

Eligible vitamin D interventions included oral or intramuscular vitamin D_2_ or vitamin D_3_ (at any dosage or frequency. Vitamin D metabolites (e.g., calcitriol) or synthetic analogues (e.g., doxercalciferol) designed for treatment of deficiency associated with medical conditions were not eligible for selection. Eligible calcium interventions included oral calcium salt preparations (e.g., carbonate, citrate, malate, lactate) at any dose and frequency. Vitamin D with calcium interventions were eligible if the vitamin D and calcium components were individually eligible. We selected studies for which the comparator groups were no treatment, placebo, or lower or higher dose vitamin D or calcium regimens. Studies of vitamin D with calcium vs calcium alone were considered as vitamin D alone interventions. We excluded studies where the intervention and comparator arms would not allow for the evaluation of the independent contribution of vitamin D or calcium to the effect, for example, when these supplements were taken in a multivitamin or used as part of a multicomponent intervention that also included other pharmacologic agents or environmental/behavioral interventions. For KQ 1, we required the intervention duration to have been at least 1 month prior to measurement of outcomes; no such restriction was used to select studies for KQ 2.

For KQ 1, we selected studies that reported incident fractures and fracture-related morbidity and mortality. We selected studies reporting fractures regardless of whether fracture outcomes were considered the primary reported outcome. For KQ 2, we selected studies that reported on several prespecified harms including all-cause mortality, symptomatic acute or chronic vitamin D or calcium toxicity, incident kidney stones, incident cancer, incident cardiovascular disease (including stroke and venous thromboembolism), as well as other harms or adverse events possibly attributed to supplementation.

RCTs were eligible for KQ 1 and KQ 2; prospective cohort and case-control study designs that were specifically designed to evaluate the use of vitamin D or calcium supplementation and that took care to adequately measure and control for nonsupplement sources (e.g., dietary, sun exposure) were also eligible for KQ 2. Systematic reviews using study selection criteria similar to this review were also eligible for both KQs. We excluded studies and articles that were not published in English, were not original research, or were conducted in countries other than those categorized as “very high” on the 2015 Human Development Index (as defined by the United Nations Human Development Programme).^63^

Two investigators independently reviewed titles and abstracts identified through the search. Those marked as potentially eligible by at least one reviewer were retrieved for full text review. Two reviewers independently reviewed full-text articles for eligibility using the study selection criteria. In addition, we reviewed studies included in the prior review for the USPSTF to confirm their eligibility, given scope changes for this update, mainly the exclusion of studies in institutionalized settings or studies where the majority of participants had a history of prior fracture.

## Quality Assessment and Data Abstraction

For each included study, one investigator abstracted relevant study characteristics (i.e., population, intervention, comparator,) and data for eligible outcomes onto a structured form. A second investigator reviewed all data for completeness and accuracy, and the principal investigator reviewed all abstracted information for consistency across included studies.

Two reviewers independently assessed each study’s quality. We used a risk of bias assessment adapted from the Cochrane Collaboration to individually assess each RCT on the following risk of bias domains: bias arising from selection or randomization; bias due to missing outcome data; bias due to departures from intended interventions; bias from measurement of outcomes; and bias from selective reporting of results.^64^ Observational studies were additionally evaluated for their risk of bias due to confounding or inadequate measurement of the exposure. Each reviewer independently assessed bias on each domain as “low,” “some concerns,” or “high,” and translated these assessments into an overall study quality rating using the predefined criteria developed by the USPSTF (Appendix B4), which uses study quality ratings of poor, fair, or good. Studies with at least one risk of bias domain rated as “high” were rated as poor quality. Studies with all domains assessed as “low” were rated as good quality. Studies with some concerns in some domains were generally rated as fair quality; however, studies with most domains rated as “some concerns” could also be rated as poor quality, if both reviewers concurred and provided justification. Studies reporting multiple outcomes may have been assigned different quality ratings for different outcomes. Disagreements in risk of bias domain assessments and study quality ratings were resolved with a third reviewer.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ in tabular and narrative formats by intervention: vitamin D alone, calcium alone, or vitamin D with calcium. We included studies in our main analysis that met all study selection criteria and that were fair or good quality; this included studies from the prior review that informed the USPSTF’s 2013 Recommendation that met the study selection criteria for this update. We also conducted sensitivity analyses using RCTs that were excluded for poor quality and for RCTs that were excluded because of mixed study populations (i.e., those with between 20 and 50 percent of the population having a history of prior fracture.)

We assessed whether a quantitative synthesis was appropriate by evaluating the number of studies available and the clinical and methodological heterogeneity present among available studies based on established guidance,^65^ which includes evaluating the similarities in study population, supplement type, dose, and frequency, and similarities in timing and specification of outcomes. When at least three independent and similar RCTs were available, we used random-effects models using the inverse-variance weighted method of DerSimonian and Laird to determine pooled effect estimates using Stata version 14 (College Station, TX).^66^ We assessed statistical heterogeneity with the chi squared statistic and the I^2^ statistic; an I^2^ between 0 and 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, and 50 to 90 percent may represent substantial heterogeneity.^67^ Because the inverse-variance method of DerSimonian and Laird may not perform well with small numbers of studies,^68^ we also calculated pooled estimates using the restricted maximum likelihood estimator. Because fracture and harm events were rare in many studies, we used both absolute risk differences (ARD) and relative risk ratios (RR) for assessing effects. We assessed the strength of evidence for each outcome based on the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews, which specifies the assessment of study limitations, directness, consistency, precision, and reporting bias for each intervention comparison and major outcome of interest.^69^

## Expert Review and Public Comment

The draft analytic framework, research questions, and study selection criteria were made available for public comment between March 27, 2016 and April 27, 2016. They were subsequently revised for a Final Research Plan posted on the USPSTF Web site.^70^ Four expert reviewers provided comments on the draft evidence report. Comments generally related to requests for additional clarification or detail. Most reviewers also offered comments related to the scope of the review; they expressed that the included population was too narrowly defined, resulting in limited applicability to primary care practice. The draft evidence report was made available for public comment between September 26, 2017, and October 26, 2017.

## USPSTF Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.