# Appendix G Summary of Trials in Progress

This appendix summarizes the details of seven ongoing trials of vitamin D supplementation.

The Finnish Vitamin D Trial (FIND) randomized men ages 65 or older and women ages 60 or older to one of three groups (daily 1,600 IU D_3_, daily 3,200 IU D_3_, or daily placebo) for 5 years.^192^ The originally planned sample size was 18,000, but due to difficulties with funding and recruitment, the current study size is 2,500 participants. This study, which will complete final data collection in June 2018, includes cancer and cardiovascular outcomes; fracture outcomes are not included as outcomes in its trial registry listing.

The Vitamin D and Omega-3 (VITAL) trial is a study of 25,874 U.S. men ages 50 years or older and women ages 55 years or older who were randomized to one of four groups (daily vitamin D _3_ 2,000 IU supplement with fish oil placebo, vitamin D3 placebo with fish oil supplement, vitamin D_3_ and fish oil supplements, or double placebo).^193,^ ^194^ The primary study outcomes are incident cardiovascular and cancer outcomes; fracture outcomes are also being collected.^195^ This 5-year study will complete final data collection in December 2020.

The D-Health trial is a parallel-group RCT among a population-based sample of community-dwelling adults between 60 and 84 years in Australia and is comparing 60,000 IU vitamin D_3_ monthly to placebo.^196^ The intervention duration and active study followup is planned for 5 years, with additional followup for an additional 5 years. The primary study outcome is all-cause mortality; secondary outcomes include total and colorectal cancer incidence. Fractures are a tertiary outcome will be ascertained through self-report in annual surveys. The planned sample size was 25,000; to date 21,315 participants are enrolled. The intervention will end in 2019, with additional followup planned through 2024.

The DO-Health trial is a 2 X 2 X 2 factorial design trial that recruited community-dwelling adults 70 years and over from 5 European countries.^197^ It is evaluating the individual and combined benefit of vitamin D3 (2,000 IU daily), omega-3 fatty acids, and a simple home exercise program. Five primary end-points are specified, including incident nonvertebral fractures confirmed with medical records or x-rays at 3 years. Incident total and hip fractures are secondary endpoints. The planned sample size was 2,152 and 2,159 participants are enrolled to date. The last data collection was scheduled for November 2017.

The Vitamin D and Longevity (VIDAL) Trial is a feasibility study in the UK that involves adults between age 65 and 84 years recruited from participating practices.^198^ Some practices are participating in a double-blind intervention comparing vitamin D_3_ (100,000 IU monthly) with placebo, while other practices are participating in an open-label intervention comparing vitamin D with placebo. This study will inform the design of a larger future trial assessing the impact of vitamin D supplementation on morbidity and mortality. In this feasibility trial, mortality and cancer incidence are the primary outcomes of interest. This trial is reported as ending in 2013, but we did not identify any published results.

The Vitamin D and Type 2 Diabetes (D2d) study includes 2,382 U.S. men and women ages 30 years and older at risk for diabetes; the study will evaluate whether 4,000 IU oral daily vitamin D_3_ delays the onset of type 2 diabetes. This study will collect and report fracture outcomes as adverse events; final data collection is projected to be completed in December 2018.^199^

The Vitamin D in Older People (VDOP) study is a single-center RCT in 375 community-dwelling adults over age 70 years in the United Kingdom to evaluate the impact of three oral doses of monthly vitamin D_3_ (12,000 IU; 24,000 IU; and 48,000 IU) BMD after 1 year.^200^ The study does not include a placebo group and information on clinical fractures during the study will be collected as a safety measure. This study finished recruiting in 2013; findings have been presented in conferences but have not been published to date.