# Appendix F Supplemental Results

Appendix F Figure 1 Impact of Vitamin D Alone vs. Placebo on Incident Hip Fracture, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; Cntl=control or placebo; d=day; IU=international units; m=month; n or N=number of participants; RD=risk difference; Suppl. = supplementation; UK=United Kingdom; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of vitamin D alone vs. placebo on incident hip fracture as estimated by absolute risk difference Appendix F Figure 1 displays a forest plot of the risk difference of developing incident hip fracture following vitamin D supplementation vs. placebo in five trials. Among the three trials included in the main analysis, the risk difference for developing hip fracture following treatment compared with placebo was -0.002 with a 95 percent confidence interval of -0.012 to 0.007 in Trivedi et al, 2003. The risk difference for developing hip fracture following treatment compared with placebo was -0.009 with a 95 percent confidence interval of -0.038 to 0.020 in Komulainen et al, 1998. The risk difference for developing hip fracture following treatment compared with placebo was 0.008 with a 95 percent confidence interval of -0.008 to 0.023 in Lips et al, 1996. Meta-analysis of these three trials resulted in a risk difference of -0.000 with a 95 percent confidence interval of -0.008 to 0.008 and a p-value of 0.405. Of the two trials included in the sensitivity analysis, the risk difference for developing hip fracture following treatment compared with placebo was 0.005 with a 95 percent confidence interval 0.000 to 0.009 in Smith et al, 2007. The risk difference for developing hip fracture following treatment compared with placebo was 0.003 with a 95 percent confidence interval -0.007 to 0.014 in Sanders et al, 2010. Meta-analysis of these two trials resulted in a risk difference of 0.004 with a 95 percent confidence interval of 0.000 to 0.008 and a p-value of 0.835. Meta-analysis of all five trials resulted in a risk difference of 0.004 with a 95 percent confidence interval of -0.000 to 0.007 and a p-value of 0.631.

Appendix F Figure 2 Impact of Vitamin D Alone vs. Placebo on Incident Hip Fracture, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; Cntl=control or placebo; IU=international units; m=month; n or N=number of participants; RR=relative risk ratio; Suppl. = supplementation; UK=United Kingdom; y=year.

Impact of vitamin D alone vs. placebo on incident hip fracture as estimated by relative risk ratio Appendix F Figure 2 displays a forest plot of the relative risk of developing incident hip fracture following vitamin D supplementation vs. placebo in five trials. Among the three trials included in the main analysis, the relative risk for developing hip fracture following treatment compared with placebo was 0.87 with a 95 percent confidence interval of 0.49 to 1.56 in Trivedi et al, 2003. The relative risk for developing hip fracture following treatment compared with placebo was 0.50 with a 95 percent confidence interval of 0.05 to 5.44 in Komulainen et al, 1998. The relative risk for developing hip fracture following treatment compared with placebo was 1.20 with a 95 percent confidence interval of 0.83 to 1.75 in Lips et al, 1996. Meta-analysis of these three trials resulted in a relative risk of 1.08 with a 95 percent confidence interval of 0.79 to 1.48 and a p-value of 0.536. Of the two trials included in the sensitivity analysis, the relative risk for developing hip fracture following treatment compared with placebo was 1.50 with a 95 percent confidence interval of 1.02 to 2.19 in Smith et al, 2007. The relative risk for developing hip fracture following treatment compared with placebo was 1.26 with a 95 percent confidence interval of 0.64 to 2.47 in Sanders et al, 2010. Meta-analysis of these two trials resulted in a relative risk of 1.43 with a 95 percent confidence interval of 1.03 to 2.00 and a p-value of 0.663. Meta-analysis of all five trials resulted in a relative risk of 1.24 with a 95 percent confidence interval of 0.98 to 1.55 and a p-value of 0.570.

Appendix F Figure 3 Impact of Vitamin D Alone vs. Placebo on Incident Nonvertebral Fracture, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; Cntl=control or placebo; d=day; IU=international units; n or N=number of participants; RD=risk differ ence; UK=United Kingdom; US=United States; Vit D=vitamin D; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of vitamin D alone vs. placebo on incident nonvertebral fracture as measured by absolute risk difference Appendix F Figure 3 displays a forest plot of the risk difference of developing incident nonvertebral fracture following vitamin D supplementation vs. placebo in five trials. Of the two trials included in the main analysis, the risk difference for developing nonvertebral fracture following treatment compared with placebo was -0.034 with a 95 percent confidence interval of -0.116 to 0.047 in Komulainen et al, 1998. The risk difference for developing nonvertebral fracture following treatment compared with placebo was 0.008 with a 95 percent confidence interval of -0.005 to 0.020 in Khaw et al, 2017. Meta-analysis of these two trials resulted in a risk difference of 0.006 with a 95 percent confidence interval of -0.010 to 0.022 and a p-value of 0.310. Among the three trials included in the sensitivity analysis, the risk difference for developing nonvertebral fracture following treatment compared with placebo was 0.032 with a 95 percent confidence interval -0.037 to 0.101 in Peacock et al, 2000. The risk difference for developing nonvertebral fracture following treatment compared with placebo was 0.006 with a 95 percent confidence interval of -0.004 to 0.015 in Smith et al, 2007. The risk difference for developing nonvertebral fracture following treatment compared with placebo was 0.020 with a 95 percent confidence interval -0.005 to 0.045 in Sanders et al, 2010. Meta-analysis of these three trials resulted in a risk difference of 0.008 with a 95 percent confidence interval of -0.001 to 0.017 and a p-value of 0.440. Meta-analysis of all five trials resulted in a risk difference of 0.007 with a 95 percent confidence interval of 0.000 to 0.015 and a p-value of 0.618.

Appendix F Figure 4 Impact of Vitamin D Alone vs. Placebo on Incident Nonvertebral Fracture, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; Cntl=control or placebo; n or N=number of participants; RR=relative risk ratio; UK=United Kingdom; US=United States; Vit D=vitamin D; y=year.

Impact of vitamin D alone vs. placebo on incident nonvertebral fracture as measured by relative risk ratio Appendix F Figure 4 displays a forest plot of the relative risk of developing incident nonvertebral fracture following vitamin D supplementation vs. placebo in five trials. Of the two trials included in the main analysis, the relative risk for developing nonvertebral fracture following treatment compared with placebo was 0.73 with a 95 percent confidence interval of 0.35 to 1.53 in Komulainen et al, 1998. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.14 with a 95 percent confidence interval of 0.91 to 1.43 in Khaw et al, 2017. Meta-analysis of these two trials resulted in a relative risk of 1.06 with a 95 percent confidence interval of 0.76 to 1.47 and a p-value of 0.257. Among the three trials included in the sensitivity analysis, the relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.43 with a 95 percent confidence interval 0.66 to 3.11 in Peacock et al, 2000. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.09 with a 95 percent confidence interval of 0.93 to 1.28 in Smith et al, 2007. The relative risk for developing nonvertebral fracture following treatment compared with placebo was 1.22 with a 95 percent confidence interval 0.95 to 1.57 in Sanders et al, 2010. Meta-analysis of these three trials resulted in a relative risk of 1.14 with a 95 percent confidence interval of 1.00 to 1.30 and a p-value of 0.640. Meta-analysis of all five trials resulted in a relative risk of 1.13 with a 95 percent confidence interval of 1.01 to 1.26 and a p-value of 0.692.

Appendix F Figure 5 Impact of Calcium Alone vs. Placebo on Incident Total Fracture, as Measured by Absolute Risk Difference, Sensitivity Analysis

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: Calc.=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RD= risk difference; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of calcium alone vs. placebo on incident total fracture as measured by absolute risk difference, sensitivity analysis Appendix F Figure 5 displays a forest plot of the risk difference of developing incident total fracture following calcium supplementation vs. placebo in the four trials used in the sensitivity analysis. The risk difference for developing total fracture following calcium supplementation vs. placebo was -0.049 with a 95 percent confidence interval of -0.131 to 0.033 in Reid et al, 1995. The risk difference for developing total fracture following calcium supplementation vs. placebo was -0.016 with a 95 percent confidence interval of -0.054 to 0.022 in Reid et al, 2006. The risk difference for developing total fracture following calcium supplementation vs. placebo was -0.033 with a 95 percent confidence interval of -0.090 to 0.023 in Reid et al, 2008. The risk difference for developing total fracture following calcium supplementation vs. placebo was -0.022 with a 95 percent confidence interval of -0.060 to 0.016 in Prince et al, 2006. Meta-analysis of these four trials resulted in a risk difference of -0.024 with a confidence interval of -0.047 to -0.001 and a p-value of 0.877.

Appendix F Figure 6 Impact of Calcium Alone vs. Placebo on Incident Total Fracture, as Measured by Relative Risk Ratio, Sensitivity Analysis

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: Calc.=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RR=relative risk rat io; y=year.

Impact of calcium alone vs. placebo on incident total fracture as measured by relative risk ratio, sensitivity analysis Appendix F Figure 6 displays a forest plot of the relative risk of developing incident total fracture following calcium supplementation vs. placebo in the four trials used in the sensitivity analysis. The relative risk for developing total fracture following calcium supplementation vs. placebo was 0.40 with a 95 percent confidence interval of 0.08 to 1.98 in Reid et al, 1995. The relative risk for developing total fracture following calcium supplementation vs. placebo was 0.91 with a 95 percent confidence interval of 0.73 to 1.14 in Reid et al, 2006. The relative risk for developing total fracture following calcium supplementation vs. placebo was 0.87 with a 95 percent confidence interval of 0.69 to 1.10 in Prince et al, 2006. The relative risk for developing total fracture following calcium supplementation vs. placebo was 0.56 with a 95 percent confidence interval of 0.22 to 1.40 in Reid et al, 2008. Meta-analysis of these four trials resulted in a relative risk of 0.87 with a confidence interval of 0.74 to 1.02 and a p-value of 0.582.

Appendix F Figure 7 Impact of Calcium Alone on Incident Nonvertebral Fracture, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: Calc.=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RD= risk difference; US=United States; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of calcium alone on incident nonvertebral fracture as measured by absolute risk difference Appendix F Figure 7 displays a forest plot of the risk difference of developing incident nonvertebral fracture following calcium supplementation vs. placebo in three trials. Based on the best available study, Riggs et al, 1998, the main analysis resulted in a risk difference of -0.010 with a 95 percent confidence interval of -0.086 to 0.066. Of the two trials used in the sensitivity analysis, the risk difference for developing incident nonvertebral fracture following calcium supplementation vs. placebo was 0.013 with a 95 percent confidence interval of -0.053 to 0.079 in Peacock et al, 2000. The risk difference for developing incident nonvertebral fracture following calcium supplementation vs. placebo was -0.015 with a 95 percent confidence interval of -0.049 to 0.018 in Prince et al, 2006. Meta-analysis of these two trials resulted in a risk difference of -0.009 with a 95 percent confidence interval of -0.039 to 0.021 and a p-value of 0.451. Meta-analysis of all three trials resulted in a risk difference of -0.009 with a 95 percent confidence interval of -0.037 to 0.018 and a p-value of 0.753.

Appendix F Figure 8 Impact of Calcium Alone on Incident Nonvertebral Fracture, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: Calc.=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RR=relative risk rat io; US=United States; y=year.

Impact of calcium alone on incident nonvertebral fracture as measured by relative risk ratio Appendix F Figure 8 displays a forest plot of the relative risk of developing incident nonvertebral fracture following calcium supplementation vs. placebo in three trials. Based on the best available study, Riggs et al, 1998, the main analysis resulted in a relative risk of 0.90 with a 95 percent confidence interval of 0.41 to 1.96. Of the two trials used in the sensitivity analysis, the relative risk for developing incident nonvertebral fracture following calcium supplementation vs. placebo was 1.18 with a 95 percent confidence interval of 0.52 to 2.68 in Peacock et al, 2000. The relative risk for developing incident nonvertebral fracture following calcium supplementation vs. placebo was 0.88 with a 95 percent confidence interval of 0.67 to 1.16 in Prince et al, 2006. Meta-analysis of these two trials resulted in a relative risk of 0.91 with a 95 percent confidence interval of 0.70 to 1.18 and a p-value of 0.514. Meta-analysis of all three trials resulted in a relative risk of 0.91 with a 95 percent confidence interval of 0.71 to 1.16 and a p-value of 0.753.

Appendix F Figure 9 Impact of Calcium Alone on Prevention of Morphometric Vertebral Fractures, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

‡ The total N with available data for this outcome was different from the other outcomes analyzed in this study.

Abbreviations: Calc.=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RD= risk difference; US=United States; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of calcium alone on prevention of morphometric vertebral fractures as measured by absolute risk difference Appendix F Figure 9 displays a forest plot of the risk difference of developing incident vertebral (morphometric) fracture following calcium supplementation vs. placebo in four trials. Of the two trials used in the main analysis, the risk difference for developing morphometric vertebral fracture following calcium supplementation vs. placebo was 0.073 with a 95 percent confidence interval of -0.098 to 0.244 in Recker et al, 1996. The risk difference for developing morphometric vertebral fracture following calcium supplementation vs. placebo was -0.010 with a 95 percent confidence interval of -0.076 to 0.056 in Riggs et al, 1998. Meta-analysis of these two trials resulted in a risk difference of 0.001 with a 95 percent confidence interval of -0.061 to 0.063 and a p-value of 0.326. Of the two trials used in the sensitivity analysis, the risk difference for developing morphometric vertebral fracture following calcium supplementation vs. placebo was 0.000 with a 95 percent confidence interval of -0.060 to 0.060 in Ruml et al, 1999. The risk difference for developing morphometric vertebral fracture following calcium supplementation vs. placebo was -0.009 with a 95 percent confidence interval of -0.049 to 0.032 in Prince et al, 2006. Meta-analysis of these two trials resulted in a risk difference of -0.006 with a 95 percent confidence interval of -0.040 to 0.028 and a p-value of 0.795. Meta-analysis of all four trials resulted in a risk difference of -0.004 with a 95 percent confidence interval of -0.034 to 0.025.

Appendix F Figure 10 Impact of Calcium Alone on Prevention of Morphometric Vertebral Fractures, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

† The total N with available data for this outcome was different from the other outcomes analyzed in this study.

‡ This study is excluded from the meta-analysis because of 0 events in both groups.

Abbreviations: Calc=calcium; CI=confidence interval; Cntl=placebo; d=day; mg=milligram; n or N=number of participants; RR=relative risk ratio; US=United States; y=year.

Impact of calcium alone on prevention of morphometric vertebral fractures as measured by relative risk ratio Appendix F Figure 10 displays a forest plot of the relative risk of developing incident vertebral (morphometric) fracture following calcium supplementation vs. placebo in four trials. Of the two trials used in the main analysis, the relative risk for developing morphometric vertebral fracture following calcium supplementation vs. placebo was 1.34 with a 95 percent confidence interval of 0.68 to 2.64 in Recker et al, 1996. The relative risk for developing morphometric vertebral fracture following calcium supplementation vs. placebo was 0.87 with a 95 percent confidence interval of 0.35 to 2.19 in Riggs et al, 1998. Meta-analysis of these two trials resulted in a relative risk of 1.15 with a 95 percent confidence interval of 0.67 to 1.99 and a p-value of 0.460. In the sensitivity analysis, the relative risk for developing morphometric vertebral fracture following calcium supplementation vs. placebo was 0.92 with a 95 percent confidence interval of -0.63 to 1.35 in Prince et al, 2006. Ruml et al, 1999 was excluded from the sensitivity analysis but included in the figure as reporting 0 incident morphometric vertebral fracture in both study arm. Meta-analysis of all three included trials resulted in a relative risk of 0.99 with a 95 percent confidence interval of 0.73 to 1.36 and a p-value of 0.615.

Appendix F Figure 11 Impact of Vitamin D Alone on All-Cause Mortality, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; d=day; IU=international units; m=month; n or N=number of participants; RD= risk difference; UK=United Kingdom; Vit D=vitamin D; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of vitamin D alone on all-cause mortality as measured by absolute risk difference Appendix F Figure 11 displays a forest plot of the absolute risk difference for all-cause mortality following vitamin D supplementation vs. placebo in six trials. Among the four trials included in the main analysis, the risk difference for all-cause mortality following treatment compared with placebo was -0.018 with a 95 percent confidence interval of -0.046 to 0.0011 in Trivedi et al, 2003. The risk difference for all-cause mortality following treatment compared with placebo was -0.003 with a 95 percent confidence interval of -0.012 to 0.005 in the ViDA trial (reported in Khaw et al, 2017 and Scragg et al, 2017). The risk difference for all-cause mortality following treatment compared with placebo was -0.009 with a 95 percent confidence interval of -0.033 to 0.015 in Komulainen et al, 1998. The risk difference for all-cause mortality following treatment compared with placebo was -0.019 with a 95 percent confidence interval of -0.052 to 0.013 in Lips et al, 1996. Meta-analysis of these four trials resulted in a risk difference of -0.007 with a 95 percent confidence interval of -0.018 to 0.003 and a p-value of 0.292. Of the two trials included in the sensitivity analysis, the risk difference for all-cause mortality following treatment compared with placebo was -0.030 with a 95 percent confidence interval 0.067 to 0.008 in Hin et al, 2017. The risk difference for all-cause mortality following treatment compared with placebo was- 0.006 with a 95 percent confidence interval -0.022 to 0.009 in Sanders et al, 2010. Meta-analysis of these two trials resulted in a risk difference of -0.012 with a 95 percent confidence interval of -0.031 to 0.008 and a p-value of 0.257. Meta-analysis of all six trials resulted in a risk difference of -0.006 with a 95 percent confidence interval of -0.013 to 0.000 and a p-value of 0.462

Appendix F Figure 12 Impact of Vitamin D Alone on All-Cause Mortality, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

Abbreviations: CI=confidence interval; d=day; IU=international units; m=month; n or N=number of participants; RR=relative risk ratio; UK=United Kingdom; Vit D=vitamin D; y=year.

Impact of vitamin D alone on all-cause mortality as measured by relative risk ratio Appendix F Figure 12 displays a forest plot of the relative risk ratio for all-cause mortality following vitamin D supplementation vs. placebo in six trials. Among the four trials included in the main analysis, the relative risk for all-cause mortality following treatment compared with placebo was 0.90 with a 95 percent confidence interval of 0.77 to 1.07 in Trivedi et al, 2003. The relative risk for all-cause mortality following treatment compared with placebo was 0.87 with a 95 percent confidence interval of 0.61 to 1.24 in the ViDA trial (reported in Khaw et al, 2017 and Scragg et al, 2017). The relative risk for all-cause mortality following treatment compared with placebo was 0.34 with a 95 percent confidence interval of 0.01 to 8.31 in Komulainen et al, 1998. The relative risk for all-cause mortality following treatment compared with placebo was 0.92 with a 95 percent confidence interval of 0.80 to 1.06 in Lips et al, 1996. Meta-analysis of these four trials resulted in a relative risk of 0.91 with a 95 percent confidence interval of 0.82 to 1.01 and a p-value of 0.932. Of the two trials included in the sensitivity analysis, the relative risk for all-cause mortality following treatment compared with placebo was 0.14 with a 95 percent confidence interval 0.01 to 2.70 in Hin et al, 2017. The relative risk for all-cause mortality following treatment compared with placebo was- 0.85 with a 95 percent confidence interval 0.56 to 1.28 in Sanders et al, 2010. Meta-analysis of these two trials resulted in a relative risk of 0.64 with a 95 percent confidence interval of 0.18 to 2.30 and a p-value of 0.237. Meta-analysis of all six trials resulted in a relative risk of 0.90 with a 95 percent confidence interval of 0.82 to 1.00 and a p-value of 0.840.

Appendix F Figure 13 Impact of Calcium Alone on All-Cause Mortality, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

† The active comparator for this analysis is the combined 600 mgand 1,200 mg calcium study groups.

Abbreviations: Calc=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RD= risk difference; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of calcium alone on all-cause mortality as measured by absolute risk difference Appendix F Figure 13 displays a forest plot of the absolute risk difference for all-cause mortality following calcium supplementation vs. placebo in three trials. Based on the best available study, Reid et al, 2008, the main analysis resulted in a risk difference of -0.000 with a 95 percent confidence interval of -0.024 to 0.025. Of the two trials included in the sensitivity analysis, the risk difference for all-cause mortality following treatment compared with placebo was 0.007 with a 95 percent confidence interval -0.013 to 0.028 in Reid et al, 2006. The risk difference for all-cause mortality following treatment compared with placebo was -0.012 with a 95 percent confidence interval --0.021 to 0.017 in Prince et al, 2006. Meta-analysis of these two trials resulted in a risk difference of -0.002 with a 95 percent confidence interval of -0.021 to 0.017 and a p-value of 0.199. Meta-analysis of all six trials resulted in a risk difference of -0.002 with a 95 percent confidence interval of -0.014 to 0.011 and a p-value of 0.429.

Appendix F Figure 14 Impact of Calcium Alone on All-Cause Mortality, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

† The active comparator for this analysis is the combined 600 mgand 1,200 mg calcium study groups.

Abbreviations: Calc=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RR=relative risk ratio; y=year.

Impact of calcium alone on all-cause mortality as measured by relative risk ratio Appendix F Figure 14 displays a forest plot of the relative risk ratio for all-cause mortality following calcium supplementation vs. placebo in three trials. Based on the best available study, Reid et al, 2008, the main analysis resulted in a relative risk of 1.01 with a 95 percent confidence interval of 0.09 to 11.06. Of the two trials included in the sensitivity analysis, the relative risk for all-cause mortality following treatment compared with placebo was 1.18 with a 95 percent confidence interval 0.73 to 1.92 in Reid et al, 2006. The relative risk for all-cause mortality following treatment compared with placebo was 0.76 with a 95 percent confidence interval 0.48 to 1.22 in Prince et al, 2006. Meta-analysis of these two trials resulted in a relative risk of 0.95 with a 95 percent confidence interval of 0.62 to 1.46 and a p-value of 0.204. Meta-analysis of all six trials resulted in a relative risk of 0.95 with a 95 percent confidence interval of 0.68 to 1.32 and a p-value of 0.445.

Appendix F Figure 15 Impact of Calcium Alone on Incident Kidney Stones, as Measured by Absolute Risk Difference

* Represents N analyzed, which may differ from the N randomized in some studies.

† The active comparator for this analysis is the combined 600 mg and 1,200 mg calcium study groups.

Abbreviations: Calc=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RD= risk difference; US=United States; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of calcium alone on incident kidney stones, as measured by absolute risk difference Appendix F Figure 15 displays a forest plot of the risk difference of developing incident kidney stones following calcium supplementation vs. placebo in eight trials. Among the three trials included in the main analysis, the risk difference for developing kidney stones following treatment compared with placebo was -0.003 with a 95 percent confidence interval of -0.007 to 0.013 in Lappe et al, 2007. The risk difference for developing kidney stones following treatment compared with placebo was -0.009 with a 95 percent confidence interval of -0.032 to 0.015 in Riggs et al, 1998. The risk difference for developing kidney stones following treatment compared with placebo was -0.010 with a 95 percent confidence interval of -0.035 to 0.015 in Reid et al, 2008. Meta-analysis of these three trials resulted in a risk difference of -0.000 with a 95 percent confidence interval of -0.009 to 0.009 and a p-value of 0.421. Among the five trials included in the sensitivity analysis, the risk difference for developing kidney stones following treatment compared with placebo was -0.003 with a 95 percent confidence interval of -0.009 to 0.004 in Reid et al, 2006. The risk difference for developing kidney stones following treatment compared with placebo was 0.016 with a 95 percent confidence interval of -0.028 to 0.061 in Reid et al, 1995. The risk difference for developing kidney stones following treatment compared with placebo was 0.000 with a 95 percent confidence interval of -0.039 to 0.039 in Recker et al, 1996. The risk difference for developing kidney stones following treatment compared with placebo was 0.000 with a 95 percent confidence interval of -0.005 to 0.005 in Prince et al, 2006. The risk difference for developing kidney stones following treatment compared with placebo was 0.008 with a 95 percent confidence interval of -0.014 to 0.030 in Peacock et al, 2000. Meta-analysis of these five trials resulted in a risk difference of -0.001 with a 95 percent confidence interval of -0.005 to 0.003 and a p-value of 0.789. Meta-analysis of all eight trials resulted in a risk difference of -0.001 with a 95 percent confidence interval of -0.004 to 0.003 and a p-value of 0.869.

Appendix F Figure 16 Impact of Calcium Alone on Incident Kidney Stones, as Measured by Relative Risk Ratio

* Represents N analyzed, which may differ from the N randomized in some studies.

† The active comparator for this analysis is the combined 600 nig and 1,200 mg calcium study groups.

Abbreviations: Calc=calcium; CI=confidence interval: d=day; mg=milligrams; n or N=numher of participants; RR=relative risk ratio; US=United States; y=year.

Impact of calcium alone on incident kidney stones as measured by relative risk ratio Appendix F Figure 16 displays a forest plot of the relative risk of developing incident kidney stones following calcium supplementation vs. placebo in eight trials. Among the three trials included in the main analysis, the relative risk for developing kidney stones following treatment compared with placebo was 1.94 with a 95 percent confidence interval of 0.20 to 18.57 in Lappe et al, 2007. The relative risk for developing kidney stones following treatment compared with placebo was 0.33 with a 95 percent confidence interval of 0.01 to 7.97 in Riggs et al, 1998. The relative risk for developing kidney stones following treatment compared with placebo was 0.17 with a 95 percent confidence interval of 0.01 to 4.22 in Reid et al, 2008. Meta-analysis of these three trials resulted in a relative risk of 0.68 with a 95 percent confidence interval of 0.14 to 3.36 and a p-value of 0.420. Among the five trials included in the sensitivity analysis, the relative risk for developing kidney stones following treatment compared with placebo was 0.50 with a 95 percent confidence interval of 0.09 to 2.75 in Reid et al, 2006. The relative risk for developing kidney stones following treatment compared with placebo was 3.00 with a 95 percent confidence interval of 0.12 to 72.23 in Reid et al, 1995. The relative risk for developing kidney stones following treatment compared with placebo was 1.00 with a 95 percent confidence interval of 0.14 to 7.06 in Prince et al, 2006. The relative risk for developing kidney stones following treatment compared with placebo was 3.12 with a 95 percent confidence interval of 0.13 to 75.87 in Peacock et al, 2000. Recker et al, 1996 was excluded from the meta-analysis but included in the figure as reporting 0 events in both study arms. Meta-analysis of the four included trials resulted in a relative risk of 0.98 with a 95 percent confidence interval of 0.32 to 2.98 and a p-value of 0.665. Meta-analysis of all seven included trials resulted in a relative risk of 0.87 with a 95 percent confidence interval of 0.35 to 2.16 and a p-value of 0.752.

Appendix F Figure 17 Impact of Vitamin D With Calcium on Incident Kidney Stones, as Measured by Absolute Risk Difference

Abbreviations: Calc.=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RD= risk difference; US=United St ates; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of vitamin D with calcium on incident kidney stones as measured by absolute risk difference Appendix F Figure 17 displays a forest plot of the risk difference of developing incident kidney stones following vitamin D and calcium combined supplementation vs. placebo in three trials. The risk difference for developing kidney stones following treatment compared with placebo was -0.001 with a 95 percent confidence interval of -0.009 to 0.007 in Lappe et al, 2007. The risk difference for developing kidney stones following treatment compared with placebo was 0.005 with a 95 percent confidence interval of -0.004 to 0.014 in Lappe et al, 2017. The risk difference for developing kidney stones following treatment compared with placebo was 0.004 with a 95 percent confidence interval of 0.001 to 0.007 in the WHI trial. Meta-analysis of these three trials resulted in a risk difference of 0.003 with a 95 percent confidence interval of 0.001 to 0.006 and a p-value of 0.461.

Appendix F Figure 18 Impact of Vitamin D With Calcium on Incident Kidney Stones, as Measured by Relative Risk Ratio

Abbreviations: Calc.=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RR=relative risk ratio; US=United States; y=year.

Impact of vitamin D with calcium on incident kidney stones as measured by relative risk ratios Appendix F Figure 18 displays a forest plot of the relative risk ratio of developing incident kidney stones following vitamin D and calcium combined supplementation vs. placebo in three trials. The relative ratio for developing kidney stones following treatment compared with placebo was 0.65 with a 95 percent confidence interval of 0.04 to 10.28 in Lappe et al, 2007. The relative risk for developing kidney stones following treatment compared with placebo was 1.59 with a 95 percent confidence interval of 0.72 to 3.49 in Lappe et al, 2017. The risk difference for developing kidney stones following treatment compared with placebo was 1.17 with a 95 percent confidence interval of 1.03 to 1.34 in the WHI trial. Meta-analysis of these three trials resulted in a risk difference of 1.18 with a 95 percent confidence interval of 1.04 to 1.35 and a p-value of 0.691.

Appendix F Figure 19 Impact of Vitamin D With Calcium on Incident Cancer, as Measured by Absolute Risk Difference

Abbreviations: Calc.=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RD= risk difference; US=United St ates; y=year.

Note: Risk difference estimates in this forest plot are differences in proportions; multiply by 100 to obtain the percentage incidence. For example, -0.0081 is a risk decrease of 0.81%.

Impact of vitamin D with calcium on incident cancer, as measured by absolute risk difference Appendix F Figure 19 displays a forest plot of the risk difference of developing incident cancer, by type, following vitamin D and calcium combined supplementation vs. placebo in three trials. The risk difference for developing total (non-skin) cancer following treatment compared with placebo was -0.00 with a 95 percent confidence interval of -0.01 to 0.00 in the WHI trial. The risk difference for developing total (non-skin) cancer following treatment compared with placebo was -0.04 with a 95 percent confidence interval of -0.07 to -0.01 in Lappe et al, 2007. The risk difference for developing total (non-skin) cancer following treatment compared with placebo was -0.02 with a 95 percent confidence interval of -0.04 to 0.00 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a risk difference of -0.01 with a 95 percent confidence interval of -0.03 to 0.00 and a p-value of 0.032. The risk difference for developing colon cancer following treatment compared with placebo was 0.00 with a 95 percent confidence interval of -0.00 to 0.00 in the WHI trial. The risk difference for developing colon cancer following treatment compared with placebo was -0.00 with a 95 percent confidence interval of -0.02 to 0.01 in Lappe et al, 2007. The risk difference for developing colon cancer following treatment compared with placebo was -0.00 with a 95 percent confidence interval of -0.01 to 0.01 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a risk difference of 0.00 with a 95 percent confidence interval of -0.00 to 0.00 and a p-value of 0.592. The risk difference for developing breast cancer following treatment compared with placebo was -0.00 with a 95 percent confidence interval of -0.00 to 0.00 in the WHI trial. The risk difference for developing breast cancer following treatment compared with placebo was -0.02 with a 95 percent confidence interval of -0.04 to 0.00 in Lappe et al, 2007. The risk difference for developing breast cancer following treatment compared with placebo was -0.01 with a 95 percent confidence interval of -0.02 to 0.00 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a risk difference of -0.00 with a 95 percent confidence interval of -0.01 to 0.00 and a p-value of 0.259.

Appendix F Figure 20 Impact of Vitamin D With Calcium on Incident Cancer, as Measured by Relative Risk Ratio

Abbreviations: Calc.=calcium; CI=confidence interval; d=day; mg=milligrams; n or N=number of participants; RR=relative risk ratio; US=United States; y=year.

Impact of vitamin D with calcium on incident cancer, as measured by relative risk ratio Appendix F Figure 20 displays a forest plot of the relative risk of developing incident cancer, by type, following vitamin D and calcium combined supplementation vs. placebo in three trials. The relative risk for developing total (non-skin) cancer following treatment compared with placebo was 0.96 with a 95 percent confidence interval of 0.90 to 1.04 in the WHI trial. The relative risk for developing total (non-skin) cancer following treatment compared with placebo was 0.42 with a 95 percent confidence interval of 0.21 to 0.83 in Lappe et al, 2007. The relative risk for developing total (non-skin) cancer following treatment compared with placebo was 0.70 with a 95 percent confidence interval of 0.48 to 1.01 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a relative risk of 0.73 with a 95 percent confidence interval of 0.49 to 1.10 and a p-value of 0.016. The relative risk for developing colon cancer following treatment compared with placebo was 1.09 with a 95 percent confidence interval of 0.87 to 1.35 in the WHI trial. The relative risk for developing colon cancer following treatment compared with placebo was 0.32 with a 95 percent confidence interval of 0.03 to 3.54 in Lappe et al, 2007. The relative risk for developing colon cancer following treatment compared with placebo was 0.99 with a 95 percent confidence interval of 0.25 to 3.96 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a relative risk of 1.07 with a 95 percent confidence interval of 0.87 to 1.33 and a p-value of 0.610. The relative risk for developing breast cancer following treatment compared with placebo was 0.96 with a 95 percent confidence interval of 0.86 to 1.08 in the WHI trial. The relative risk for developing breast cancer following treatment compared with placebo was 0.40 with a 95 percent confidence interval of 0.13 to 1.22 in Lappe et al, 2007. The relative risk for developing breast cancer following treatment compared with placebo was 0.69 with a 95 percent confidence interval of 0.37 to 1.30 in Lappe et al, 2017. Meta-analysis of these three trials resulted in a relative risk of -0.82 with a 95 percent confidence interval of 0.56 to 1.19 and a p-value of 0.191.