# Appendix E Quality Ratings

Appendix E Table 1 Quality Ratings for RCTS, Overall Rating: Part 1

Author, Year, Trial Name | Overall Quality Rating^*^ | Overall Rationale for Quality Rating | Was method of randomization adequate? | Was allocation concealment adequate? | Were group characteristics balanced at baseline? | Bias arising from randomization or selection? | Comments
Aloia et al, 2005^114^ | Poor | High risk of bias because of high attrition with rare outcome and no harm outcome specification/ascertainment information; further, some concern for contamination due to varying calcium cointervention received by both study groups. | Yes | No information | Yes | Low | None
Cherniack et al, 2011^119^ | Poor | High risk of bias for harms outcomes due no information on specification/ascertainment of harms and inadequate duration of follow up. Also, high risk of bias due to varying calcium cointervention that some participants in each study group received. | Yes | Yes | Yes | Low | None
Dawson-Hughes et al, 1997^74^ | Fair | Some concerns over selection of participants because of lack of information about randomization and allocation concealment and fidelity to intended intervention as only modest adherence at final follow up. | No information | No information | Yes | Uncertain because no information | No information about randomization or allocation concealment.
Glendenning et al, 2012^86^ | Poor | High risk of bias for measurement of both fractures (self-reported) and harms and inadequate duration of follow up. | Yes | Yes | Probably yes | Low | Higher proportion of participants with a prior history of falls in the treatment group; this was accounted for in the analysis.
Hin et al, 2017^110^ | Fair for all-cause mortality, Poor for others | Some concerns about randomization and harm specification and ascertainment. | Yes | Yes | Probably no | Some concerns | 4,000 IU group had higher prevalence of existing heart disease than other two groups.
Khaw, Scragg et al, 2017^77,^ ^78^ | Good | Low risk of bias across all domains. | Yes | Yes | Yes | Low | None
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Fair | Some concerns for bias due to lack of masking and minimal information on harms outcomes specification/ascertainment (unclear whether based on self-report or clinically validated). | Yes | Yes | Yes | Low | None
Lappe et al, 2007^107^ | Good for cancer; fair for kidney stones | Low risk of bias across all domains for the cancer outcomes, some concerns in measurement domain for kidney stone outcome. | Yes | No information | Probably yes | Low | Allocation concealment NR.
Lappe et al, 2017^108^ | Fair | Some concerns related to departures from intended intervention and modest adherence. | Yes | Yes | Yes | Low
Larsen et al, 2004^163^ | Poor | High risk of bias introduced by the nonmasked intervention and low participation rates in the intervention. The results presented in the paper do not represent effect estimates of the individual four study groups and it is not possible to extract effect estimates for our interventions of interest apart from the environmental interventions that were also implemented. Also, fractures (except for hip) were self-reported. Some concerns related to selection bias because of the cluster randomization and failure to demonstrate equivalence of groups at baseline. | No information | No information | Probably yes | Some concerns | Few details regarding the cluster randomization and whether important geographic differences in the community may have led to important baseline differences; unable to assess baseline differences in groups between the two intervention arms of interest to this review.
Lips et al, 1996^75^ | Fair | Some concerns due to contamination and modest adherence for both benefits and harms outcomes. Peripheral fractures were self-reported and not clinically validated. | Yes | Yes | Yes | Low | None
Peacock et al, 2000^85^ | Poor | High risk of bias due to very high attrition, also some concerns because of lack of information about randomization/allocation concealment, fidelity to intervention, and specification/ascertainment of outcomes. | No information | No information | Yes | Some concerns | No description of randomization or allocation concealment.
Prince et al, 2006,^89^ and Lewis et al, 2011^90^ and Zhu et al, 2008^109^ | Fair^†^ | Some concerns because adherence to study medication was low. | Yes | Yes | Yes | Low | None
Recker et al, 1996^72^ | Fair for Benefits Poor for Harms | Some concerns due to borderline high attrition, modest fidelity to intervention, and lack of information about randomization/assignment. For harms, no information about outcome specification/ascertainment. | No information | No information | Probably yes | Some concerns | No description of randomization or allocation concealment.
Reid et al, 1993,^94^ Reid et al, 1995^92^ | Poor | High risk of bias due to attrition and measurement of fractures as unclear whether self-reported or clinically validated. Also, some concerns for bias due to poorly specified harm measures in and uncertainty in selection bias domain because of missing information. | No information | No information | Yes | Uncertain as NR | None
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Fair | Some concerns for bias due to modest adherence. | Yes | Yes | Yes | Low | None
Reid et al, 2008^91^ | Poor for Benefits Fair for Harms | High risk of bias in measurement of fractures as outcome not prespecified and was collected as an ‘adverse event’; most were the result of substantial trauma and unclear whether clinically validated. Some concerns in measurement domain for harms due to no information on outcome specification/ascertainment. | Yes | Yes | Yes | Low | None
Riggs et al, 1998^73^ | Fair | Some concerns because of borderline high attrition and no information about how missing data for those with incomplete data were handled. Also, some concerns due to modest adherence. | No information | No information | Yes | Low | No information about randomization or allocation concealment.
Ruml et al, 1999^93^ | Poor | High risk of bias from high overall attrition and differential attrition and lack of ITT analysis. Some concerns over lack of information about randomization and allocation concealment and intervention adherence. | No information | No information | Probably yes | Uncertain because no information | No information about randomization or allocation concealment.
Salovaara et al, 2010^106^ | Poor | High risk of bias across multiple domains, including selection bias (lack of allocation concealment with open label trial and evidence of group imbalances at baseline), departure from intended interventions as personal use of supplements allowed by control group and increased over study duration. | Yes | No information | Probably no | High | Potential for bias given lack of allocation concealment in this open-label trial; some imbalances at baseline, but these were adjusted for in the analysis. 15 people in control group died after randomization but before start of trial. None died in intervention group before start. This suggests groups were not balanced at baseline.
Sanders et al, 2010^83^ | Good for Benefits Good for all-cause mortality; fair for incident CVD and cancer | No risk of bias concerns in any domain for benefits outcomes. Some risk of bias concerns for some harms outcomes because of limited information on outcome specification/ascertainment. | Yes | Yes | Yes | Low | None
Smith et al, 2007^84^ | Fair | Some concerns over attrition, and fidelity of intervention as this intervention could span from 1 to 3 annual doses over 3 years. | Yes | Yes | Yes | Low | None
Trivedi et al, 2003^76^ | Fair | Some concerns because of study attrition, no information about randomization/allocation concealment, departure from intended intervention due to use of supplements outside the study, and self-reported outcomes though most participants were physicians. | No information | No information | Yes | Uncertain because no information | No information about randomization or allocation concealment.
Women’s Health Initiative Calcium and Vitamin D Trial Jackson et al, 2003.^95^ Jackson et al, 2006,^70^ Wactaw ski-Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011.^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013.^97^ Robbins et al, 2014.^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Fair | Some concerns for bias as adherence to study intervention was modest, and personal use of supplements was allowed throughout the trial. Also, some concerns for bias in harms outcomes due to limited information on outcome specification/ascertainment. | Yes | No information | Yes | Low | No information about allocation concealment.

* This is the overall study quality rating, which reflects the risk of bias across multiple domains, including selection bias, bias from missing data, bias from departures from intended intervention, measurement bias, and reporting bias. Each part of Tables 1 through 8 include a domain specific risk of bias assessment.

† All outcomes reported after 9.5 years of followup were not considered eligible as these outcomes represent 5 years of a rando mized trial followed by 4.5 years of observation during which participants were not required to stay with assigned treatment, and no information is available about calcium use or nonuse during these additional 4.5 years.

Abbreviations: CVD=cardiovascular diseases; ITT=intent-to-treat; NR=not reported.

Appendix E Table 2 Quality Ratings for RCTs: Part 2

Author, Year, Trial Name | What were the overall attrition, attrition by group, and variation in attrition by outcome? | Did the study have low attrition? | Are the proportion of participants and reasons for data similar across interventions? | For benefits outcomes, was intent to treat analysis used? | Were appropriate statistical methods used to account for missing data? | Bias arising from missing outcome data? | Comments
Aloia et al, 2005^114^ | Overall: (30+30)/208=28.8% Pacebo: 30/104=28.8% Vit D: 30/104=28.8% | No | Yes | NA | Probably yes | High | High attrition with a rare outcome, no evidence of differential attrition.
Cherniack et al, 2011^119^ | Overall: 12/46=26% for efficacy results only, safety results have 0% attrition | Yes for safely endpoints, No for efficacy endpoints | No information | NA | No information | Low | Although the study had somewhat high attrition foi efficacy endpoints, safety results presented are for the entire study population consented and randomized, thus are likely low risk of bias.
Dawson-Hughes et al, 1997^74^ | Overall: 56/445=12.6% Placebo: NR Vit D & Calcium: NR | Probably yes | No information | Yes | Probably yes | Low | Attrition by groups was NR.
Glendenning et al, 2012^86^ | Overall: 48/686=7.0% Pacebo: 22/333=6.2% Vit D: 26/353=7.8% | Yes | Yes | Yes | Yes | Low | None
Hin et al, 2017^110^ | Overall: 15/305=4.9% Placebo: 6/101= 5.9% 4.000 IU/d: 5/102=4.9% 2.000 IU/d: 4/102=3.9% | Yes | Yes | NA | Probably yes | Low
Khaw, Scragg et al, 2017^77,^ ^78^ | Pacebo: 2/2552=0.1% Vit D: 0/2558=0% | Yes | Yes | Yes | Yes | Low | None
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Overall: 6/232=2.6% Calcium: 3/116=2.6% Vit D & Calcium: 3/116=2.6% | Yes | Yes | Yes | Probably yes | Low | None
Lappe et al, 2007^107^ | Overall: 156/1,180=13.2% Attrition by group NR | Yes | No information | Yes | Yes | Low | None
Lappe et al, 2017^108^ | Overall: 106/2,303=4.6% Pacebo: 52/1,147=4.5% Vit D/Calcium 54/1,156=4.7% | Yes | Yes | Yes | No information | Low | None
Larsen et al, 2004^163^ | NR by study group, but overall 17.4% died. 6 participants left the city during follow up | Yes | No information | Yes | Yes | Low | Use of hospital registration database for outcome, thus risk of missing outcome data is probably low.
Lips et al, 1996^75^ | Pacebo: 7/1287=0.5% Vit D: 7/1291=0.5% | Yes | Yes | Yes | Yes | Low | Loss to follow up w as low overall and within each group. However, authors reported that only 63% of participants completed 3 years of the study: 18% died and 18% stopped treatment.
Peacock et al, 2000^85^ | Overall: 236/437=54%; Placebo: 61/129=47% Vit D: 69/124=55.6%; Calcium: 71/124=57.3%. | No | Yes | Probably yes | Probably yes | High | 46% overall attrition, and signal of some differential attrition between placebo and treatment groups, although not statistically significant.
Prince et al, 2006,^89^ and Lew is et al, 2011^90^ and Zhu et al, 2008^109^ | Overall: 232/1460=15.9% Pacebo: 119/730=16.3% Calcium: 113/730=15.5% Specific to Zhu et al, 2008^109^: Overall: 13/120=10.8% Placebo: 5/41=12.2% Calcium: 2/40=5% Calcium & Vit D: 6/40=15% | Yes | Yes | Yes | Probably yes | Low | None
Recker et al, 1996^72^ | Overall attrition: 54/251=22% Differential attrition: NR | Probably no | No information | Yes | Yes | Some concerns | Borderline high overall attrition; intent to treat analysis used, but a sizable proportion of participants screened as eligible declined to participate, introducing some risk for selection bias.
Reid et al, 1993,^94^ Reid et al, 1995^92^ | Original trial: 13/135=9.6% Extension trial: 8/86=9.3% Overall attrition: 57/135=42% Cannot judge attrition by group because the N originally randomized and the N agreeing to extension trial is not provided by group | Probably yes | No information | Yes | No information | High | Attrition for original trial and attrition limited to extension phase are both low. However, a proportion of participants did not reconsent to the extension trial, so if that loss is considered, overall attrition is high.
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Overall: 216/1471=14.7% Placebo: 104/739=14.1% Calcium: 112/732=15.3% | Yes | No information | Yes | Probably yes | Low | ITT analyses run with and without imputation (maximum likelihood) of missing values, and with and without adjustment for compliance.
Reid et al, 2008^91^ | Overall: 14/323=4.3% Placebo: 3/107=2.8% 600 mg Calcium: 2/108=1.9% 1,200 mg Calcium: 9/108=8.3% | Yes | Probably yes | Yes | Yes | Low | Compared with the other groups, in the 1,200-mg calcium group, a slightly higher number of participants did not complete follow up.
Riggs et al, 1998^73^ | Overall: 59/236=25.0% Pacebo: 28/117=23.9% Calcium: 30/119=25.2% | No | No information | Yes | No information | Some concerns | High attrition overall and no information about how missing data were handled regarding fractures for participants with incomplete follow up.
Ruml et al, 1999^93^ | Overall: 18/63=28.6% Pacebo: 6/34=17.6% Calcium: 12/29=41.4% | No | Probably yes | No information | No information | High | Moderate attrition and evidence of differential attrition. Also unclear whether ITT analysis was used.
Salovaara et al, 2010^106^ | Overall: 237/3,432=6.9% Control: 105/1,714=6.5% Vit D & Calcium: 132/1,718=7.7% | Yes | Yes | Yes | Yes | Low | None
Sanders et al, 2010^83^ | Pacebo: 110/1,125=9.8% Vit D: 116/1,131=10.3% | Yes | Yes | Yes | Yes | Low | None
Smith et al, 2007^84^ | Unable to calculate; participants were recruited over 3 years. Therefore, not all contributed to the analysis at all time points. Appears that 71% of those recruited in first year contributed to the analysis at 36 months | No information | Yes | Yes | Probably yes | Some concerns | Unable to determine attrition given rolling recruitment over the 3-year study period, and unclear whether the figures describing the number of participants that did not return questionnaires are unique participants or include the same participants.
Trivedi et al, 2003^76^ | Overall: 631/2,686=23.5% Placebo: 324/1,341=24.2% Vit D: 307/1,345=22.8% Taking into account those who died, only 6% did not complete for another reason | Probably yes | Probably yes | Yes | No information | Some concerns | Study attrition nearly a quarter of the randomized population, mostly due to deaths that were adjudicated centrally, no evidence of differential attrition. Authors reported no significant differences between participants who completed 5 years and those who discontinued questionnaire follow up.
Women’s Health Initiative Calcium and Vitamin D Trial Jackson et al, 2003.^95^ Jackson et al, 2006,^70^ Wactaw ski-Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011,^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013.^97^ Robbins et al, 2014.^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Overall: 2,531/36,282=7.0% Pacebo: 1,291/18,106=7.1% Vit D & Calcium: 1,240/18,176=6.8% | Yes | Yes | Yes | Yes | Low | None

Abbreviations: ITT=intent to treat; N=number; NA=not applicable; NR=not reported.

Appendix E Table 3 Quality Ratings for RCTs: Part 3

Author, Year, Trial Name | Were the participants unaware of their intervention status? | Were the trial personnel and clinicians unaware of the intervention status of participants? | Were outcome assessors unaware of the intervention status of participants? | Was intervention fidelity adequate (specifically adherence)? | Were cross-overs or contamination minimal such that it would not raise concern for bias? | Bias arising from departures from intended interventions? | Comments
Aloia et al, 2005^114^ | Yes | Yes | Probably yes | Probably yes | Probably no | Some concerns | Mean adherence by pill count was 87.5% (SD 8%); participants in both study groups were given unknown, individually tailored dose of calcium supplements to achieve total daily intake of 1,200-1,500 mg.
Cherniack et al, 2011^119^ | Yes | Yes | Yes | Probably no | No | High | 19 participants in the treatment group and 22 in the control group with inadequate calcium intake (>1,200 mg/d) were given supplements to ensure adequate calcium intake.
Dawson-Hughes et al, 1997^74^ | Yes | Yes | Yes | Yes | Yes | Some concerns | Participants instructed to avoid personal use of supplements. Adherence based on pill counts was ≥90% among participants who completed the study. 71.4% of those randomized were still taking study drug at follow up.
Glendenning et al, 2012^86^ | Yes | Yes | Yes | Yes | Yes | Low | Medication was administered during clinic visits, so adherence was 100%.
Hin et al 2017^110^ | Yes | Yes | No | Yes | Yes | Low | Vit D use <400 IU was allowed, but intervention doses were quite high (4,000 and 2,000 IU); thus, very little potential of contamination in placebo group by low levels of vitamin D use outside of study protocol.
Khaw, Scragg et al, 2017^77,^ ^78^ | Yes | Yes | Yes | Yes | No information | Low | Unclear whether continued use of personal supplements was allowed during study, but a relatively low proportion were using supplements at baseline so this is unlikely to result in serious bias.
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Probably no | Probably no | No information | Yes | Yes | Some concerns | Study was described as "open" following randomization, suggesting that masking was not used. Approximately 10% of participants in both groups did not adhere to study medication.
Lappe et al, 2007^107^ | Yes | Yes | No information | Yes | No information | Low | Mean adherence (defined as ≥80% of doses) was 85.7% for vitamin D (and its placebo) and 74.4% for calcium (and its placebo).
Lappe et al, 2017^108^ | Yes | Yes | Yes | Probably yes | Probably no | Some concerns | Only moderate levels of adherence, and personal supplement use was allowed during the study.
Larsen et al, 2004^163^ | Probably no | No information | No information | Probably no | No information | High | 55.7% of those offered the vitamin D/calcium-only intervention agreed to participate. Different rates of uptake of the intervention in each study group (47.8% in the 2,532 residents who were offered the pure Environment and Health Program, 55.7% in the 2,426 residents offered the pure Calcium and Vitamin D Program, and 45.0% in the 2,531 residents offered both programs), creating the potential for unmeasured confounding. When combined with likely differences in baseline, it is possible that baseline characteristics predicted uptake and outcomes.
Lips et al, 1996^75^ | Yes | Yes | No information | Probably yes | Probably yes | Some concerns | 18% of placebo group and of treatment group had stopped taking study drug by year 3. Similar proportions of participants in each group took vitamin or multivitamin supplements at two or more followup visits.
Peacock et al, 2000^85^ | Yes | Yes | No information | No information | No information | Some concerns | None
Prince et al, 2006,^89^ and Lew is et al, 2011^90^ and Zhu et al, 2008^109^ | Yes | Yes | No information | No | No information | Some concerns | Adherence was 56.8% (defined as at least 80% adherent to study drug). No significant difference in adherence between placebo (56.1%) and calcium (57.5%). Zhu et al, 2008^109^: adherence rates similar across groups, ranging from 80% to 89%
Recker et al, 1996^72^ | Yes | Yes | Yes | No | Yes | Some concerns | Median adherence was 64%, but no evidence of differential attrition.
Reid et al, 1993,^94^ Reid et al, 1995^92^ | Yes | Yes | No information | Probably yes | No information | Low | Adherence: Original trial: Placebo: 83% Calcium: 84%
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Yes | Yes | Probably yes | Probably yes | Probably no | Some concerns | Adherence by those remaining at end of trial was 85% overall. However, across entire study period, adherence was 55% in calcium group and 58% in placebo group.
Reid et al, 2008^91^ | Yes | Yes | No information | Yes | Yes | Low | Adherence by participants remaining at the end of follow up: Placebo: 93% Group 2: 91% Group 3: 86%
Riggs et al, 1998^73^ | Yes | Yes | No information | Yes | No information | Some concerns | Mean dose based on tablet count was 1,234 mg/day, approximately 75% adherence.
Ruml et al, 1999^93^ | Yes | Probably Yes | No information | No information | No information | Some concerns | No information about adherence to study drug.
Salovaara et al, 2010^106^ | No | No | No information | Yes | Probably no | High | Open-label study, participants and investigators were not masked. Participants in control group were allowed to continue personal use of supplements, intake of vitamin D in control group increased from 3.8% to 16.1% over follow up. Mean adherence in intervention group was 78%.
Sanders et al, 2010^83^ | Yes | Yes | No information | Yes | Probably yes | Low | Adherence with taking annual dose confirmed for all participants, other than those for whom dose withheld or dose declined. At study end: Placebo: 6% were taking more than 400 IU of vitamin D Vit D: 3% were taking more than 400 IU of vitamin D
Smith et al, 2007^84^ | Yes | Yes | Probably yes | No | Yes | Some concerns | Study designed to provide an annual dose of vitamin D, but recruitment was over 3 years, so participants received between 1 and 3 annual doses depending on when they were recruited. Dose was administered by nursing staff.
Trivedi et al, 2003^76^ | Yes | Yes | Probably Yes | Probably yes | No information | Some concerns | 76% of participants took at least 80% of study drugs. No information about personal use of supplements at baseline or throughout study. Participants were told to continue any usual drug treatment and any new drugs that were advised. If they were advised to start vitamin D of >200 IU daily, they discontinued the trial intervention but continued to be followed.
Women’s Health Initiative Calcium and Vitamin D Trial Jackson et al, 2003.^95^ Jackson et al, 2006,^70^ Wactaw ski-Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011.^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013.^97^ Robbins et al, 2014.^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Yes | Yes | Yes | Probably yes | Probably no | Some concerns | At the end of the trial, 76% were taking study drug, and 59% took 80% or more of it. Participants did not have to discontinue use of personal vitamin D or calcium supplements and concurrent use of calcium (up to 1,000 mg/day) and vitamin D (up to 600 IU per day) was allowed throughout the intervention.

Abbreviations: IU=international units, mg=milligram, SD=standard deviation.

Appendix E Table 4 Quality Ratings for RCTs: Part 4

Author, Year, Trial Name | Were benefit outcomes (e.g., fractures) adequately described, prespecified, valid, and reliable? | Were similar techniques used among groups to ascertain benefit outcomes? | Was the duration of follow up adequate to assess benefit outcomes? | Bias arising from measurement of benefit outcomes? | Comments
Aloia et al, 2005^114^ | NA | NA | NA | NA | NA
Cherniack et al, 2011^119^ | NA | NA | NA | NA | NA
Dawson-Hughes et al, 1997^74^ | Yes | Yes | Yes | Low | Measures include total nonvertebral fractures and a subset of fractures deemed to be osteoporotic. Fractures confirmed by x-ray or hospital records.
Glendenning et al, 2012^86^ | No | Yes | Probably no | High | Fractures were self-reported, were not specific to site or cause (traumatic vs. osteoporotic), no radiographic/clinical validation, and time period of follow up (9 months) may be too short to see benefit.
Hin et al, 2017^110^ | NA | NA | NA | NA | NA
Khaw, Scragg et al, 2017^77,^ ^78^ | Yes | Yes | Yes | Low | None
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Yes | Yes | Yes | Low | Self-reported fractures were validated by medical record.
Lappe et al, 2007^107^ | NA | NA | NA | NA | NA
Lappe et al, 2017^108^ | NA | NA | NA | NA | NA
Larsen et al, 2004^163^ | Yes | Yes | Yes | Low | None
Lips et al, 1996^75^ | Probably yes | Yes | Yes | Varies by outcome | Low for hip fracture, high for other fractures since based on self-report and not clinically validated.
Peacock et al, 2000^85^ | Yes | Yes | Yes | Low | None
Prince et al, 2006,^89^ and Lew is et al, 2011^90^ and Zhu et al, 2008^109^ | Yes | Yes | Yes | Low | None
Recker et al, 1996^72^ | Probably no | Yes | Yes | Some concerns | Self-reported fractures were confirmed with radiographs in the extension trial, but no information about how fractures were defined or whether confirmed in the original trial.
Reid et al, 1993,^94^ Reid et al, 1995^92^ | No | Yes | Yes | High | Fractures other than vertebral, not defined and not specified as to whether self-reported or confirmed radiographically.
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Yes | Yes | Yes | Low | None
Reid et al, 2008^91^ | No | Yes | Yes | High | Fracture outcomes not specified as to site, authors report that “except for toe fractures, all fractures occurred after substantial trauma.” Adverse events were elicited from patients based on symptoms; fractures were not specifically elicited from participants during study visits, unclear whether radiographically or clinically confirmed.
Riggs et al, 1998^73^ | Yes | Yes | Yes | Low | None
Ruml et al, 1999^93^ | Probably yes | Yes | Yes | Low | Vertebral morphometric fractures as ascertained by spine radiographs.
Salovaara et al, 2010^106^ | Yes | Yes | Yes | Low | Self-reported fractures were validated by medical records or radiologic reports.
Sanders et al, 2010^83^ | Yes | Yes | Yes | Low | Fractures were radiologically validated.
Smith et al, 2007^84^ | Yes | Yes | Yes | Low | None
Trivedi et al, 2003^76^ | Probably yes | Yes | Yes | Low | Fractures were self-reported, although authors suggested that physicians (who comprised the majority of participants) were a reliable source of self-reported fracture data. The authors found no differences between physician participants and nonphysician participants in terms of outcome reporting.
WHI CaD Jackson et al, 2003.^95^ Jackson et al, 2006,^70^ Wactawski- Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011.^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013.^97^ Robbins et al, 2014.^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Yes | Yes | Yes | Low | Total fractures were all clinical fractures other than those of ribs, sternum, skull, or face. Fractures were verified radiographically or through operative reports by centrally trained and blinded physician adjudicators at each site; hip fractures were verified by centralized adjudicators.

Abbreviations: NA=not applicable; vs.=versus; WHI CaD=Women’s Health Initiative Calcium and Vitamin D Study.

Appendix E Table 5 Quality Ratings for RCTs: Part 5

Author, Year, Trial Name | Were harms outcomes adequately described, valid, and reliable? | Were similar techniques used among groups to ascertain harms outcomes? | Was the duration of follow up adequate to assess harms outcomes? | Bias arising from measurement of harms outcomes? | Comments
Aloia et al, 2005^114^ | No information | No information | Yes | Uncertain because no information | Study does not describe how incidents of kidney stones are specified or ascertained.
Cherniack et al, 2011^119^ | No information | No information | Probably no | High | Study does not describe how incidents of myocardial infarction are ascertained, no baseline characteristics about study population’s risk for CVD or CVD risk factors, and the follow up time period (6 months) may not be long enough to observe this harm.
Dawson-Hughes et al, 1997^74^ | NA | NA | NA | NA | NA
Glendenning et al, 2012^86^ | Probably no | Yes | Probably no | High | Adverse events were self-reported in a diary with no clinical validation. Short time period to assess incident cancer and CVD (9 months). Observed harms were likely because of high baseline risk of disease (i.e., undiagnosed asymptomatic cancer or coronary arterial blockages) that became symptomatic during follow up.
Hin et al, 2017^110^ | Probably yes | Yes | Probably no | Some concerns | 12 months may not be adequate to evaluate harms with longer induction periods (CVD and cancer). Only all-cause mortality and the serious adverse event outcome were adequately specified for inclusion in this review.
Khaw, Scragg et al, 2017^77,^ ^78^ | Probably yes | Yes | Yes | Low | None
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Probably no | Yes | Yes | Some concerns | No information about whether harms measured were clinically verified or based on self-report.
Lappe et al, 2007^107^ | Varies by outcome | Yes | Yes | Varies by outcome | No information about how kidney stones outcome was specified or ascertained, thus some concerns for this outcome.
Lappe et al, 2017^108^ | Yes | Yes | Yes | Low | None
Larsen et al, 2004^163^ | NA | NA | NA | NA | NA
Lips et al, 1996^75^ | Probably yes | Yes | Yes | Low | None
Peacock et al, 2000^85^ | No | Yes | Yes | Some concerns | No information on how kidney stones were specified or ascertained and data not explicitly provided by groups.
Prince et al, 2006,^89^ and Lewis et al, 2011^90^ and Zhu et al, 2008^109^ | Probably no | Yes | Yes | Some concerns | Incident cancer, vascular disease, and kidney stone outcomes are self-reported by participants during follow up visits with a health care provider. No description of outcome ascertainment and whether clinically validated.
Recker et al, 1996^72^ | No | No information | Yes | Uncertain because no information | Unclear how instances of kidney stones are specified or ascertained.
Reid et al, 1993,^94^ Reid et al, 1995^92^ | Probably no | Yes | Yes | Some concerns | Harms not specified, but rather reported as adverse events and/or reasons for dropout.
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Probably yes | Yes | Yes | Low | Systematic adjudication of most self- and family-reported harms, including cardiovascular events and all-cause mortality.
Reid et al, 2008^91^ | Probably no | Yes | Yes | Some concerns | Harms outcomes not well specified, and method of ascertainment relied on patients to self-report symptoms or events vs. a systematic assessment of various harms.
Riggs et al, 1998^73^ | No information | Yes | Yes | Low | None
Ruml et al, 1999^93^ | NA | NA | NA | NA | NA
Salovaara et al, 2010^106^ | Yes | Yes | Yes | Low | None
Sanders et al, 2010^83^ | Varies by outcome | Yes | Yes | Varies by outcome | Low for all-cause mortality, some concerns for incident CVD and cancer, since not defined and not clear w hether based on self-report or clinically validated with medical record review.
Smith et al, 2007^84^ | NA | NA | NA | NA | NA
Trivedi et al, 2003^76^ | Probably yes | Yes | Yes | Some concerns | Other than all-cause mortality and incident of selected conditions resulting in death, all harms were ascertained via self-reported questionnaire.
Women’s Health Initiative Calcium and Vitamin D Trial Jackson et al, 2003.^95^ Jackson et al, 2006,^70^ Wactaw ski-Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011.^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013.^97^ Robbins et al, 2014.^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Yes | Yes | Yes | Low^*^ | Kidney stone incidence was based on self-report,^113^ not validated by clinical records. Skin cancer was self-reported^120^; validity of self-report of skin cancer is high.^164,^ ^165^ Cancers based on central physician adjudicators masked to randomization status.^121^ Approximately half of VTE outcomes were adjudicated; validity of self-reported VTE outcomes was assessed and was found to be valid.^116^ Central adjudication of medical records for heart failure outcomes.^117^

* Some concerns for kidney stone outcomes reported in Wallace et al, 2011,^113^ VTE outcomes reported in Blondon et al, 2015,^116^ and heart failure outcomes reported in Donneyong et al, 2015.^117^

Abbreviations: CVD=cardiovascular disease; NA=not applicable; vs.=versus; VTE=venous thromboembolism.

Appendix E Table 6 Quality Ratings for RCTs: Part 6

Author, Year, Trial Name | Is the reported effect estimate unlikely to be selected, on the basis of the results, from multiple outcomes measurements within the domain, multiple analyses, or different subgroups? | Bias arising from selection of reported results? | Comments
Aloia et al, 2005^114^ | Yes | Low | None
Cherniack et al, 2011^119^ | Yes | Low | None
Dawson-Hughes et al, 1997^74^ | Yes | Low | None
Glendenning et al, 2012^86^ | Yes | Low | None
Hin et al, 2017^110^ | Yes | Low | None
Khaw, Scragg et al, 2017^77,^ ^78^ | Yes | Low | None
Komulainen et al, 1998,^71^ Komulainen et al, 1999^118^ | Yes | Low | None
Lappe et al, 2007^107^ | No | See comment | This study’s primary aim was fracture incidence per its trial registry but these outcomes have not been published to date. Per personal communication with the study author, no effect on fracture incidence was observed and study contamination due to uptake by of alendronate (which came to market during the study) was suggested as a reason.
Lappe et al, 2017^108^ | Yes | Low | None
Larsen et al, 2004^163^ | Yes | Low | None
Lips et al, 1996^75^ | Yes | Low | None
Peacock et al, 2000^85^ | Yes | Low | None
Prince et al, 2006,^89^ and Lewis et al, 2011^90^ and Zhu et al, 2008^109^ | Yes | Low | None
Recker et al, 1996^72^ | Yes | Low | None
Reid et al, 1993,^94^ Reid et al, 1995^92^ | Yes | Low | None
Reid et al, 2006,^87^ Bolland et al, 2008^88^ | Yes | Low | None
Reid et al, 2008^91^ | Yes | Low | None
Riggs et al, 1998^73^ | Yes | Low | None
Ruml et al, 1999^93^ | Yes | Low | None
Salovaara et al, 2010^106^ | Yes | Low | None
Sanders et al, 2010^83^ | Yes | Low | None
Smith et al, 2007^84^ | Yes | Low | None
Trivedi et al, 2003^76^ | Probably no | Some concerns | Multiple fracture outcomes reported, which are multiple variations of the same types of fractures.
Women’s Health Initiative Calcium and Vitamin D Trial Jackson et al, 2003,^95^ Jackson et al, 2006,^70^ Wactawski-Wende et al, 2006,^112^ LaCroix et al, 2009,^111^ Bolland et al, 2011,^115^ Bolland et al, 2011,^96^ Brunner et al, 2011,^121^ Tang et al, 2011,^120^ Wallace et al, 2011,^113^ Prentice et al, 2013,^97^ Robbins et al, 2014,^98^ Blondon et al, 2015,^116^ Donneyong et al, 2015^117^ | Yes/Probably yes | Low | Subgroups analyzed in Robbins et al (2014) appear to have been preplanned.^98^ Rationale and biologic bases for the post hoc subgroup analyses seem sound.^96,^ ^115^

Abbreviations: KQ=key question; WHI CaD=Women’s Health Initiative Calcium and Vitamin D Trial.

Appendix E Table 7 Quality Ratings for Observational Studies: Part 1

Author, Year, Trial Name | Overall Quality Rating^*^ | Overall Rationale for Quality Rating
Ahn et al, 2007^166^ | Poor | High risk of bias due to selection bias, confounding, missing data, measurement of exposure, and departure from intended intervention.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Poor | High risk of bias in multiple domains, including measurement of exposure and departure from intended intervention. Some concerns related to confounding.
Cadeau et al, 2015^170^ | Poor | High risk of bias in multiple domains, including confounding and exposure ascertainment and selection bias due to large proportion of missing data.
Cauley et al, 2013^171^ | Poor | This study is the observational extension phase to the Women’s Health Initiative Calcium and Vitamin D randomized, controlled trial. High risk of bias in multiple domains, including selection bias, confounding, and departure from intended intervention. Some concerns for outcome measurement bias, missing data, and exposure measurement.
Chan et al, 2013^172^ | Poor | High risk of bias in multiple domains, including confounding and exposure ascertainment.
Cheng et al, 2014^173^ | Poor | High risk of bias across multiple domains, including confounding, high amount of missing data on exposure and confounding variables, measurement of exposure.
Curhan et al, 1997^174^ | Poor | High risk of bias across multiple domains, including confounding, measurement of exposure, and missing data; also, some concerns for selection bias.
Flood et al, 2005^175^ | Poor | High risk of bias due to unclear definition of exposure groups and without adequate measurement post baseline to be confident subjects supplement use did not vary over time, significant baseline and time-varying confounding also present.
Langsetmo et al, 2013^176^ | Poor | High risk of bias due to confounding, particularly for an outcome such as all-cause mortality. Further, measurement of exposure was based on self-report questionnaire at baseline and one other point in time over the 10-year period of follow up, high likelihood of departure from intended interventions and no measures of adherence/compliance done throughout the period of follow up.
Li et al, 2012^177^ | Poor | Confounding, selection bias due to missing exposure data, and poorly defined exposure result in high risk of bias across multiple domains.
Lin et al, 2005^178^ | Poor | High risk of bias in multiple domains, including measurement of exposure and departure from intended intervention. Some concerns related to residual confounding.
McCullough et al, 2003^179^ | Poor | High risk of bias in multiple domains, including measurement of exposure and departure from intended intervention. Some concerns related to residual confounding and no information about missing data.
Michaelsson et al, 2013^180^ | Poor | High risk of bias due to residual confounding, particularly for outcomes such as all-cause mortality. High risk of bias due to measure of exposure, which included multivitamin use in addition to single-tablet calcium, and high risk of bias due to departures from intended intervention, since adherence is not measured and likelihood of switches is high given changes in health and aging over time and availability of supplements.
Paik et al, 2014^181^ | Poor | High risk of bias in multiple domains, including confounding and measurement of exposure, and contamination of study groups over course of observation; also, some concerns for selection bias,
Sorenson et al, 2012^182^ | Poor | Some concerns in nearly all bias domains, including confounding, exposure ascertainment/definition. Residual confounding likely because dietary calcium intake was not included as covariate in multivariate analyses of association between nephrolithiasis and either calcium supplement dosing or history of use.
Sun et al, 1997^183^ | Poor | High risk of bias in multiple domains, including confounding and measurement of exposure, and contamination of study groups over period of observation; also, some concerns about selection bias.
Sun et al, 2011^184^ | Poor | High risk of bias across most domains, including confounding, measurement of outcome, measurement of exposure, and departure from intended intervention; also, some concerns about adequate length of follow up.
Terry et al, 2002^185^ | Poor | High risk or some concerns across most bias domains. Confounding, assessment of calcium supplement intake, and the approach to handling missing data all contribute to a high risk of bias.
Waterhouse et al, 2015^186^ | Poor | High risk of bias due to information bias stemming from differences in how vitamin D supplement intake was measured across the pooled 4 studies relevant to this review. Risk of misclassification of vitamin D supplement intake groups because of variations in the operationalized definitions of supplement use. Multiple other concerns based on lack of information, like similarity of baseline characteristics between supplement intake groups and how recall bias affects outcome ascertainment between cases vs. controls.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | Poor | High risk of bias due to confounding and definition/measurement of exposure, and in potential for departures from intended intervention, no measures of adherence and follow -up was only every 4 years.
Van Hemelrijck et al, 2013^189^ | Poor | High risk of bias in multiple domains, including measurement of exposure and departure from intended intervention. Some concerns related to residual confounding and missing data.
Xiao et al, 2013^190^ | Poor | High risk of bias due to residual confounding, particularly for outcomes such as cardiovascular mortality. High risk of bias due to measure of exposure, which included multivitamin use in addition to single tablet calcium, and high risk of bias due to departures from intended intervention, since adherence not measured and likelihood of switches is high given changes in health and aging over time, and availability of supplements.
Yang et al, 2016 ^191^ | Poor | High risk of bias due to confounding, measurement of exposure, missing data, and departure from intended intervention. Some concerns related to selection bias.

* This is the overall study quality rating, which reflects the risk of bias across multiple domains, including selection bias, bias from confounding, bias from missing data, bias from departures from intended intervention, and measurement bias. Each part of Tables 8 through 14 include one domain specific risk of bias assessment.

Appendix E Table 8 Quality Ratings for Observational Studies: Part 2

Author, Year, Trial Name | For Cohort Studies Only: Was selection of participants into the study unrelated to intervention or unrelated to outcome? | For Cohort Studies Only: Were post-intervention variables that influenced selection likely to be associated with the intervention or likely to be influenced by the outcome or a cause of the outcome? | For Cohort Studies Only: Do start of follow up and start of intervention coincide for most subjects? | For Cohort Studies Only: Were adjustment techniques used that are likely to correct for the presence of selection biases? | For Case-Control Studies Only: Were the controls sampled from the population that gave rise to the cases, or using another method that avoids selection bias? | Bias Arising From Selection | Comments
Ahn et al, 2007^166^ | Probably no | Related to outcome | No | Probably no | NA | High | Not an inception cohort. All participants were in the screening arm of a prostate screening trial, received screening, and may have behaviors and/or diagnostics, and/or treatment interventions related to participation in the trial.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Cadeau et al, 2015^170^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Cauley et al, 2013^171^ | No | Yes | Yes | Probably no | NA | High | Not an inception cohort, observational extension phase following completion of the WHI CaD Trial. Participants were told of their treatment assignment at the end of the trial and reconsented to participate in the extension phase. Reconsenting participants were different than those who did not reconsent.
Chan et al, 2013^172^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Cheng et al, 2014^173^ | NA | NA | NA | NA | Yes | Low | None
Curhan et al, 1997^174^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Flood et al, 2005^175^ | Probably yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Langsetmo et al, 2013^176^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Li et al, 2012^177^ | No | NA | No | Probably no | NA | High | Selection related to outcome, and not an inception cohort.
Lin et al, 2005^178^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
McCullough et al, 2003^179^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Michaelsson et al, 2013^180^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Paik et al, 2014^181^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Sorenson et al, 2012^182^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort.
Sun et al, 2011^183^ | Yes | NA | No | Probably no | NA | Some concerns | Not an inception cohort
Sun et al, 2011^184^ | NA | NA | NA | NA | Probably yes | Low | Population-based cancer registries used to select cases, controls were subjects randomly sampled from the provincial population.
Terry et al, 2002^185^ | NA | NA | NA | NA | Probably yes | Low | Case patients sampled from Swedish regional cancer registries, while control patients sampled from Swedish population register including all of the country’s residents.
Van Hemelrijck et al, 2013^189^ | Yes | NA | No | NA | NA | Some concerns | Not an inception cohort.
Waterhouse et al, 2015^186^ | NA | NA | NA | NA | Probably no | Some Concerns | No information about similarities/differences in sourcing by supplement use groups, but expected bias can be evaluated by looking at sources of overall case vs. control participant selection. Sources of case vs. control selection varied by individual study, meaning resulting bias varies by study.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | Yes | NA | No | NA | NA | Some concerns | Not an inception cohort.
Xiao et al, 2013^190^ | Yes | NA | No | NA | NA | Some concerns | Not an inception cohort.
Yang et al, 2016^191^ | Probably yes | NA | Yes | No | NA | Some Concerns | Not an inception cohort.

Abbreviations: NA=not applicable; vs=versus; WHI CaD Trial=Women’s Health Initiative Calcium and Vitamin D Trial.

Appendix E Table 9 Quality Ratings for Observational Studies: Part 3

Author, Year, Trial Name | Is confounding of the effect of intervention unlikely in this study? | Did the authors use an appropriate analysis method that adjusted for all the critically important confounding domains? | Were confounding domains that were controlled for measured validly and reliably by the variables available in the study? | Did the authors avoid adjusting for post-intervention variables? | Were participants analyzed according to their initial intervention group throughout follow up? | Were intervention discontinuations or switches unlikely to be related to factors that are prognostic for the outcome? | Bias Arising From Confounding | Comments
Ahn et al, 2007^166^ | Probably no | Probably yes | Probably no | NA | No information | No information | High | Relies on self-reported measures of confounding.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Probably no | Probably yes | Probably no | Probably no | No information | No information | High | Relies on self-reported measures, and potential for time-varying confounding.
Cadeau et al, 2015^170^ | No | Probably yes | Probably no | Probably yes | Probably no | No information | High | Relies on self-reported measures, and possibility of time-varying confounding as change in use of supplements may be related to engagement in other health promotion behaviors or the start of menopause, which are both factors related to breast cancer.
Cauley et al, 2013^171^ | No | Probably no | Probably no | Probably no | Yes | No | High | Adjustments for relatively few confounding variables; age, hormone trial participation, and baseline vitamin D and calcium intake and supplement use.
Chan et al, 2013^172^ | No | No | No information | Yes | Yes | No | High | No measures or adjustment for CVD risks factors (HTN, DM, cholesterol); further confounders such as diet and physical activity assessed only at baseline, yet these are likely to change over time, as is the use of supplements. Thus, time-varying confounding is also a factor.
Cheng et al, 2014^173^ | No | No | NA | No information | Probably yes | No | High | Odds ratios for supplemental vitamin D use appears to be unadjusted for any confounding variables, particularly smoking and asbestos exposure. Further, this study reports the r elationship between vitamin D and lung cancer over a period that included a trial component for vitamin A and an observational study component, because the trial was ended early due to increase in lung cancer risk in treatment arm; this could have led to discontinuations and switches during the observational phase as a result.
Curhan et al, 1997^174^ | Probably no | Probably yes | No | No information | No information | Probably no | High | Self-report measures, time-varying confounding likely.
Flood et al, 2005^175^ | No | Probably yes | Probably no | Probably yes | Probably yes | Probably no | High | Sources of vitamin D (dietary) based on self-reported recall, no adjustment for sun exposure as source of vitamin D; colorectal cancer screening based on self-report and how specified w as not reported. No adjustment for family history of colorectal cancer or other medical conditions related to this type of cancer that might also influence likelihood to take preventive supplements such as calcium.
Langsetmo et al, 2013^176^ | No | No | NA | No | Yes | No | High | Adjusted estimates for low trauma fracture; baseline characteristics assessed only between groups based on total intake (including diet and supplements), not balanced by group on a variety of characteristics that were measured; numerous potential influences on all-cause mortality that were not measured at baseline.
Li et al, 2012^177^ | Probably no | Probably yes | No | Probably yes | Probably yes | No information | High | Important confounders such as DM, HTN, and hyperlipidemia, were based on self-report, as was smoking status, and use of CVD-risk-lowering drugs.
Lin et al, 2005^178^ | Probably no | Probably yes | Probably no | Probably no | No information | No information | High | Relies on self-reported measures, potential for time- varying confounding.
McCullough et al, 2003^179^ | Probably no | Yes | Probably no | No information | No information | No information | High | Relies on self-reported measures.
Michaelsson et al, 2013^180^ | No | Probably yes | Probably yes | No information | Probably yes | Probably no | High | Authors relied on diagnostic codes for comorbidities, w hich is probably more suitable than self-report. However, these may not capture the severity of disease, thus residual confounding remains a concern. Time-updated information was used to adjust models, which offered different results than models with only baseline information, suggesting that time-varying confounding is a factor.
Paik et al, 2014^181^ | No | Yes | Probably no | Probably no | No | Probably yes | High | Self-report measures, residual confounding, and time-varying confounding.
Sorenson et al, 2012^182^ | No | Probably yes | Probably no | Probably yes | Yes | No information | Some concerns | Validated FFQ used to evaluate dietary confounders, others were self-reported, medication use evaluated by asking women to bring medications to clinic during visit and provide in-person medication history. Dietary calcium intake was not included in multivariate analyses for calcium supplementation as independent risk factor for nephrolithiasis.
Sun et al, 2011^183^ | No | Yes | Probably no | Probably yes | No | Probably yes | High | Self-report measures, residual confounding, participants analyzed according to the supplement intake level they endorsed at the start of each intermediate follow-up period (i.e., between one follow-up survey and the next one).
Sun et al, 2011^184^ | No | Probably yes | No | No | Probably yes | Probably no | High | Estimates adjusted for mediating variables on the direct effect of the intervention (multivitamin supplement use, physical activity). Discontinuations and switches likely to be related to factors prognostic for outcome (use of vitamins/ supplements during cancer treatment). Confounders measured based on self-report, inherent recall bias with case-control designs.
Terry et al, 2002^185^ | No | Probably yes | No | Yes | Yes | Probably yes | High | Retrospective measurement of important confounding variables, particularly among cases.
Van Hemelrijck et al, 2013^189^ | Probably no | Probably yes | Probably no | Probably no | No information | No information | High | Self-reported measures.
Waterhouse et al, 2015^186^ | No | Probably no | No information | Probably yes | Yes | Probably no | High | Residual confounding, not clear that all important confounders were considered.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | No | No | NA | No | No information | Probably no | High | Did not adjust for factors such as presence of BPH, use of alpha reductase inhibitors, both of w hich may be related to prostate cancer risk or increased opportunities for cancer detection through regular urologic care. Other confounders measured by self-report and updated with each new questionnaire; thus, unclear how this was accounted for in the analysis.
Xiao et al, 2013^190^ | No | Probably yes | Probably no | Probably yes | Yes | No | High | All confounders measured based on self-report, potential for residual confounding high for outcome of cardiovascular mortality given that few cardiovascular risks or related CHD conditions were measured at baseline. Also, likely time-varying confounding due to switches.
Yang et al, 2016^191^ | No | Probably no | No | No information | Probably yes | Probably no | High | Differences in numerous covariates at baseline, severity and treatment of CVD comorbidities not assessed, all rely on self-reported measures.

Abbreviations: BPH=benign prostatic hyperplasia; CHD=coronary heart disease; CVD=cardiovascular disease; DM=diabetes mellitus; FFQ=food frequency questionnaire; HTN=hypertension.

Appendix E Table 10 Quality Ratings for Observational Studies: Part 4

Author, Year, Trial Name | Is intervention status well defined? | Was information on intervention status recorded at the time of intervention? | Was classification of intervention status unaffected by knowledge of the outcome or risk of the outcome? | Bias Arising From Measurement of the Intervention | Comments
Ahn et al, 2007^166^ | No | Yes | Yes | High | Calcium use assessed based on self-report at baseline, and classified as current use or past use (within previous 2 or 5 years). Only mean dose of calcium (135 to 320 mg) provided, no additional information about duration of use and no information about ongoing use during period of study observation. Similarly, vitamin D use was dichotomized as users of <600 IU versus users of >600 IU.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | No | Yes | Yes | High | Use of supplements based on single self-reported questionnaire at baseline. Categories of exposure determined by distribution of data.
Cadeau et al, 2015^170^ | No | Probably yes | Probably yes | High | Supplement use assessed at baseline and via followup questionnaires; categorized as “current use,” “never use,” “past use.” Specific dose, frequency, and duration are not reported.
Cauley et al, 2013^171^ | Yes | Yes | No information | Some concerns | Participants were informed of treatment assignment at the end of the trial period; participants were analyzed in their original treatment assignment groups at the end of the observational extension phase.
Chan et al, 2013^172^ | No | Yes | Yes | High | Calcium use recorded as “yes” or “no” at baseline, no information about dose, frequency, or duration of use.
Cheng et al, 2014^173^ | No | Yes | Yes | High | Information on the use of personal supplemental vitamins were collected during clinical visits. Information on doses and frequency were retrospectively calculated/extracted based on the brand names captured during baseline. Author noted potential measurement error since ascertainment of vitamin D dosage based on bottle labels was incomplete; and only the baseline assessment was used. Further, the analysis of supplement use was only provided as “any use” vs. “no use” and it is not clear what the range of doses, frequency, and duration was for the group of “any use.”
Curhan et al, 1997^174^ | No | No information | Probably yes | High | Exposure based on self-report use at baseline and every few years.
Flood et al, 2005^175^ | No | No | Probably yes | High | Calcium supplement categories based on self-reported recall assessing usual intake over the prior year at baseline; no information about calcium supplementation use in years prior to the baseline recall, and in years subsequent to the baseline year recall.
Langsetmo et al, 2013^176^ | Probably no | Yes | Probably yes | High | Calcium and vitamin D supplement use defined as yes/no, and then low, moderate, or high within the “yes” category; use based on baseline questionnaire for the first 5 years, and then updated from questionnaires for the second 5-year period.
Li et al, 2012^177^ | Probably no | Probably yes | Probably yes | High | Self-reported use of supplements was coded using the Anatomical Therapeutic Chemical classification system, but data on dosage, frequency, and duration of use were not collected. Subjects classified as users if they reported daily use for at least 1 week, or nondaily use for at least 5 doses, all within the previous 4 weeks. Supplementation use documented at baseline and used for Model A analysis, followup supplementation use was assessed but frequency was not specified, cumulative use of calcium from baseline through followup assessed with Model D analysis.
Lin et al, 2005^178^ | No | Yes | Yes | High | Calcium supplement use defined as <500 or >500 mg, use for vitamin D defined as 0 or between 0 and 400 IU. All based on single self-report at baseline.
McCullough et al, 2003^179^ | No | Yes | Yes | High | Calcium supplement use ascertained only at baseline and during one single followup by self-report.
Michaelsson et al, 2013^180^ | No | Yes | Yes | High | Authors defined supplement use as use of single supplements (calcium tablets) but also estimated an additional dose from use of multivitamin supplements, of w hich 74% of subjects were users. Thus, the exposure in this analysis is not a single supplement calcium. Supplement use was not ascertained on the first questionnaire, and only 6% of subjects reported using supplements in the subsequent questionnaire.
Paik et al, 2014^181^ | Probably no | No information | Probably yes | High | Average daily dosing information captured at baseline and during follow-up, limitations in ascertainment noted.
Sorenson et al, 2012^182^ | Probably no | Probably yes | Probably yes | High | Calcium use specified as before study, since study, before and since study, and never. Dose, frequency, and duration not specified.
Sun et al, 2011^183^ | Probably no | No information | Probably yes | High | Average daily dosing information captured at baseline and during follow-up, but had limitations.
Sun et al, 2011^184^ | Probably no | No | No information | High | Exposure status documented retrospectively, based on self-report and analyzed as “yes/no” to use of supplements.
Terry et al, 2002^185^ | No | No | Probably no | High | Assessment of calcium supplement intake likely more accurate among cases than controls. Also, definition of “occasional” supplement intake frequency not provided, so that category could have encompassed a broad variety of different intake levels from several times a week (but not daily) to only once or twice a week.
Van Hemelrijck et al, 2013^189^ | No | Yes | Yes | High | Supplement use based on self-report at a single baseline measurement.
Waterhouse et al, 2015^186^ | Probably no | No | Probably no | High | Inconsistent methods used to solicit information about vitamin D supplement intake from participants across studies, which means varying risk of bias from information bias. Risk of misclassified vitamin D supplement intake because of variation in operationalized definitions of supplement use.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | No | Yes | Yes | High | Calcium supplement use is defined as “yes” or “no” at baseline measurement; specific doses, frequency of use, and duration of use are not provided.
Xiao et al, 2013^190^ | No | Yes | Yes | High | Supplement use defined based on use of single supplements plus supplements from multivitamin. Analysis is conducted comparing “users” to “nonusers,” with no specification as to dose, frequency, or duration.
Yang et al, 2016^191^ | No | Probably yes | Probably yes | High | Exposure based on self-report use at baseline and 2 additional time points separated by ~7 years.

Abbreviations: IU=international unit; mg=milligram.

Appendix E Table 11 Quality Ratings for Observational Studies: Part 5

Author, Year, Trial Name | Were outcome data available for all, or nearly all participants? | Were few or no participants excluded because of missing data on intervention status? | Were few or no participants excluded due to missing data on other variables needed for the analysis? | Were the proportion of participants and reasons for missing data similar across intervention groups? | Were appropriate statistical methods used to account for missing data or assess robustness to presence of missing data? | Bias Arising From Missing Outcome Data | Comments
Ahn et al, 2007^166^ | Probably no | Probably no | Probably yes | No information | Probably no | High | More than 20% of the original cohort was excluded because of missing exposure data, or missing covariate data. No sensitivity analyses to assess robustness to missing data were performed.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Probably yes | Probably yes | Probably yes | No information | No information | Some concerns | None
Cadeau et al, 2015^170^ | No | No | No information | No information | No | High | 6,237 women who were premenopausal at the time of time 1995 survey were excluded, and 23,000 did not complete the dietary questionnaire in 1993 or 1995. The original cohort was 98,000; only 54,000 were used for this analysis.
Cauley et al, 2013^171^ | Probably no | Yes | Probably yes | Yes | Yes | Some concerns | 82.6% of original treatment group, and 81.9% of original placebo group reconsented to observational extension phase.
Chan et al, 2013^172^ | Probably yes | Yes | No information | No information | No information | Some concerns | Of 4,000 in original cohort, 3,139 were included in analysis. Some were excluded for existing CVD, but specific numbers not provided.
Cheng et al, 2014^173^ | Probably no | No | No | Probably yes | Probably no | High | The original case and control cohort size was 1,016. The final sizes were 749 vs. 679 after excluding those that had a history of disease in the intestines, liver, and kidney that prevent oral vitamin D absorption, and those who did not complete a food frequency questionnaire during followup, among other reasons.
Curhan et al, 1997^174^ | No | No | Probably yes | No information | No | High | Supplement use data missing for 29.7% of participants reporting symptomatic kidney stones because 1980 survey did not capture that information. Also unclear how many participants were excluded because of missing dietary information from each intermediate period making up the study’s duration.
Flood et al, 2005^175^ | Yes | Probably yes | Probably yes | No information | No information | Low | None
Langsetmo et al, 2013^176^ | Yes | Yes | No information | No information | Probably yes | Low | Missing exposure status for a small proportion of participants; these subjects were excluded from the analysis.
Li et al, 2012^177^ | Yes | No | Yes | No information | No information | High | Authors note that, because 44.5% of all vitamin/mineral users in the EPIC study did not report the names of their supplements, the number of calcium supplement users captured in this analysis only accounted for 3.6% of all cohort participants. There is a possibility that the unreported calcium supplementation would affect the accuracy of results on cardiovascular risks.
Lin et al, 2005^178^ | Probably yes | Probably yes | Probably yes | No information | No information | Some concerns | None
McCullough et al, 2003^179^ | Probably yes | Probably yes | Probably yes | No information | No information | Some concerns | Missing data for 19.4% of original cohort; outcomes for 245 subjects could not be confirmed.
Michaelsson et al, 2013^180^ | No information | No information | Probably no | No information | Probably yes | Some concerns | Physical activity and smoking not assessed at baseline.
Paik et al, 2014^181^ | No information | No information | No information | No information | No | Uncertain because no information | Unclear how many participants excluded due to missing data about intervention status or for any outcome.
Sorenson et al, 2012^182^ | Probably yes | No information | No information | No information | No information | Uncertain because no information | None
Sun et al, 2011^183^ | Probably yes | Yes | Probably yes | No information | No | Some Concerns | About 9.2% and 10.7% of eligible participants from two cohorts, respectively, excluded from analysis because of either missing baseline dietary/supplemental Vit D intake information or because of a baseline CVD/cancer diagnosis. Unclear what proportion of these participants were excluded because of missing baseline information.
Sun et al, 2011^184^ | No | No | No | No information | No information | High | Only 65% of eligible cases and 53.5% of eligible controls provided responses to surveys.
Terry et al, 2002^185^ | Probably no | Probably no | Yes | No | No | High | No statistical methods used to account for missing dietary information for controls who failed to return their mailed questionnaires and were excluded from this analysis (14.3% of the group). In contrast, 100% of case patients returned their questionnaires. Additionally, other patients excluded by investigators for reasons besides missing questionnaires (nonparticipation in both groups, and atypical hyperplasia among some cases), but no mention of how their baseline characteristics compared with those of the study sample.
Van Hemelrijck et al, 2013^189^ | No information | No information | No information | No information | No information | Uncertain because no information | No information on how many participants had complete data.
Waterhouse et al, 2015^186^ | No | No information | Probably yes | No information | No | Uncertain because no information | Only 4 of 9 pooled case-control studies reported vitamin D supplement intake data. Also, participants were excluded due to missing confounder data, but specific numbers are not provided.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | Probably yes | No information | No information | No information | Probably yes | Uncertain because no information | No information on the proportion of subjects with missing calcium supplement use data or missing data on confounding variables.
Xiao et al, 2013^190^ | Probably yes | No information | No information | No information | No information | Uncertain because no information | Missing data not discussed by authors, and not evaluated based on supplement status.
Yang et al, 2016^191^ | No | No | No | No information | Probably no | High | Some exclusions were appropriate, but over 25% of the original cohort was not included in the analysis.

Appendix E Table 12 Quality Ratings for Observational Studies: Part 6

Trial Name | Were there no or minimal deviations from the intended intervention beyond what would be expected in usual practice? | Were these deviations from intended intervention unbalanced between groups and likely to have affected the outcome? | Were important co-interventions balanced across intervention groups? | Did the study measure adherence with defined intervention? | Bias Arising From Departures From Intended Interventions | Comments
Ahn et al, 2007^166^ | No information | No information | No information | No | Uncertain because no information | No attempts made to measure ongoing/continuing use of calcium or vitamin D throughout the study observation period.
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | No information | No information | No information | No | Uncertain because no information | No attempts made to measure ongoing/continuing use of calcium or vitamin D throughout the study observation period.
Cadeau et al, 2015^170^ | Probably no | Probably yes | No information | No | High | No attempts made to measure ongoing/continuing use of calcium or vitamin D throughout the study observation period.
Cauley et al, 2013^171^ | No information | No information | No information | No | High | Participants were unmasked at the end of the trial phase; no information about supplement use by the treatment and placebo groups throughout the observational extension phase.
Chan et al, 2013^172^ | Probably no | No information | No information | No | High | No information about supplement use other than the single baseline interview assessment.
Cheng et al, 2014^173^ | No information | No information | No information | No | Uncertain because no information | None
Curhan et al, 1997^174^ | No information | No information | No information | No | Uncertain because no information | Unclear how dietary calcium intake and other nutrient intake levels changed over course of study.
Flood et al, 2005^175^ | No information | No information | No information | Probably no | High | No data about subjects᾽ use of calcium beyond the single measurement at baseline; thus, cannot tell if subjects stopped, started, or changed doses of calcium throughout the period of observation.
Langsetmo et al, 2013^176^ | Probably no | No information | Probably no | No | High | Use was based on two questionnaires at baseline and at 5 years. No attempt to measure or characterize changes in use over the duration of the cohort.
Li et al, 2012^177^ | No information | No information | NA | No | Uncertain because no information | None
Lin et al, 2005^178^ | No information | No information | No information | No | Uncertain because no information | No attempts made to measure ongoing/continuing use of calcium or vitamin D throughout the study observation period.
McCullough et al, 2003^179^ | No information | No information | No information | No | Uncertain because no information | Only one followup to ascertain ongoing exposure and no information provided as to how this was used.
Michaelsson et al, 2013^180^ | No | No information | No information | Probably no | High | Baseline characteristics by supplement use were not provided. Use of supplements was measured by self-report on questionnaire and not clear how switches were handled in analysis.
Paik et al, 2014^181^ | No | Yes | No information | No | High | Contamination of no-supplement-use group over time (proportion of users increased from 30.5% of participants at baseline in 1984 to 80% in 2004) likely introduced differential bias.
Sorenson et al, 2012^182^ | Probably yes | NA | No information | No | Some concerns | Classification of patients into groups based on self-report, but confidence in their report of supplement use increased because of periodic in-person clinic visits involving complete medication histories. Still, the stability of self-reported supplement use between clinic visits was uncertain (e.g., frequency of use might have varied across time).
Sun et al, 2011^183^ | Probably no | Probably yes | No information | No | High | Vit D supplement intake increased substantially over time in the NHS cohort, as calcium supplement intake increased by 49.5% from baseline through the Paik et al. (2014^181^) companion study.
Sun et al, 2011^184^ | No information | NA | No information | No information | Uncertain because no information | No information about supplement use other than the single questionnaire assessment about supplement use during the prior 1–2 years. Dose, duration and frequency not assessed.
Terry et al, 2002^185^ | Probably yes | NA | No information | No | Some concerns | Unclear to what extent hormone therapy or oral contraceptive use were balanced across the different calcium supplement intake groups, although case vs. control group differences were apparent for both.
Van Hemelrijck et al, 2013^189^ | No information | No information | No information | No | Uncertain because no information | No measures of ongoing supplement use.
Waterhouse et al, 2015^186^ | Probably no | Probably yes | No information | No | Some concerns | Cases more likely to recall use vs. nonuse of supplements, but unclear in what direction their improved recall might have biased the findings. No information about the distribution of cointerventions between different supplement intake dose groups.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | No information | No information | No information | No | Uncertain because no information | No information about calcium supplement use provided beyond what was recorded at baseline. Subjects were analyzed according to their baseline use.
Xiao et al, 2013^190^ | Probably no | No information | No information | Probably no | High | Baseline characteristics by supplement use were not provided. Use of supplements was measured by self-report on questionnaire; not clear how switches were handled in analysis.
Yang et al, 2016^191^ | Probably no | No information | No information | No | Uncertain because no information | None

Abbreviations: CVD=cardiovascular disease; vs.=versus.

Appendix E Table 13 Quality Ratings for Observational Studies: Part 7

Author, Year, Trial Name | Was measurement of harms outcomes unlikely to have been influenced by knowledge of the intervention received? | Were methods of harm outcome assessment comparable across groups? | Was the duration of followup adequate to assess harm outcomes? | Bias Arising From Measurement of Harms Outcomes | Comments
Ahn et al, 2007^166^ | Yes | Yes | Yes | Low | None
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Yes | Yes | Yes | Low | None
Cadeau et al, 2015^170^ | Probably yes | Yes | Yes | Low | None
Cauley et al, 2013^171^ | Probably no | Yes | Yes | Some concerns | Participants were unmasked at end of trial phase; outcomes initially collected by self-report, then confirmed with medical records. Potential for recall bias for self-reported outcomes given that participants were unmasked from their treatment assignment during the observational extension phase.
Chan et al, 2013^172^ | Yes | Yes | Yes | Low | None
Cheng et6 al, 2014^173^ | Yes | Yes | Yes | Low | None
Curhan et al, 1997^174^ | Probably yes | Yes | Yes | Low | Self-reported measures of kidney stones; however, random validity check of about 10% of participants’ kidney stone reports found nearly 100% concordance with medical records.
Flood et al, 2005^175^ | No information | Yes | Probably yes | Low | None
Langsetmo et al, 2013^176^ | Yes | Yes | Yes | Low | None
Li et al, 2012^177^ | No information | Probably yes | Yes | Low | None
Lin et al, 2005^178^ | Yes | Yes | Yes | Low | None
McCullough et al, 2003^179^ | Yes | Yes | Yes | Low | None
Michaelsson et al, 2013^180^ | Yes | Yes | Yes | Low | None
Paik et al, 2014^181^ | Yes | Yes | Yes | Low | Only outcome data verified as “confirmed” or “probable” by study investigators were used.
Sorenson et al, 2012^182^ | Probably yes | Yes | Yes | Some concerns | Self-reported outcome measures.
Sun et al, 2011^183^ | Yes | Yes | Yes | Low | Only outcome data verified as “confirmed” or “probable” by study investigators were used.
Sun et al, 2011^184^ | NA | NA | Probably no | Some concerns | Length of followup time may not be adequate.
Terry et al, 2002^185^ | NA | Yes | Probably no | Some concerns | Length of followup time may not be adequate.
Van Hemelrijck et al, 2013^189^ | Yes | Yes | Yes | Low | None
Waterhouse et al, 2015^186^ | NA | Yes | Probably no | Some concerns | Length of followup time may not be adequate.
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | Yes | Yes | Yes | Low | None
Xiao et al, 2013^190^ | Yes | Yes | Yes | Low | None
Yang et al, 2016^191^ | N/A | N/A | N/A | N/A | N/A

Appendix E Table 14 Quality Ratings for Observational Studies: Part 8

Author, Year, Trial Name | Is the reported effect estimate unlikely to be selected, on the basis of the results from multiple outcomes measurements within the domain, m ultiple analyses, or different subgroups? | Bias Arising From Selection of Reported Results | Comments
Ahn et al, 2007^166^ | Yes | Low | None
Bostick et al, 1993^167^ and Sellers et al, 1998^168^ and Mursu, 2011^169^ | Yes | Low | None
Cadeau et al, 2015^170^ | Yes | Low | None
Cauley et al, 2013^171^ | Yes | Low | None
Chan et al, 2013^172^ | Yes | Low | None
Cheng et al, 2014^173^ | Yes | Low | None
Curhan et al, 1997^174^ | Yes | Low | None
Flood et al, 2005^175^ | Yes | Low | None
Langsetmo et al, 2013^176^ | Yes | Low | None
Li et al, 2012^177^ | No | High | This rating applies to models B and C analyses only.
Lin et al, 2005^178^ | Yes | Low | None
Michaelsson et al, 2013^180^ | Yes | Low | None
McCullough et al, 2003^179^ | Yes | Low | None
Paik et al, 2014^181^ | Yes | Low | None
Sorenson et al, 2012^182^ | Probably no | Some concerns | Investigators did not report the results of the multivariate analysis for current calcium supplementation dose and nephrolithiasis, as they did for calcium supplement history. Likely a decision based on the lack of a statistically significant association.
Sun et al, 2011^183^ | Yes | Low | None
Sun et al, 2011^184^ | Yes | Low | None
Terry et al, 2002^185^ | Yes | Low | None
Van Hemelrijck et al, 2013^189^ | Yes | Low | None
Waterhouse et al, 2015^186^ | Yes | Low | None
Wilson et al, 2015^187^ and Kearney et al, 1996^188^ | Yes | Low | None
Xiao et al, 2013^190^ | Yes | Low | None
Yang et al, 2016^191^ | Yes | Low | None