# Appendix D Evidence Tables

Appendix D Table 1 Characteristics of RCTs Included in the Main Analysis and in Sensitivity Analysis for Vitamin D and Calcium Supplementation Benefits and Harms (KQs 1 and 2)

Appendix D Table 2 Benefits of Supplementation for Fracture Prevention From RCTs in the Main Analysis and in the Sensitivity Analysis (KQ 1)

Appendix D Table 3 Harms of Supplementation From RCTs in the Main Analysis and in the Sensitivity Analysis (KQ 2)

Appendix D Table 4 Other Harms of Supplementation From RCTs in the Main Analysis and in the Sensitivity Analysis