# Appendix C Excluded Studies

List of Exclusion Codes:

X1: Not original research

X2: Ineligible or no intervention

X3: Ineligible population

X4: Ineligible setting

X5: Ineligible or no outcomes

X6: Ineligible study design

X7: Ineligible or no comparator

X8: Ineligible timing

X9: Ineligible country

X10: Not published in English

X11: Study protocol

X12: Systematic reviews used to identify primary research articles

X13: Poor quality

1 Link between calcium supplements and heart attack risk unclear. Harv Womens Health Watch. 2010 Oct;18(2):6-7. Exclusion Code: X1.
2 Do vitamin D supplements affect mortality? Drug Ther Bull. 2011;49(9):100. Exclusion Code: X1.
3 Calcium and vitamin D supplements linked to raised CVD risk. Menopause International. 2011;17(2):38-9. Exclusion Code: X1.
4 Calcium supplements could increase heart attack risks. Harv Womens Health Watch. 2012 Aug;19(12):8. PMID: 23033553. Exclusion Code: X1.23033553
5 Calcium supplementation: Cardiovascular risk? Prescrire Int. 2013;22(139):152-3. Exclusion Code: X1.23866352
6 Abbas S, Linseisen J, Rohrmann S, . Dietary intake of vitamin D and calcium and breast cancer risk in the European Prospective Investigation into Cancer and Nutrition. Nutr Cancer. 2013;65(2):178-87. doi: 10.1080/01635581.2013.752018. PMID: 23441605. Exclusion Code: X2.23441605
7 Abdelaziz KM, Combe EC, Hodges JS. The effect of disinfectants on the properties of dental gypsum: 1. Mechanical properties. J Prosthodont. 2002 Sep;11(3):161-7. doi: S1059941X02000141 [pii]. PMID: 12237796. Exclus ion Code: X2.12237796
8 Ahn J, Albanes D, Peters U, . Dairy products, calcium intake, and risk of prostate cancer in the prostate, lung, colorectal, and ovarian cancer screening trial. Cancer Epidemiol Biomarkers Prev. 2007 Dec;16(12):2623-30. doi: 10.1158/1055-9965.epi-07-0601. PMID: 18086766. Exclusion Code: X13.18086766
9 Aigner E, Stadlmayr A, Huber-Schonauer U, . Gender- and site-specific differences of colorectal neoplasia relate to vitamin D. Aliment Pharmacol Ther. 2014 Dec;40(11-12):1341-8. doi: 10.1111/apt.12981. PMID: 25278035. Exclus ion Code: X6.25278035
10 Aloia JF, Talwar SA, Pollack S, . A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 2005 Jul 25;165(14):1618-23. doi: 10.1001/archinte.165.14.1618. PMID: 16043680. Exclus ion Code: X13.16043680
11 Amaral T, de Almeida MD, Barros H. Diet and colorectal cancer in Portugal. IARC Sci Publ. 2002;156:549-52. PMID: 12484258. Exclusion Code: X2.12484258
12 Anderson JJ, Kruszka B, Delaney JA, . Calcium intake from diet and supplements and the risk of coronary artery calcification and its progression among older adults: 10-year follow-up of the Multi-Ethnic Study of Atherosclerosis (MESA). J Am Heart Assoc. 2016 Oct 11;5(10)doi: 10.1161/JAHA.116.003815. PMID: 27729333. Exclus ion Code: X5.27729333
13 Arora P, Song Y, Dusek J, . Vitamin D therapy in individuals with prehypertension or hypertension: the DAYLIGHT trial. Circulation. 2015 Jan 20;131(3):254-62. doi: 10.1161/CIRCULATIONAHA.114.011732. PMID: 25359163. Exclusion Code: X5.25359163
14 Aune D, Navarro Rosenblatt DA, Chan DS, . Dairy products, calcium, and prostate cancer risk: a systematic review and metaanalysis of cohort studies. Am J Clin Nutr. 2015 Jan;101(1):87-117. doi: 10.3945/ajcn.113.067157. PMID: 25527754. Exclusion Code: X7.25527754
15 Autier P, Gandini S, Mullie P. A systematic review: influence of vitamin D supplementation on serum 25-hydroxyvitamin D concentration. J Clin Endocrinol Metab. 2012 Aug;97(8):2606-13. doi: 10.1210/jc.2012-1238. PMID: 22701014. Exclus ion Code: X12.22701014
16 Avenell A, MacLennan GS, Jenkinson DJ, . Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). J Clin Endocrinol Metab. 2012 Feb;97(2):614-22. doi: 10.1210/jc.2011-1309. PMID: 22112804. Exclusion Code: X3.22112804
17 Avenell A, Mak JC, O’Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database Syst Rev. 2014 Apr 14(4):CD000227. doi: 10.1002/14651858.CD000227.pub4. PMID: 24729336. Exclus ion Code: X2.24729336
18 Baron JA, Barry EL, Mott LA, . A Trial of Calcium and Vitamin D for the Prevention of Colorectal Adenomas. N Engl J Med. 2015 Oct 15;373(16):1519-30. doi: 10.1056/NEJMoa1500409. PMID: 26465985. Exclus ion Code: X7.26465985
19 Baron JA, Beach M, Mandel JS, . Calcium supplements for the prevention of colorectal adenomas. Calcium Polyp Prevention Study Group. N Engl J Med. 1999 Jan 14;340(2):101-7. doi: 10.1056/NEJM199901143400204. PMID: 9887161. Exclus ion Code: X3.9887161
20 Baron JA, Beach M, Wallace K, . Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 2005 Mar;14(3):586-9. doi: 10.1158/1055-9965.epi-04-0319. PMID: 15767334. Exclusion Code: X3.15767334
21 Baron JA, Tosteson TD, Wargovich MJ, . Calcium supplementation and rectal mucosal proliferation: a randomized controlled trial. J Natl Cancer Inst. 1995 Sep 6;87(17):1303-7. PMID: 7658482. Exclusion Code: X5.7658482
22 Bendich A, Leader S, Muhuri P. Supplemental calcium for the prevention of hip fracture: potential health-economic benefits. Clin Ther. 1999 Jun;21(6):1058-72. doi: 10.1016/S0149-2918(99)80024-1. PMID: 10440627. Exclusion Code: X1.10440627
23 Bergman GJ, Fan T, McFetridge JT, . Efficacy of vitamin D3 supplementation in preventing fractures in elderly women: a meta-analysis. Curr Med Res Opin. 2010 May;26(5):1193-201. doi: 10.1185/03007991003659814. PMID: 20302551. Exclus ion Code: X12.20302551
24 Bhakta M, Bruce C, Messika-Zeitoun D, . Oral calcium supplements do not affect the progression of aortic valve calcification or coronary artery calcification. J Am Board Fam Med. 2009 Nov-Dec;22(6):610-6. doi: 10.3122/jabfm.2009.06.080217. PMID: 19897688. Exclus ion Code: X5.19897688
25 Bidoli E, La Vecchia C, Talamini R, . Micronutrients and ovarian cancer: an Italian case-control study. IARC Sci Publ. 2002;156:357-60. PMID: 12484205. Exclusion Code: X2.12484205
26 Biel RK, Csizmadi I, Cook LS, . Risk of endometrial cancer in relation to individual nutrients from diet and supplements. Public Health Nutr. 2011 Nov;14(11):1948-60. doi: 10.1017/S1368980011001066. PMID: 21752313. Exclus ion Code: X6.21752313
27 Bischoff HA, Stahelin HB, Dick W, . Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Miner Res. 2003 Feb;18(2):343-51. doi: 10.1359/jbmr.2003.18.2.343. PMID: 12568412. Exclus ion Code: X3.12568412
28 Bischoff-Ferrari HA, Dawson-Hughes B, Orav EJ, . Monthly High-Dose Vitamin D Treatment for the Prevention of Functional Decline: A Randomized Clinical Trial. JAMA Intern Med. 2016 Feb;176(2):175-83. doi: 10.1001/jamainternmed.2015.7148. PMID: 26747333. Exclusion Code: X5.26747333
29 Bischoff-Ferrari HA, Orav EJ, Dawson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 2006 Feb 27;166(4):424-30. doi: 10.1001/archinte.166.4.424. PMID: 16505262. Exclus ion Code: X5.16505262
30 Bischoff-Ferrari HA, Willett WC, Orav EJ, . A pooled analysis of vitamin D dose requirements for fracture prevention. N Engl J Med. 2012 Jul 5;367(1):40-9. doi: 10.1056/NEJMoa1109617. PMID: 22762317. Exclusion Code: X12.22762317
31 Bischoff-Ferrari HA, Willett WC, Wong JB, . Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA. 2005 May 11;293(18):2257-64. doi: 10.1001/jama.293.18.2257. PMID: 15886381. Exclusion Code: X12.15886381
32 Bischoff-Ferrari HA, Willett WC, Wong JB, . Prevention of nonvertebral fractures with oral vitamin D and dose dependency: a meta-analysis of randomized controlled trials. Arch Intern Med. 2009 Mar 23;169(6):551-61. doi: 10.1001/archinternmed.2008.600. PMID: 19307517. Exclus ion Code: X12.19307517
33 Bjelakovic G, Gluud LL, Nikolova D, . Vitamin D supplementation for prevention of cancer in adults. Cochrane Database Syst Rev. 2014;6:CD007469. doi: 10.1002/14651858.CD007469.pub2. PMID: 24953955. Exclus ion Code: X2.24953955
34 Bjelakovic G, Gluud LL, Nikolova D, . Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2014;1:CD007470. doi: 10.1002/14651858.CD007470.pub3. PMID: 24414552. Exclusion Code: X8.24414552
35 Body JJ, Bergmann P, Boonen S, . Extraskeletal benefits and risks of calcium, vitamin D and anti-osteoporosis medications. Osteoporos Int. 2012 Feb;23 Suppl 1:S1-23. doi: 10.1007/s00198-011-1891-8. PMID: 22311111. Exclusion Code: X6.22311111
36 Bolland MJ, Avenell A, Baron JA, . Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ. 2010;341:c3691. doi: 10.1136/bmj.c3691. PMID: 20671013. Exclusion Code: X12.20671013
37 Bolland MJ, Barber PA, Doughty RN, . Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 2008 Feb 2;336(7638):262-6. doi: bmj.39440.525752.BE [pii]; 10.1136/bmj.39440.525752.BE [doi]. PMID: 18198394. Exclusion Code: X3.18198394
38 Bolland MJ, Grey A, Gamble GD, . The effect of vitamin D supplementation on skeletal, vascular, or cancer outcomes: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014 Apr;2(4):307-20. doi: 10.1016/S2213-8587(13)70212-2. PMID: 24703049. Exclus ion Code: X12.24703049
39 Bolland MJ, Grey A, Gamble GD, . Concordance of results from randomized and observational analyses within the same study: A re-analysis of the women’s health initiative limited-access dataset. PLoS One. 2015;10(10). Exclusion Code: X6.
40 Bolland MJ, Grey A, Reid IR. Calcium supplements and cardiovascular risk: 5 years on. Therapeutic Advances in Drug Safety. 2013;4(5):199-210. Exclusion Code: X6.25114781
41 Bolland MJ, Leung W, Tai V, . Calcium intake and risk of fracture: systematic review. BMJ. 2015;351:h4580. PMID: 26420387. Exclus ion Code: X12.26420387
42 Bolton-Smith C, McMurdo ME, Paterson CR, . Two-year randomized controlled trial of vitamin K1 (phylloquinone) and vitamin D3 plus calcium on the bone health of older women. J Bone Miner Res. 2007 Apr;22(4):509-19. doi: 10.1359/jbmr.070116. PMID: 17243866. Exclusion Code: X5.17243866
43 Bonithon-Kopp C, Kronborg O, Giacosa A, . Calcium and fibre supplementation in prevention of colorectal adenoma recurrence: a randomised intervention trial. European Cancer Prevention Organisation Study Group. Lancet. 2000 Oct 14;356(9238):1300-6. doi: S0140673600028130 [pii]. PMID: 11073017. Exclus ion Code: X5.11073017
44 Boonen S, Lips P, Bouillon R, . Need for additional calcium to reduce the risk of hip fracture with vitamin d supplementation: evidence from a comparative metaanalysis of randomized controlled trials. J Clin Endocrinol Metab. 2007 Apr;92(4):1415-23. doi: 10.1210/jc.2006-1404. PMID: 17264183. Exclus ion Code: X12.17264183
45 Bostick RM, Potter JD, Sellers TA, . Relation of calcium, vitamin D, and dairy food intake to incidence of colon cancer among older women. The Iowa Women’s Health Study. Am J Epidemiol. 1993 Jun 15;137(12):1302-17. PMID: 8333412. Exclusion Code: X13.8333412
46 Bristow SM, Bolland MJ, MacLennan GS, . Calcium supplements and cancer risk: a meta-analysis of randomised controlled trials. Br J Nutr. 2013 Oct;110(8):1384-93. doi: 10.1017/S0007114513001050. PMID: 23601861. Exclus ion Code: X12.23601861
47 Cadeau C, Fournier A, Mesrine S, . Interaction between current vitamin D supplementation and menopausal hormone therapy use on breast cancer risk: evidence from the E3N cohort. Am J Clin Nutr. 2015 Oct;102(4):966-73. doi: 10.3945/ajcn.114.104323. PMID: 26354532. Exclusion Code: X13.26354532
48 Candelas G, Martinez-Lopez JA, Rosario MP, . Calcium supplementation and kidney stone risk in osteoporosis: a systematic literature review. Clin Exp Rheumatol. 2012 Nov-Dec;30(6):954-61. . PMID: 23137489. Exclusion Code: X3.23137489
49 Carroll C, Cooper K, Papaioannou D, . Supplemental calcium in the chemoprevention of colorectal cancer: a systematic review and meta-analysis. Clin Ther. 2010 May;32(5):789-803. doi: 10.1016/j.clinthera.2010.04.024. PMID: 20685491. Exclusion Code: X3.20685491
50 Cauley JA, Chlebowski RT, Wactawski-Wende J, . Calcium plus vitamin D supplementation and health outcomes five years after active intervention ended: the Women’s Health Initiative. J Womens Health (Larchmt). 2013 Nov;22(11):915-29. doi: 10.1089/jwh.2013.4270. PMID: 24131320. Exclus ion Code: X13.24131320
51 Chan R, Leung J, Woo J. A prospective cohort study examining the associations of dietary calcium intake with all-cause and cardiovascular mortality in older Chinese community-dwelling people. PLoS One. 2013;8(11):e80895. doi: 10.1371/journal.pone.0080895. PMID: 24224062. Exclus ion Code: X13.24224062
52 Chapuy MC, Arlot ME, Delmas PD, . Effect of calcium and cholecalciferol treatment for three years on hip fractures in elderly women. Br Med J. 1994:1081-2. PMID: CN-00218546. Exclus ion Code: X3.8173430
53 Chapuy MC, Arlot Met a. Prevention of non vertebral fractures and cortical bone loss in elderly women: a prospective controlled trial using calcium and vitamin D3 supplements [abstract]. Osteoporos Int. 1993:258. PMID: CN-00259756. Exclus ion Code: X3.
54 Chapuy MC, Pamphile R, Paris E, . Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002(3):257-64. doi: 10.1007/s001980200023. PMID: CN-00379937. Exclus ion Code: X3.11991447
55 Chen F, Li Q, Yu Y, . Association of vitamin C, vitamin D, vitamin E and risk of bladder cancer: a dose-response meta-analysis. Sci Rep. 2015;5:9599. doi: 10.1038/srep09599. PMID: 25905583. Exclusion Code: X2.25905583
56 Cheng TY, Goodman GE, Thornquist MD, . Estimated intake of vitamin D and its interaction with vitamin A on lung cancer risk among smokers. Int J Cancer. 2014 Nov 1;135(9):2135-45. doi: 10.1002/ijc.28846. PMID: 24622914. Exclusion Code: X13.24622914
57 Cheng TY, Lacroix AZ, Beresford SA, . Vitamin D intake and lung cancer risk in the Women’s Health Initiative. Am J Clin Nutr. 2013 Oct;98(4):1002-11. doi: 10.3945/ajcn.112.055905. PMID: 23966428. Exclusion Code: X2.23966428
58 Cherniack EP, Florez HJ, Hollis BW, . The response of elderly veterans to daily vitamin D3 supplementation of 2,000 IU: a pilot efficacy study. J Am Geriatr Soc. 2011 Feb;59(2):286-90. doi: 10.1111/j.1532-5415.2010.03242.x. PMID: 21288233. Exclusion Code: X13.21288233
59 Chevalley T, Rizzoli R, Nydegger V, . Effects of calcium supplements on femoral bone mineral density and vertebral fracture rate in vitamin-D-replete elderly patients. Osteoporos Int. 1994 Sep;4(5):245-52. PMID: 7812072. Exclusion Code: X5.7812072
60 Cho E, Smith-Warner SA, Spiegelman D, . Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. J Natl Cancer Inst. 2004 Jul 7;96(13):1015-22. PMID: 15240785. Exclusion Code: X2.15240785
61 Chowdhury R, Kunutsor S, Vitezova A, . Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348:g1903. PMID: 24690623. Exclusion Code: X2.24690623
62 Chung M, Balk EM, Brendel M, . Vitamin D and calcium: a systematic review of health outcomes. Evid Rep Technol Assess (Full Rep). 2009 Aug(183):1-420. PMID: 20629479. Exclusion Code: X12.20629479
63 Chung M, Lee J, Terasawa T, . Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2011 Dec 20;155(12):827-38. doi: 10.7326/0003-4819-155-12-201112200-00005. PMID: 22184690. Exclusion Code: X12.22184690
64 Chung M, Lee J, Terasawa T, . Correction: Vitamin D with or without calcium supplementation for prevention of cancer and fractures. Ann Intern Med. 2014;161(8):615. doi: 10.7326/L14-5020-7. Exclusion Code: X12.
65 Chung M, Tang AM, Fu Z, . Calcium intake and cardiovascular disease risk: an updated systematic review and metaanalysis. Ann Intern Med. 2016 Dec 20;165(12):856-66. doi: 10.7326/M16-1165. PMID: 27776363. Exclusion Code: X12.27776363
66 Clarke R, Newman C, Tomson J, . Estimation of the optimum dose of vitamin D for disease prevention in older people: rationale, design and baseline characteristics of the BEST-D trial. Maturitas. 2015 Apr;80(4):426-31. doi: 10.1016/j.maturitas.2015.01.013. PMID: 25721698. Exclus ion Code: X11.25721698
67 Clemmesen B, Ravn P, Zegels B, . A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int. 1997;7(5):488-95. PMID: 9425508. Exclusion Code: X2.9425508
68 Cooper K, Squires H, Carroll C, . Chemoprevention of colorectal cancer: systematic review and economic evaluation. Health Technol Assess. 2010 Jun;14(32):1-206. doi: 10.3310/hta14320. PMID: 20594533. Exclus ion Code: X3.20594533
69 Cooper L, Clifton-Bligh PB, Nery ML, . Vitamin D supplementation and bone mineral density in early postmenopausal women. Am J Clin Nutr. 2003 May;77(5):1324-9. PMID: 12716689. Exclusion Code: X5.12716689
70 Cranney A, Horsley T, O’Donnell S, . Effectiveness and safety of vitamin D in relation to bone health. Evid Rep Technol Assess (Full Rep). 2007 Aug(158):1-235. PMID: 18088161. Exclusion Code: X12.18088161
71 Cumming RG, Nevitt MC. Calcium for prevention of osteoporotic fractures in postmenopausal women. J Bone Miner Res. 1997 Sep;12(9):1321-9. doi: 10.1359/jbmr.1997.12.9.1321. PMID: 9286747. Exclus ion Code: X6.9286747
72 Curhan GC, Willett WC, Speizer FE, . Comparison of dietary calcium with supplemental calcium and other nutrients as factors affecting the risk for kidney stones in women. Ann Intern Med. 1997 Apr 1;126(7):497-504. PMID: 9092314. Exclusion Code: X13.9092314
73 Dawson-Hughes B, Dallal GE, Krall EA, . A controlled trial of the effect of calcium supplementation on bone density in postmenopausal women. N Engl J Med. 1990 Sep 27;323(13):878-83. doi: 10.1056/nejm199009273231305. PMID: 2203964. Exclus ion Code: X5.2203964
74 de Courten B, Mousa A, Naderpoor N, . Vitamin D supplementation for the prevention of type 2 diabetes in overweight adults: study protocol for a randomized controlled trial. Trials. 2015;16:335. doi: 10.1186/s13063-015-0851-6. PMID: 26246241. Exclus ion Code: X5.26246241
75 Dennehy C, Tsourounis C. A review of select vitamins and minerals used by postmenopausal women. Maturitas. 2010 Aug;66(4):370-80. doi: 10.1016/j.maturitas.2010.06.003. PMID: 20580500. Exclusion Code: X6.20580500
76 Dik VK, Murphy N, Siersema PD, . Prediagnostic intake of dairy products and dietary calcium and colorectal cancer survival--results from the EPIC cohort study. Cancer Epidemiol Biomarkers Prev. 2014 Sep;23(9):1813-23. doi: 10.1158/1055-9965.EPI-14-0172. PMID: 24917183. Exclusion Code: X2.24917183
77 Domrongkitchaiporn S, Sopassathit W, Stitchantrakul W, . Schedule of taking calcium supplement and the risk of nephrolithiasis. Kidney Int. 2004 May;65(5):1835-41. doi: 10.1111/j.1523-1755.2004.00587.x. PMID: 15086924. Exclusion Code: X5.15086924
78 Downing L, Islam MA. Influence of calcium supplements on the occurrence of cardiovascular events. Am J Health Syst Pharm. 2013 Jul 1;70(13):1132-9. doi: 10.2146/ajhp120421. PMID: 23784160. Exclusion Code: X6.23784160
79 Edvardsen K, Veierod MB, Brustad M, . Vitamin D-effective solar UV radiation, dietary vitamin D and breast cancer risk. Int J Cancer. 2011 Mar 15;128(6):1425-33. doi: 10.1002/ijc.25463. PMID: 20473950. Exclusion Code: X2.20473950
80 Elders PJ, Netelenbos JC, Lips P, . Calcium supplementation reduces vertebral bone loss in perimenopausal women: a controlled trial in 248 women between 46 and 55 years of age. J Clin Endocrinol Metab. 1991 Sep;73(3):533-40. doi: 10.1210/jcem-73-3-533. PMID: 1874931. Exclusion Code: X5.1874931
81 Espaulella J, Guyer H, Diaz-Escriu F, . Nutritional supplementation of elderly hip fracture patients. A randomized, double-blind, placebo-controlled trial. Age Ageing. 2000 Sep;29(5):425-31. PMID: 11108415. Exclusion Code: X3.11108415
82 Flicker L, MacInnis RJ, Stein MS, . Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. J Am Geriatr Soc. 2005 Nov;53(11):1881-8. doi: 10.1111/j.1532-5415.2005.00468.x. PMID: 16274368. Exclusion Code: X3.16274368
83 Flood A, Peters U, Chatterjee N, . Calcium from diet and supplements is associated with reduced risk of colorectal cancer in a prospective cohort of women. Cancer Epidemiol Biomarkers Prev. 2005 Jan;14(1):126-32. . PMID: 15668485. Exclus ion Code: X13.15668485
84 Ford JA, MacLennan G, Bolland MJ, . Vitamin d supplementation prevents cardiac failure; MRC record trial analysis, systematic review and meta-analysis. Circulation. 2012;126(21). Exclusion Code: X3.
85 Ford JA, MacLennan GS, Avenell A, . Cardiovascular disease and vitamin D supplementation: trial analysis, systematic review, and meta-analysis. Am J Clin Nutr. 2014 Sep;100(3):746-55. doi: 10.3945/ajcn.113.082602. PMID: 25057156. Exclusion Code: X12.25057156
86 Fortmann SP, Burda BU, Senger CA, . Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville MD; 2013. Exclusion Code: X12.
87 Franco A, Sikalidis AK, Solis Herruzo JA. Colorectal cancer: influence of diet and lifestyle factors. Rev Esp Enferm Dig. 2005 Jun;97(6):432-48. PMID: 16011418. Exclusion Code: X1.16011418
88 Fry CM, Sanders TA. Vitamin D and risk of CVD: a review of the evidence. Proc Nutr Soc. 2015 Aug;74(3):245-57. doi: 10.1017/S0029665115000014. PMID: 25697289. Exclus ion Code: X1.25697289
89 Gallagher JC, Smith LM, Yalamanchili V. Incidence of hypercalciuria and hypercalcemia during vitamin D and calcium supplementation in older women. Menopause. 2014 Nov;21(11):1173-80. doi: 10.1097/GME.0000000000000270. PMID: 24937025. Exclus ion Code: X3.24937025
90 Galloe AM, Graudal N, Moller J, . Effect of oral calcium supplementation on blood pressure in patients with previously untreated hypertension: a randomised, double-blind, placebo-controlled, crossover study. J Hum Hypertens. 1993 Feb;7(1):43-5. PMID: 8450520. Exclusion Code: X3.8450520
91 Gao X, LaValley MP, Tucker KL. Prospective studies of dairy product and calcium intakes and prostate cancer risk: a meta-analysis. J Natl Cancer Inst. 2005 Dec 7;97(23):1768-77. doi: 10.1093/jnci/dji402. PMID: 16333032. Exclusion Code: X2.16333032
92 Garland CF, French CB, Baggerly LL, . Vitamin D supplement doses and serum 25-hydroxyvitamin D in the range associated with cancer prevention. Anticancer Res. 2011 Feb;31(2):607-11. . PMID: 21378345. Exclusion Code: X5.21378345
93 Geleijnse JM. Vitamin D and the prevention of hypertension and cardiovascular diseases: a review of the current evidence. AmJ Hypertens. 2011 Mar;24(3):253-62. doi: 10.1038/ajh.2010.199. PMID: 20847727. Exclusion Code: X6.20847727
94 George AL, Jr., Folk BP, 3rd, Crecelius PL, . Calcium and cardiac arrest. Ann Intern Med. 1987 Mar;106(3):472-3. PMID: 3813244. Exclus ion Code: X1.3813244
95 Giammanco M, Di Majo D, La Guardia M, . Vitamin D in cancer chemoprevention. Pharm Biol. 2015;53(10):1399-434. doi: 10.3109/13880209.2014.988274. PMID: 25856702. Exclus ion Code: X1.25856702
96 Glendenning P, Zhu K, Inderjeeth C, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012 Jan;27(1):170-6. doi: 10.1002/jbmr.524. PMID: 21956713. Exclusion Code: X13.21956713
97 Gök H. Does calcium supplementation with or without vitamin D increase the risk of cardiovascular disease? Turkish Journal of Rheumatology. 2012;27(2):77-8. Exclusion Code: X1.
98 Gotsman I, Shauer A, Zwas DR, . Vitamin D deficiency is a predictor of reduced survival in patients with heart failure; vitamin D supplementation improves outcome. Eur J Heart Fail. 2012 Apr;14(4):357-66. doi: 10.1093/eurjhf/hfr175. PMID: 22308011. Exclusion Code: X6.22308011
99 Grant AM, Avenell A, Campbell MK, . Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005 May 7-13;365(9471):1621-8. doi: 10.1016/s0140-6736(05)63013-9. PMID: 15885294. Exclus ion Code: X3.15885294
100 Grobbee DE, Hofman A. Effect of calcium supplementation on diastolic blood pressure in young people with mild hypertension. Lancet. 1986 Sep 27;2(8509):703-7. doi: S0140-6736(86)90228-X [pii]. PMID: 2876183. Exclus ion Code: X5.2876183
101 Harris SS, Dawson-Hughes B. Effects of Hydration and Calcium Supplementation on Urine Calcium Concentration in Healthy Postmenopausal Women. J Am Coll Nutr. 2015;34(4):340-6. doi: 10.1080/07315724.2014.959207. PMID: 25856469. Exclus ion Code: X5.25856469
102 Harwood RH, Sahota O, Gaynor K, . A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. 2004 Jan;33(1):45-51. PMID: 14695863. Exclusion Code: X3.14695863
103 Heaney RP. Calcium supplementation and incident kidney stone risk: a systematic review. J Am Coll Nutr. 2008 Oct;27(5):519-27. . PMID: 18845701. Exclusion Code: X12.18845701
104 Heine-Broring RC, Winkels RM, Renkema JM, . Dietary supplement use and colorectal cancer risk: a systematic review and meta-analyses of prospective cohort studies. Int J Cancer. 2015 May 15;136(10):2388-401. doi: 10.1002/ijc.29277. PMID: 25335850. Exclusion Code: X8.25335850
105 Hin H, Tomson J, Newman C, . Optimum dose of vitamin D for disease prevention in older people: bEST-D trial of vitamin D in primary care. Osteoporos Int; 2017. p. 1-11. Exclusion Code: X3.
106 Hyman J, Baron JA, Dain BJ, . Dietary and supplemental calcium and the recurrence of colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 1998 Apr;7(4):291-5. PMID: 9568783. Exclusion Code: X2.9568783
107 Inkovaara J, Gothoni G, Halttula R, . Calcium, vitamin D and anabolic steroid in treatment of aged bones: double-blind placebo-controlled long-term clinical trial. Age Ageing. 1983 May;12(2):124-30. PMID: 6346829. Exclusion Code: X3.6346829
108 Iso H, Stampfer MJ, Manson JE, . Prospective study of calcium, potassium, and magnesium intake and risk of stroke in women. Stroke. 1999 Sep;30(9):1772-9. PMID: 10471422. Exclusion Code: X2.10471422
109 Jackson C, Gaugris S, Sen SS, . The effect of cholecalciferol (vitamin D3) on the risk of fall and fracture: a meta-analysis. QJM. 2007 Apr;100(4):185-92. doi: 10.1093/qjmed/hcm005. PMID: 17308327. Exclusion Code: X12.17308327
110 Jacobs ET, Thomson CA, Flatt SW, . Vitamin D and breast cancer recurrence in the Women’s Healthy Eating and Living (WHEL) Study. Am J Clin Nutr. 2011 Jan;93(1):108-17. doi: 10.3945/ajcn.2010.30009. PMID: 20980485. Exclusion Code: X3.20980485
111 Jarvinen R, Knekt P, Hakulinen T, . Prospective study on milk products, calcium and cancers of the colon and rectum. Eur J Clin Nutr. 2001 Nov;55(11):1000-7. doi: 10.1038/sj.ejcn.1601260. PMID: 11641750. Exclusion Code: X2.11641750
112 Jorde R, Sneve M, Figenschau Y, . Effects of vitamin D supplementation on symptoms of depression in overweight and obese subjects: randomized double blind trial. J Intern Med. 2008 Dec;264(6):599-609. doi: 10.1111/j.1365-2796.2008.02008.x. PMID: 18793245. Exclusion Code: X5.18793245
113 Kaluza J, Orsini N, Levitan EB, . Dietary calcium and magnesium intake and mortality: a prospective study of men. Am J Epidemiol. 2010 Apr 1;171(7):801-7. doi: 10.1093/aje/kwp467. PMID: 20172919. Exclusion Code: X2.20172919
114 Karanja N, McCarron DA. Calcium and hypertension. Annu Rev Nutr. 1986;6:475-94. doi: 10.1146/annurev.nu.06.070186.002355. PMID: 2425832. Exclusion Code: X5.2425832
115 Karkkainen M, Tuppurainen M, Salovaara K, . Effect of calcium and vitamin D supplementation on bone mineral density in women aged 65-71 years: a 3-year randomized population-based trial (OSTPRE-FPS). Osteoporos Int. 2010 Dec;21(12):2047-55. doi: 10.1007/s00198-009-1167-8. PMID: 20204604. Exclusion Code: X5.20204604
116 Karkkainen MK, Tuppurainen M, Salovaara K, . Does daily vitamin D 800 IU and calcium 1000 mg supplementation decrease the risk of falling in ambulatory women aged 65-71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010 Apr;65(4):359-65. doi: 10.1016/j.maturitas.2009.12.018. PMID: 20060665. Exclus ion Code: X5.20060665
117 Kearney J, Giovannucci E, Rimm EB, . Calcium, vitamin D, and dairy foods and the occurrence of colon cancer in men. Am J Epidemiol. 1996 May 1;143(9):907-17. PMID: 8610704. Exclusion Code: X13.8610704
118 Keum N, Aune D, Greenwood DC, . Calcium intake and colorectal cancer risk: dose-response meta-analysis of prospective observational studies. Int J Cancer. 2014 Oct 15;135(8):1940-8. doi: 10.1002/ijc.28840. PMID: 24623471. Exclusion Code: X3.24623471
119 Keum N, Lee DH, Greenwood DC, . Calcium intake and colorectal adenoma risk: dose-response meta-analysis of prospective observational studies. Int J Cancer. 2015 Apr 1;136(7):1680-7. doi: 10.1002/ijc.29164. PMID: 25156950. Exclusion Code: X5.25156950
120 Korownyk C, Ivers N, Allan GM. Does calcium supplementation increase risk of myocardial infarction? Can Fam Physician. 2011;57(7):798. Exclusion Code: X1.21753105
121 Kuehn BM. High calcium intake linked to heart disease, death. JAMA. 2013 Mar 13;309(10):972. doi: 10.1001/jama.2013.2123. PMID: 23483151. Exclusion Code: X1.23483151
122 Kunutsor SK, Apekey TA, Steur M. Vitamin D and risk of future hypertension: meta-analysis of 283,537 participants. Eur J Epidemiol. 2013 Mar;28(3):205-21. doi: 10.1007/s10654-013-9790-2. PMID: 23456138. Exclus ion Code: X2.23456138
123 Langsetmo L, Berger C, Kreiger N, . Calcium and vitamin D intake and mortality: results from the Canadian Multicentre Osteoporosis Study (CaMos). J Clin Endocrinol Metab. 2013 Jul;98(7):3010-8. doi: 10.1210/jc.2013-1516. PMID: 23703722. Exclus ion Code: X13.23703722
124 Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: a pragmatic population-based 3-year intervention study. J Bone Miner Res. 2004 Mar;19(3):370-8. doi: 10.1359/jbmr.0301240. PMID: 15040824. Exclus ion Code: X13.15040824
125 Larsen T, Mose FH, Bech JN, . Effect of cholecalciferol supplementation during winter months in patients with hypertension: a randomized, placebo-controlled trial. Am J Hypertens. 2012 Nov;25(11):1215-22. doi: 10.1038/ajh.2012.111. PMID: 22854639. Exclusion Code: X5.22854639
126 Larsson SC, Orsini N, Wolk A. Dietary calcium intake and risk of stroke: a dose-response meta-analysis. Am J Clin Nutr. 2013 May;97(5):951-7. doi: 10.3945/ajcn.112.052449. PMID: 23553167. Exclusion Code: X2.23553167
127 Law M, Withers H, Morris J, . Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing. 2006 Sep;35(5):482-6. doi: 10.1093/ageing/afj080. PMID: 16641143. Exclusion Code: X3.16641143
128 LeBoff MS, Yue AY, Copeland T, . VITAL-Bone Health: rationale and design of two ancillary studies evaluating the effects of vitamin D and/or omega-3 fatty acid supplements on incident fractures and bone health outcomes in the VITamin D and OmegA-3 TriaL (VITAL). Contemp Clin Trials. 2015:259-68. doi: 10.1016/j.cct.2015.01.007. PMID: CN-01110871. Exclus ion Code: X11.25623291
129 Lewis JR, Calver J, Zhu K, . Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res. 2011 Jan;26(1):35-41. doi: 10.1002/jbmr.176 [doi]. PMID: 20614474. Exclusion Code: X3.20614474
130 Lewis JR, Radavelli-Bagatini S, Rejnmark L, . The effects of calcium supplementation on verified coronary heart disease hospitalization and death in postmenopausal women: a collaborative meta-analysis of randomized controlled trials. J Bone Miner Res. 2015 Jan;30(1):165-75. doi: 10.1002/jbmr.2311. PMID: 25042841. Exclusion Code: X12.25042841
131 Li J, Koh WP, Jin AZ, . Calcium intake is not related to breast cancer risk among Singapore Chinese women. Int J Cancer. 2013 Aug 1;133(3):680-6. doi: 10.1002/ijc.28027. PMID: 23319293. Exclusion Code: X2.23319293
132 Li K, Kaaks R, Linseisen J, . Associations of dietary calcium intake and calcium supplementation with myocardial infarction and stroke risk and overall cardiovascular mortality in the Heidelberg cohort of the European Prospective Investigation into Cancer and Nutrition study (EPIC-Heidelberg). Heart. 2012 Jun;98(12):920-5. doi: 10.1136/heartjnl-2011-301345. PMID: 22626900. Exclusion Code: X13.22626900
133 Lin J, Zhang SM, Cook NR, . Intakes of calcium and vitamin D and risk of colorectal cancer in women. Am J Epidemiol. 2005 Apr 15;161(8):755-64. doi: 10.1093/aje/kwi101. PMID: 15800268. Exclusion Code: X13.15800268
134 López-Torres Hidalgo J. Prevention of falls and fractures in old people by administration of calcium and vitamin D, randomized clinical trial. BMC Public Health. 2011:910. doi: 10.1186/1471-2458-11-910. PMID: CN-00860468. Exclus ion Code: X11.22151975
135 Lyons RA, Johansen A, Brophy S, . Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int. 2007 Jun;18(6):811-8. doi: 10.1007/s00198-006-0309-5. PMID: 17473911. Exclus ion Code: X3.17473911
136 Ma Y, Zhang P, Wang F, . Association between vitamin D and risk of colorectal cancer: a systematic review of prospective studies. J Clin Oncol. 2011 Oct 1;29(28):3775-82. doi: 10.1200/JCO.2011.35.7566. PMID: 21876081. Exclus ion Code: X2.21876081
137 Macdonald HM, Wood AD, Aucott LS, . Hip bone loss is attenuated with 1000 IU but not 400 IU daily vitamin D3: a 1-year double-blind RCT in postmenopausal women. J Bone Miner Res. 2013 Oct;28(10):2202-13. doi: 10.1002/jbmr.1959. PMID: 23585346. Exclusion Code: X5.23585346
138 MacLean C, Newberry S, Maglione M, . Systematic review: comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis. Ann Intern Med. 2008 Feb 5;148(3):197-213. PMID: 18087050. Exclus ion Code: X12.18087050
139 Mak JCS, Cameron ID, Mason RS, . Improving mobilityand reducing disability in older people through early high-dose vitamin D replacement following hip fracture (the revitahip trial): Preliminary results. Osteoporos Int. 2011;22((Mak J.C.S.; Soong M.; Ohn K.) Department of Geriatric Medicine, Central Coast Health, Gosford Hospital, Gosford, Australia):S586-S7. Exclusion Code: X3.
140 Mak JCS, Mason R, Klein L, . Improving mobility and reducing disability in older people through early high-dose vitamin d replacement following hip fracture: a protocol for a randomized controlled trial and economic evaluation. Geriatric Orthopaedic Surgery and Rehabilitation. 2011(3):94-9. doi: 10.1177/2151458511406723. PMID: CN-00906724. Exclus ion Code: X3.23569677
141 Malihi Z, Wu Z, Stewart AW, . Hypercalcemia, hypercalciuria, and kidney stones in long-term studies of vitamin D supplementation: a systematic review and meta-analysis. Am J Clin Nutr. 2016 Sep 7doi: 10.3945/ajcn.116.134981. PMID: 27604776. Exclusion Code: X12.27604776
142 Manson JE, Bassuk SS, Lee IM, . The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012 Jan;33(1):159-71. doi: 10.1016/j.cct.2011.09.009. PMID: 21986389. Exclus ion Code: X11.21986389
143 Mao PJ, Zhang C, Tang L, . Effect of calcium or vitamin D supplementation on vascular outcomes: a meta-analysis of randomized controlled trials. Int J Cardiol. 2013 Oct 30;169(2):106-11. doi: 10.1016/j.ijcard.2013.08.055. PMID: 24035175. Exclus ion Code: X3.24035175
144 Martinez ME, Giovannucci EL, Colditz GA, . Calcium, vitamin D, and the occurrence of colorectal cancer among women. J Natl Cancer Inst. 1996 Oct 2;88(19):1375-82. PMID: 8827015. Exclusion Code: X2.8827015
145 McAlindon T, LaValley M, Schneider E, . Effect of vitamin D supplementation on progression of knee pain and cartilage volume loss in patients with symptomatic osteoarthritis: a randomized controlled trial. JAMA. 2013 Jan 9;309(2):155-62. doi: 10.1001/jama.2012.164487. PMID: 23299607. Exclus ion Code: X2.23299607
146 McCarron DA, Morris CD. Blood pressure response to oral calcium in persons with mild to moderate hypertension. A randomized, double-blind, placebo-controlled, crossover trial. Ann Intern Med. 1985 Dec;103(6 (Pt 1)):825-31. PMID: 3904559. Exclus ion Code: X5.3904559
147 McCullough ML, Robertson AS, Rodriguez C, . Calcium, vitamin D, dairy products, and risk of colorectal cancer in the Cancer Prevention Study II Nutrition Cohort (United States). Cancer Causes Control. 2003 Feb;14(1):1-12. PMID: 12708719. Exclusion Code: X13.12708719
148 Meier C, Woitge HW, Witte K, . Supplementation with oral vitamin D3 and calcium during winter prevents seasonal bone loss: a randomized controlled open-label prospective trial. J Bone Miner Res. 2004 Aug;19(8):1221-30. doi: 10.1359/jbmr.040511. PMID: 15231008. Exclusion Code: X5.15231008
149 Menon M. A prospective study of dietary calcium and other nutrients and the risk of symptomatic kidney stones. J Urol. 1993 Aug;150(2 Pt 1):563-4. PMID: 8326599. Exclusion Code: X1.8326599
150 Menon VB, Baxmann AC, Froeder L, . Effects of calcium supplementation on body weight reduction in overweight calcium stone formers. Urol Res. 2009 Jun;37(3):133-9. doi: 10.1007/s00240-009-0187-3. PMID: 19326108. Exclusion Code: X3.19326108
151 Meredith AJ, McManus BM. Vitamin D in heart failure. J Card Fail. 2013 Oct;19(10):692-711. doi: 10.1016/j.cardfail.2013.09.002. PMID: 24125108. Exclus ion Code: X1.24125108
152 Messenger W, Nielson CM, Li H, . Serum and dietary vitamin D and cardiovascular disease risk in elderly men: a prospective cohort study. Nutr Metab Cardiovasc Dis. 2012 Oct;22(10):856-63. doi: 10.1016/j.numecd.2010.10.019. PMID: 21466949. Exclus ion Code: X6.21466949
153 Meyer HE, Smedshaug GB, Kvaavik E, . Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res. 2002 Apr;17(4):709-15. doi: 10.1359/jbmr.2002.17.4.709. PMID: 11918228. Exclus ion Code: X3.11918228
154 Michael YL, Whitlock EP, Lin JS, . Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010 Dec 21;153(12):815-25. doi: 10.7326/0003-4819-153-12-201012210-00008. PMID: 21173416. Exclus ion Code: X12.21173416
155 Michaelsson K, Melhus H, Warensjo Lemming E, . Long term calcium intake and rates of all cause and cardiovascular mortality: community based prospective longitudinal cohort study. BMJ. 2013;346:f228. PMID: 23403980. Exclusion Code: X13.23403980
156 Murad MH, Drake MT, Mullan RJ, . Clinical review. Comparative effectiveness of drug treatments to prevent fragility fractures: a systematic review and network meta-analysis. J Clin Endocrinol Metab. 2012 Jun;97(6):1871-80. doi: 10.1210/jc.2011-3060. PMID: 22466336. Exclusion Code: X3.22466336
157 Mursu J, Robien K, Harnack LJ, . Dietary supplements and mortality rate in older women: the Iowa Women’s Health Study. Arch Intern Med. 2011 Oct 10;171(18):1625-33. doi: 10.1001/archinternmed.2011.445. PMID: 21987192. Exclus ion Code: X13.21987192
158 Newberry SJ, Chung M, Shekelle PG, . Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update) Evidence Report/Technology Assessment No. 217. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2012-00006-I.) AHRQ Publication No. 14-E004-EF. Rockville, MD: Agency for Healthcare Research and Quality; September 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm Exclusion Code: X12.
159 Ng K, Scott JB, Drake BF, . Dose response to vitamin D supplementation in African Americans: results of a 4-arm, randomized, placebo-controlled trial. Am J Clin Nutr. 2014 Mar;99(3):587-98. doi: 10.3945/ajcn.113.067777. PMID: 24368437. Exclusion Code: X5.24368437
160 Nordin BE, Lewis JR, Daly RM, . The calcium scare--what would Austin Bradford Hill have thought? Osteoporos Int. 2011 Dec;22(12):3073-7. doi: 10.1007/s00198--011-1680-4. PMID: 21633827. Exclusion Code: X1.21633827
161 Nuti R. Calcium supplementation and risk of cardiovascular disease. Clinical Cases in Mineral and Bone Metabolism. 2012;9(3):133-4. Exclusion Code: X6.23289023
162 Ohta H, Sugimoto I, Masuda A, . Decreased bone mineral density associated with early menopause progresses for at least ten years: cross-sectional comparisons between early and normal menopausal women. Bone. 1996 Mar;18(3):227-31. . PMID: 8703577. Exclusion Code: X2.8703577
163 Ooms ME, Roos JC, Bezemer PD, . Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. 1995 Apr;80(4):1052-8. doi: 10.1210/jcem.80.4.7714065. PMID: 7714065. Exclusion Code: X5.7714065
164 Osafi J, Hejazi A, Stutz DD, . Differential effects of 1,25-dihydroxyvitamin D(3) on oral squamous cell carcinomas in vitro. J Diet Suppl. 2014 Jun;11(2):145-54. doi: 10.3109/19390211.2013.859209. PMID: 24670118. Exclus ion Code: X2.24670118
165 Overton ET, Chan ES, Brown TT, . High-Dose Vitamin D and Calcium Attenuates Bone Loss With ART Initiation: Results From ACTG A5280. Top Antivir Med; 2014. p. 66-7. Exclusion Code: X3.
166 Paik JM, Curhan GC, Sun Q, . Calcium supplement intake and risk of cardiovascular disease in women. Osteoporos Int. 2014 Aug;25(8):2047-56. doi: 10.1007/s00198-014-2732-3. PMID: 24803331. Exclusion Code: X13.24803331
167 Payne ME, McQuoid DR, Steffens DC, . Elevated brain lesion volumes in older adults who use calcium supplements: a cross-sectional clinical observational study. Br J Nutr. 2014 Jul 28;112(2):220-7. doi: 10.1017/S0007114514000828. PMID: 24787048. Exclus ion Code: X5.24787048
168 Peacock M, Liu G, Carey M, . Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab; 2000. p. 3011-9. Exclusion Code: X13.10999778
169 Peters U, Chatterjee N, McGlynn KA, . Calcium intake and colorectal adenoma in a US colorectal cancer early detection program. Am J Clin Nutr. 2004 Nov;80(5):1358-65. . PMID: 15531687. Exclusion Code: X5.15531687
170 Pfeifer M, Begerow B, Minne HW, . Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000 Jun;15(6):1113-8. doi: 10.1359/jbmr.2000.15.6.1113. PMID: 10841179. Exclus ion Code: X3.10841179
171 Pfeifer M, Begerow B, Minne HW, . Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009 Feb;20(2):315-22. doi: 10.1007/s00198-008-0662-7. PMID: 18629569. Exclus ion Code: X3.18629569
172 Pilz S, Gaksch M, Kienreich K, . Effects of vitamin D on blood pressure and cardiovascular risk factors: a randomized controlled trial. Hypertension. 2015 Jun;65(6):1195-201. doi: 10.1161/HYPERTENSIONAHA.115.05319. PMID: 25801871. Exclusion Code: X3.25801871
173 Poole CD, Smith JC, Davies JS. The short-term impact of vitamin D-based hip fracture prevention in older adults in the United Kingdom. J Endocrinol Invest. 2014;37(9):811-7. Exclusion Code: X6.24957166
174 Pop LC, Sukumar D, Schneider SH, . Three doses of vitamin D, bone mineral density, and geometry in older women during modest weight control in a 1-year randomized controlled trial. Osteoporos Int; 2017. p. 377-88. Exclusion Code: X5.27535752
175 Porthouse J, Cockayne S, King C, . Randomised controlled trial of supplementation with calcium and cholecalciferol (vitamin D3) for prevention of fractures in primary care. Br Med J. 2005(7498):1003-6. PMID: CN-00569278. Exclusion Code: X3.15860827
176 Pradhan AD, Manson JE. Update on the Vitamin D and OmegA-3 trial (VITAL). J Steroid Biochem Mol Biol. 2016 Jan;155(Pt B):252-6. doi: 10.1016/j.jsbmb.2015.04.006. PMID: 25864623. Exclusion Code: X11.26277096
177 Prietl B, Treiber G, Mader JK, . High-dose cholecalciferol supplementation significantly increases peripheral CD4(+) Tregs in healthy adults without negatively affecting the frequency of other immune cells. Eur J Nutr. 2014 Apr;53(3):751-9. doi: 10.1007/s00394-013-0579-6. PMID: 23999998. Exclus ion Code: X5.23999998
178 Prince RL, Austin N, Devine A, . Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008 Jan 14;168(1):103-8. doi: 10.1001/archinternmed.2007.31. PMID: 18195202. Exclus ion Code: X3.18195202
179 Prince RL, Devine A, Dhaliwal SS, . Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med. 2006 Apr 24;166(8):869-75. ; 10.1001/archinte.166.8.869 [doi]. PMID: 16636212. Exclusion Code: X3.16636212
180 Punthakee Z, Bosch J, Dagenais G, . Design, history and results of the Thiazolidinedione Intervention with vitamin D Evaluation (TIDE) randomised controlled trial. Diabetologia. 2012 Jan;55(1):36-45. doi: 10.1007/s00125-011-2357-4. PMID: 22038523. Exclusion Code: X1.22038523
181 Rabenda V, Bruyere O, Reginster JY. Relationship between bone mineral density changes and risk of fractures among patients receiving calcium with or without vitamin D supplementation: a meta-regression. Osteoporos Int. 2011 Mar;22(3):893-901. doi: 10.1007/s00198-010-1469-x. PMID: 21060990. Exclus ion Code: X2.21060990
182 Radford LT, Bolland MJ, Mason B, . The Auckland calcium study: 5-year posttrial follow-up. Osteoporos Int. 2014 Jan;25(1):297-304. doi: 10.1007/s00198-013-2526-z. PMID: 24114400. Exclus ion Code: X7.24114400
183 Redaniel MT, Gardner MP, Martin RM, . The association of vitamin D supplementation with the risk of cancer in postmenopausal women. Cancer Causes Control. 2014 Feb;25(2):267-71. doi: 10.1007/s10552-013-0328-4. PMID: 24337883. Exclus ion Code: X6.24337883
184 Reid IR, Ames RW, Evans MC, . Effect of calcium supplementation on bone loss in postmenopausal women. N Engl J Med. 1993 Feb 18;328(7):460-4. doi: 10.1056/nejm199302183280702. PMID: 8421475. Exclus ion Code: X13.8421475
185 Reid IR, Ames RW, Evans MC, . Long-term effects of calcium supplementation on bone loss and fractures in postmenopausal women: a randomized controlled trial. Am J Med. 1995 Apr;98(4):331-5. doi: 10.1016/S0002-9343(99)80310-6. PMID: 7709944. Exclus ion Code: X13.7709944
186 Reid IR, Bolland MJ. Does widespread calcium supplementation pose cardiovascular risk? Yes: the potential risk is a concern. Am Fam Physician. 2013;87(3):Online. Exclusion Code: X1.
187 Reid IR, Bolland MJ, Avenell A, . Cardiovascular effects of calcium supplementation. Osteoporos Int. 2011 Jun;22(6):1649-58. doi: 10.1007/s00198-011-1599-9. PMID: 21409434. Exclusion Code: X1.21409434
188 Reid IR, Bolland MJ, Grey A. Effects of vitamin D supplements on bone mineral density: a systematic review and meta-analysis. Lancet. 2014 Jan 11;383(9912):146-55. doi: 10.1016/S0140-6736(13)61647-5. PMID: 24119980. Exclusion Code: X12.24119980
189 Reid IR, Bristow SM, Bolland MJ. Cardiovascular complications of calcium supplements. J Cell Biochem. 2015 Apr;116(4):494-501. doi: 10.1002/jcb.25028. PMID: 25491763. Exclusion Code: X1.25491763
190 Reid IR, Mason B, Horne A, . Randomized controlled trial of calcium in healthy older women. Am J Med. 2006 Sep;119(9):777-85. doi: S0002-9343(06)00336-6 [pii]; 10.1016/j.amjmed.2006.02.038 [doi]. PMID: 16945613. Exclus ion Code: X3.16945613
191 Rejnmark L, Avenell A, Masud T, . Vitamin D with calcium reduces mortality: patient level pooled analysis of 70,528 patients from eight major vitamin D trials. J Clin Endocrinol Metab. 2012 Aug;97(8):2670-81. doi: 10.1210/jc.2011-3328. PMID: 22605432. Exclusion Code: X3.22605432
192 Rojas-Fernandez CH, MacLaughlin EJ, Dore NL, . Assessing the potential adverse consequences of supplemental calcium on cardiovascular outcomes: Should we change our approach to bone health? Ann Pharmacother. 2012;46(5):696-702. Exclusion Code: X1.22570431
193 Rosen CJ, Adams JS, Bikle DD, . The nonskeletal effects of vitamin D: an Endocrine Society scientific statement. Endocr Rev. 2012 Jun;33(3):456-92. doi: 10.1210/er.2012-1000. PMID: 22596255. Exclusion Code: X1.22596255
194 Rowland GW, Schwartz GG, John EM, . Protective effects of low calcium intake and low calcium absorption vitamin D receptor genotype in the California Collaborative Prostate Cancer Study. Cancer Epidemiol Biomarkers Prev. 2013 Jan;22(1):16-24. doi: 10.1158/1055-9965.EPI-12-0922-T. PMID: 23129590. Exclusion Code: X2.23129590
195 Ruml LA, Sakhaee K, Peterson R, . The effect of calcium citrate on bone density in the early and mid-postmenopausal period: a randomized placebo-controlled study. Am J Ther. 1999 Nov;6(6):303-11. PMID: 11329114. Exclus ion Code: X13.11329114
196 Sakhaee K, Poindexter JR, Griffith CS, . Stone forming risk of calcium citrate supplementation in healthy postmenopausal women. J Urol. 2004 Sep;172(3):958-61. doi: 10.1097/01.ju.0000136400.14728.cd. PMID: 15311008. Exclusion Code: X5.15311008
197 Salovaara K, Tuppurainen M, Karkkainen M, . Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res. 2010 Jul;25(7):1487-95. doi: 10.1002/jbmr.48. PMID: 20200964. Exclusion Code: X13.20200964
198 Samelson EJ, Booth SL, Fox CS, . Calcium intake is not associated with increased coronary artery calcification: the Framingham Study. Am J Clin Nutr. 2012 Dec;96(6):1274-80. doi: 10.3945/ajcn.112.044230. PMID: 23134889. Exclusion Code: X5.23134889
199 Sanders KM, Nicholson GC, Ebeling PR. Is high dose vitamin D harmful? Calcif Tissue Int. 2013;92(2):191-206. Exclusion Code: X1.23250508
200 Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 2010 May 12;303(18):1815-22. doi: 10.1001/jama.2010.594. PMID: 20460620. Exclusion Code: X3.20460620
201 Satia-Abouta J, Galanko JA, Martin CF, . Associations of micronutrients with colon cancer risk in African Americans and whites: results from the North Carolina Colon Cancer Study. Cancer Epidemiol Biomarkers Prev. 2003 Aug;12(8):747-54. PMID: 12917206. Exclusion Code: X2.12917206
202 Schatzkin A, Peters U. Advancing the calcium-colorectal cancer hypothesis. J Natl Cancer Inst. 2004 Jun 16;96(12):893-4. PMID: 15199101. Exclusion Code: X1.15199101
203 Schleithoff SS, Zittermann A, Tenderich G, . Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial. Am J Clin Nutr. 2006 Apr;83(4):754-9. PMID: 16600924. Exclusion Code: X3.16600924
204 Schnabel C, Jett K, Friedman JM, . Effect of vitamin D3 treatment on bone density in neurofibromatosis 1 patients: a retrospective clinical study. Joint Bone Spine. 2013 May;80(3):315-9. doi: 10.1016/j.jbspin.2012.07.010. PMID: 23021159. Exclus ion Code: X3.23021159
205 Scragg R, Waayer D, Stewart AW, . The Vitamin D Assessment (ViDA) Study: Design of a randomized controlled trial of vitamin D supplementation for the prevention of cardiovascular disease, acute respiratory infection, falls and non-vertebral fractures. J Steroid Biochem Mol Biol. 2015((Scragg R., r.scragg@auckland.ac.nz; Waayer D.; Stewart A.W.; Lawes C.M.M.; Murphy J.) School of Population Health, The University of Auckland, Auckland, New Zealand). Exclusion Code: X11.
206 Sellers TA, Bazyk AE, Bostick RM, . Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes Control. 1998 Aug;9(4):357-67. PMID: 9794167. Exclusion Code: X13.9794167
207 Severi G, English DR, Hopper JL, . Re: Prospective studies of dairy product and calcium intakes and prostate cancer risk: a meta-analysis. J Natl Cancer Inst. 2006 Jun 7;98(11):794-5; author reply 5. doi: 10.1093/jnci/djj215. PMID: 16757704. Exclusion Code: X1.16757704
208 Shaker HK, Stigleman S. Clinical Inquiry: Can calcium supplements cause serious adverse effects in healthy people? J Fam Pract. 2012 Oct;61(10):620-1. doi: jfp_6110g [pii]. PMID: 23106065. Exclusion Code: X1.23106065
209 Shaukat A, Grau MV, Church TR, . Serum salicylate levels and risk of recurrent colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 2011 Apr;20(4):679-82. doi: 10.1158/1055-9965.EPI-10-1135. PMID: 21307305. Exclusion Code: X5.21307305
210 Shea B, Wells G, Cranney A, . Calcium supplementation on bone loss in postmenopausal women. Cochrane Database Syst Rev. 2004(1):CD004526. doi: 10.1002/14651858.CD004526.pub2. PMID: 14974070. Exclus ion Code: X3.14974070
211 Shea B, Wells G, Cranney A, . VII. Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis. Endocr Rev. 2002;23(4):552-9. Exclusion Code: X5.12202470
212 Smith EL, Gilligan C, Smith PE, . Calcium supplementation and bone loss in middle-aged women. Am J Clin Nutr. 1989 Oct;50(4):833-42. PMID: 2801589. Exclusion Code: X5.2801589
213 Smith H, Anderson F, Raphael H, . Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology (Oxford). 2007 Dec;46(12):1852-7. doi: 10.1093/rheumatology/kem240. PMID: 17998225. Exclus ion Code: X3.17998225
214 Sneve M, Figenschau Y, Jorde R. Supplementation with cholecalciferol does not result in weight reduction in overweight and obese subjects. Eur J Endocrinol. 2008 Dec;159(6):675-84. doi: 10.1530/eje-08-0339. PMID: 19056900. Exclusion Code: X5.19056900
215 Sokol SI, Tsang P, Aggarwal V, . Vitamin D status and risk of cardiovascular events: lessons learned via systematic review and meta-analysis. Cardiol Rev. 2011 Jul-Aug;19(4):192-201. doi: 10.1097/CRD.0b013e31821da9a5. PMID: 21646873. Exclus ion Code: X2.21646873
216 Sorensen MD, Eisner BH, Stone KL, . Impact of calcium intake and intestinal calcium absorption on kidney stones in older women: the study of osteoporotic fractures. J Urol. 2012 Apr;187(4):1287-92. doi: 10.1016/j.juro.2011.11.109. PMID: 22341269. Exclus ion Code: X13.22341269
217 Sorenson AW, Slattery ML, Ford MH. Calcium and colon cancer: a review. Nutr Cancer. 1988;11(3):135-45. doi: 10.1080/01635588809513981. PMID: 3043387. Exclusion Code: X6.3043387
218 Spence LA, Weaver CM. Calcium intake, vascular calcification, and vascular disease. Nutr Rev. 2013 Jan;71(1):15-22. doi: 10.1111/nure.12002. PMID: 23282248. Exclusion Code: X6.23282248
219 Steffensen LH, Jorgensen L, Straume B, . Can vitamin D supplementation prevent bone loss in persons with MS? A placebo-controlled trial. J Neurol. 2011 Sep;258(9):1624-31. doi: 10.1007/s00415-011-5980-6. PMID: 21400196. Exclusion Code: X3.21400196
220 Strazzullo P, Siani A, Gugliemi S, . Controlled trial of long-term oral calcium supplementation in essential hypertension. Hypertension. 1986 Nov;8(11):1084-8. PMID: 3770869. Exclusion Code: X5.3770869
221 Ströhle A, Hadji P, Hahn A. Calcium and bone health - Goodbye, calcium supplements? Climacteric. 2015;18(5):702-14. Exclusion Code: X6.25689871
222 Sullivan SD, Lehman A, Nathan NK, . Age of menopause and fracture risk in postmenopausal women randomized to calcium + vitamin D, hormone therapy, or the combination: results from the Women’s Health Initiative Clinical Trials. Menopause (new york, N.Y.); 2017. Exclusion Code: X6.
223 Sun Q, Shi L, Rimm EB, . Vitamin D intake and risk of cardiovascular disease in US men and women. Am J Clin Nutr. 2011 Aug;94(2):534-42. doi: 10.3945/ajcn.110.008763. PMID: 21653796. Exclusion Code: X13.21653796
224 Sun Z, Wang PP, Roebothan B, . Calcium and vitamin D and risk of colorectal cancer: results from a large population-based case-control study in Newfoundland and Labrador and Ontario. Can J Public Health. 2011 Sep-Oct;102(5):382-9. PMID: 22032106. Exclusion Code: X13.22032106
225 Suzuki T, Aoki K. Hypertensive effects of calcium infusion in subjects with normotension and hypertension. J Hypertens. 1988 Dec;6(12):1003-8. PMID: 3221095. Exclus ion Code: X2.3221095
226 Takagi Y, Fukase M, Takata S, . Calcium treatment of essential hypertension in elderly patients evaluated by 24 H monitoring. Am J Hypertens. 1991 Oct;4(10 Pt 1):836-9. PMID: 1747217. Exclusion Code: X5.1747217
227 Takata Y, Shu XO, Yang G, . Calcium intake and lung cancer risk among female nonsmokers: a report from the Shanghai Women’s Health Study. Cancer Epidemiol Biomarkers Prev. 2013 Jan;22(1):50-7. doi: 10.1158/1055-9965.EPI-12-0915-T. PMID: 23093548. Exclus ion Code: X9.23093548
228 Tamez H, Thadhani RI. Vitamin D and hypertension: an update and review. Curr Opin Nephrol Hypertens. 2012 Sep;21(5):492-9. doi: 10.1097/MNH.0b013e3283557bf0. PMID: 22820371. Exclus ion Code: X5.22820371
229 Tang BM, Eslick GD, Nowson C, . Use of calcium or calcium in combination with vitamin D supplementation to prevent fractures and bone loss in people aged 50 years and older: a meta-analysis. Lancet. 2007 Aug 25;370(9588):657-66. doi: 10.1016/s0140-6736(07)61342-7. PMID: 17720017. Exclus ion Code: X12.17720017
230 Tanji JL, Lew EY, Wong GY, . Dietary calcium supplementation as a treatment for mild hypertension. J Am Board Fam Pract. 1991 May-Jun;4(3):145-50. PMID: 2053453. Exclus ion Code: X5.2053453
231 Tedeschi-Blok N, Schwartzbaum J, Lee M, . Dietary calcium consumption and astrocytic glioma: the San Francisco Bay Area Adult Glioma Study, 1991-1995. Nutr Cancer. 2001;39(2):196-203. doi: 10.1207/S15327914nc392_6. PMID: 11759280. Exclus ion Code: X2.11759280
232 Terry P, Vainio H, Wolk A, . Dietary factors in relation to endometrial cancer: a nationwide case-control study in Sweden. Nutr Cancer. 2002;42(1):25-32. doi: 10.1207/S15327914NC421_4. PMID: 12235647. Exclus ion Code: X13.12235647
233 Theodoratou E, Tzoulaki I, Zgaga L, . Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014;348:g2035. doi: 10.1136/bmj.g2035. PMID: 24690624. Exclusion Code: X12.24690624
234 Thomas J. Calcium supplements associated with increased risk of myocardial infarction. Australian Journal of Pharmacy. 2011;92(1089):66-7. Exclusion Code: X1.
235 Toss G, Magnusson P. Is a daily supplementation with 40 microgram vitamin D3 sufficient? A randomised controlled trial. Eur J Nutr. 2012 Dec;51(8):939-45. doi: 10.1007/s00394-011-0271-7. PMID: 22086300. Exclus ion Code: X5.22086300
236 Touvier M, Chan DS, Lau R, . Meta-analyses of vitamin D intake, 25-hydroxyvitamin D status, vitamin D receptor polymorphisms, and colorectal cancer risk. Cancer Epidemiol Biomarkers Prev. 2011 May;20(5):1003-16. doi: 10.1158/1055-9965.EPI-10-1141. PMID: 21378269. Exclusion Code: X2.21378269
237 Tseng M, Breslow RA, Graubard BI, . Dairy, calcium, and vitamin D intakes and prostate cancer risk in the National Health and Nutrition Examination Epidemiologic Follow-up Study cohort. Am J Clin Nutr. 2005 May;81(5):1147-54. PMID: 15883441. Exclusion Code: X2.15883441
238 Turner AN, Carr Reese P, Fields KS, . A blinded, randomized controlled trial of high-dose vitamin D supplementation to reduce recurrence of bacterial vaginosis. Am J Obstet Gynecol. 2014 Nov;211(5):479 e1-e13. doi: 10.1016/j.ajog.2014.06.023. PMID: 24949544. Exclusion Code: X3.24949544
239 Uemura H, Katsuura-Kamano S, Yamaguchi M, . Association between dietary calcium intake and arterial stiffness according to dietary vitamin D intake in men. Br J Nutr. 2014 Oct 28;112(8):1333-40. doi: 10.1017/S0007114514002153. PMID: 25192171. Exclusion Code: X2.25192171
240 Vacek JL, Vanga SR, Good M, . Vitamin D deficiency and supplementation and relation to cardiovascular health. Am J Cardiol. 2012 Feb 1;109(3):359-63. doi: 10.1016/j.amjcard.2011.09.020. PMID: 22071212. Exclus ion Code: X3.22071212
241 Van Hemelrijck M, Michaelsson K, Linseisen J, . Calcium Intake and Serum Concentration in Relation to Risk of Cardiovascular Death in NHANES III. PLoS One. 2013;8(4):e61037. doi: 10.1371/journal.pone.0061037. Exclusion Code: X13.23593383
242 Van Pelt N, Ruygrok P, Bolland MJ, . Do calcium supplements lead to an increase in coronary calcification? Eur Heart J. 2009;30((Van Pelt N.; Ruygrok P.; Bolland M.J.) Auckland City Hospital, Auckland, New Zealand):235. Exclusion Code: X5.
243 Vestergaard P, Mosekilde L, Langdahl B. Fracture prevention in postmenopausal women. BMJ Clin Evid. 2011;2011. PMID: 21542947. Exclusion Code: X3.21542947
244 Wang L, Manson JE, Sesso HD. Calcium intake and risk of cardiovascular disease: a review of prospective studies and randomized clinical trials. Am J Cardiovasc Drugs. 2012 Apr 1;12(2):105-16. doi: 10.2165/11595400-000000000-00000. PMID: 22283597. Exclusion Code: X2.22283597
245 Wang L, Song Y, Manson JE, . Circulating 25-hydroxy-vitamin D and risk of cardiovascular disease: a meta-analysis of prospective studies. Circ Cardiovasc Qual Outcomes. 2012 Nov;5(6):819-29. doi: 10.1161/circoutcomes.112.967604. PMID: 23149428. Exclus ion Code: X12.23149428
246 Wang LD, Qiu SL, Yang GR, . A randomized double-blind intervention study on the effect of calcium supplementation on esophageal precancerous lesions in a high-risk population in China. Cancer Epidemiol Biomarkers Prev. 1993 Jan-Feb;2(1):71-8. PMID: 8420615. Exclusion Code: X3.8420615
247 Wang X, Chen H, Ouyang Y, . Dietary calcium intake and mortality risk from cardiovascular disease and all causes: a meta-analysis of prospective cohort studies. BMC Med. 2014;12:158. doi: 10.1186/s12916-014-0158-6. PMID: 25252963. Exclus ion Code: X2.25252963
248 Waterhouse M, Risch HA, Bosetti C, . Vitamin D and pancreatic cancer: a pooled analysis from the Pancreatic Cancer Case-Control Consortium. Ann Oncol. 2015 Aug;26(8):1776-83. doi: 10.1093/annonc/mdv236. PMID: 25977560. Exclusion Code: X13.25977560
249 Weaver CM, Alexander DD, Boushey CJ, . Calcium plus vitamin D supplementation and risk of fractures: an updated metaanalysis from the National Osteoporosis Foundation. Osteoporos Int. 2016 Jan;27(1):367-76. doi: 10.1007/s00198-015-3386-5. PMID: 26510847. Exclusion Code: X12.26510847
250 Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. Cochrane Database Syst Rev. 2008(1):CD003548. doi: 10.1002/14651858.CD003548.pub4. PMID: 18254022. Exclus ion Code: X3.18254022
251 Wilson KM, Shui IM, Mucci LA, . Calcium and phosphorus intake and prostate cancer risk: a 24-y follow-up study. Am J Clin Nutr. 2015 Jan;101(1):173-83. doi: 10.3945/ajcn.114.088716. PMID: 25527761. Exclusion Code: X13.25527761
252 Witham MD, Price RJ, Struthers AD, . Cholecalciferol treatment to reduce blood pressure in older patients with isolated systolic hypertension: the VitDISH randomized controlled trial. JAMA Intern Med. 2013 Oct 14;173(18):1672-9. doi: 10.1001/jamainternmed.2013.9043. PMID: 23939263. Exclus ion Code: X3.23939263
253 Witte KK, Byrom R, Gierula J, . Effects of Vitamin D on Cardiac Function in Patients With Chronic HF: The VINDICATE Study. J Am Coll Cardiol. 2016 Jun 7;67(22):2593-603. doi: 10.1016/j.jacc.2016.03.508. PMID: 27058906. Exclus ion Code: X3.27058906
254 Wlodarek D, Glabska D, Kolota A, . Calcium intake and osteoporosis: the influence of calcium intake from dairy products on hip bone mineral density and fracture incidence - a population-based study in women over 55 years of age. Public Health Nutr. 2014 Feb;17(2):383-9. doi: 10.1017/S1368980012005307. PMID: 23217270. Exclus ion Code: X2.23217270
255 Wood AD, Secombes KR, Thies F, . Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 2012 Oct;97(10):3557-68. doi: 10.1210/jc.2012-2126. PMID: 22865902. Exclusion Code: X5.22865902
256 Wu K, Willett WC, Fuchs CS, . Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst. 2002 Mar 20;94(6):437-46. PMID: 11904316. Exclusion Code: X2.11904316
257 Xiao Q, Murphy RA, Houston DK, . Dietary and supplemental calcium intake and cardiovascular disease mortality: the National Institutes of Health-AARP diet and health study. JAMA Intern Med. 2013 Apr 22;173(8):639-46. doi: 10.1001/jamainternmed.2013.3283. PMID: 23381719. Exclus ion Code: X13.23381719
258 Yang B, Campbell PT, Gapstur SM, . Calcium intake and mortality from all causes, cancer, and cardiovascular disease: the Cancer Prevention Study II Nutrition Cohort. Am J Clin Nutr. 2016 Mar;103(3):886-94. doi: 10.3945/ajcn.115.117994. Exclusion Code: X13.26864361
259 Yokoyama S, Takahashi S, Kawakami Y, . Effect of vitamin D supplementation on pegylated interferon/ribavirin therapy for chronic hepatitis C genotype 1b: a randomized controlled trial. J Viral Hepat. 2014 May;21(5):348-56. doi: 10.1111/jvh.12146. PMID: 24716637. Exclusion Code: X3.24716637
260 Zhang L, Wang S, Che X, . Vitamin D and lung cancer risk: a comprehensive review and meta-analysis. Cell Physiol Biochem. 2015;36(1):299-305. doi: 10.1159/000374072. PMID: 25967968. Exclusion Code: X2.25967968
261 Zheng W, Anderson KE, Kushi LH, . A prospective cohort study of intake of calcium, vitamin D, and other micronutrients in relation to incidence of rectal cancer among postmenopausal women. Cancer Epidemiol Biomarkers Prev. 1998 Mar;7(3):221-5. PMID: 9521437. Exclus ion Code: X2.9521437
262 Zheng YT, Cui QQ, Hong YM, . A meta-analysis of high dose, intermittent vitamin D supplementation among older adults. PLoS One. 2015;10(1):e0115850. doi: 10.1371/journal.pone.0115850. PMID: 25602255. Exclus ion Code: X4.25602255
263 Zhu K, Devine A, Dick IM, . Effects of calcium and vitamin D supplementation on hip bone mineral density and calcium-related analytes in elderly ambulatory Australian women: a five-year randomized controlled trial. J Clin Endocrinol Metab. 2008 Mar;93(3):743-9. doi: 10.1210/jc.2007-1466. PMID: 18089701. Exclusion Code: X3.18089701
264 Zittermann A, Pilz S, Börgermann J, . Calcium supplementation and vitamin D: A trigger for adverse cardiovascular events? Future Cardiol. 2011;7(6):725-7. Exclusion Code: X1.22050056
265 Zittermann A, Prokop S. The role of vitamin D for cardiovascular disease and overall mortality. Adv Exp Med Biol. 2014;810:106-19. PMID: 25207362. Exclusion Code: X1.25207362