# Appendix B Detailed Methods

Appendix B1 Relationship of Current Update to Previous AHRQ Evidence Reviews

Relationships of current update to previous AHRQ evidence reviews The figure displays a flow chart showing the relationship among the 6 AHRQ reviews conducted between 2007 and 2017. Cranney et al, 2007, an AHRQ EPC review, funded by the NIH Office on Dietary Supplements (ODS), focused on the effect of vitamin D supplementation (with or without calcium) on bone health outcomes across the lifespan. Chung et al, 2009, an AHRQ EPC review, is an update to the 2009 review and has a broader scope of examining the effect of vitamin D, calcium, or combined supplementation on many health outcomes across the lifespan. The 2009 review was jointly funded by NIH ODS, the Food and Drug Administration, and Health Canada in support of IOM Dietary Reference Intakes (DRI). Chung et al, 2011 is an AHRQ EPC review for the USPSTF, an update to the 2009 review, and has a more narrow scope focusing on the effect of vitamin D (with or without calcium) on fracture and cancer outcomes among adults, institutionalized, community-dwelling, and secondary prevention populations. The resulting 2013 USPSTF recommendation statement is based on a limited set of analyses for fracture outcomes among community-dwelling populations. Newberry et al, 2014, an AHRQ EPC review, is an undate to the 2009 review funded by the NIH ODS in support of updating the IOM DRI, and once again changes the scope to focusing on the effect of vitamin D (with or without calcium) on many health outcomes across lifespan. The 2014 review serves to inform the current review, Kahwati et al, 2017, which is an AHRQ EPC review for the USPSTF and an update to the 2011 USPSTF review. The current review has a changed scope focusing on the effect of vitamin D, calcium, or combined supplementation on fracture outcomes only among community-dwelling and primary prevention populations (< 20% with history of prior fracture).

## Appendix B2 Search Strategies

KQ 1 PubMed (January 1, 2011 through May 25, 2016)

| Terms | Results
#22 | Search “Vitamin D”[Mesh] OR “Vitamin D”[tw] | 67831
#23 | Search “Calcium”[Mesh] OR “Calcium Compounds”[Mesh] OR “Calcium”[tw] | 535891
#25 | Search (#22 OR #23) | 576628
#26 | Search ((Fracture, Bone (MeSH) OR fracture[tw])) | 160977
#27 | Search (#25 AND #26) | 7631
#28 | Search (#25 AND #26) Filters: Publication date from 2011/01/01 | 2424
#29 | Search (#25 AND #26) Filters: Publication date from 2011/01/01; Humans | 1559
#30 | Search (#25 AND #26) Filters: Publication date from 2011/01/01; Humans; English | 1404
## | Search (#25 AND #26) Filters: Systematic Reviews; Publication date from 2011/01/01; Humans Total | 98
#31 | Search (#25 AND #26) Filters: Systematic Reviews; Publication date from 2011/01/01; Humans; English | 88
#32 | Search ((((“Controlled Clinical Trial” [Publication Type] OR “Clinical Trial, Phase IV” [Publication Type] OR “Clinical Trial, Phase III” [Publication Type]) OR “Meta-Analysis” [Publication Type]) OR “Comparative Study” [Publication Type])) Or (((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2200139
#33 | Search (#29 AND #32) | 266
#34 | Search (#30 AND #32) | 252
#39 | Search (((“Cohort Studies”[Mesh]) OR “Epidemiologic Studies”[Mesh]) OR “Prospective Studies”[Mesh]) OR “Observational Study” [Publication Type] | 1869921
#40 | Search (#29 AND #39) | 505
#41 | Search (#30 AND #39) | 484
#53 | Search (#31 OR #34 OR #41) | 681

Cochrane=23=new

Review s=15=9 new

DARE=8=2 new

Cochrane Central Register of Controlled Trials=29=12 new

Embase=321=313 English=212 new

Total Database=232

Both Databases KQ 1=913

Calcium Alone PubMed (Database Inception Through 2010)

| Search Terms | Results
#22 | Search “Vitamin D”[Mesh] OR “Vitamin D”[tw] | 67831
#23 | Search “Calcium”[Mesh] OR “Calcium Compounds”[Mesh] OR “Calcium”[tw] | 535891
#26 | Search ((Fracture, Bone (MeSH) OR fracture[tw])) | 160977
#32 | Search ((((“Controlled Clinical Trial” [Publication Type] OR “Clinical Trial, Phase IV” [Publication Type] OR “Clinical Trial, Phase III” [Publication Type]) OR “Meta-Analysis” [Publication Type]) OR “Comparative Study” [Publication Type])) OR (((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2200139
#33 | Search (#23 AND #26) | 6515
#34 | Search (#33 NOT #22) | 4220
#35 | Search (#33 NOT #22) Filters: Humans | 2608
#36 | Search (#33 NOT #22) Filters: Publication date to 2010/12/31; Humans | 1991
#37 | Search (#33 NOT #22) Filters: Publication date to 2010/12/31; Humans; English | 1717
#38 | Search (#33 NOT #22) Filters: Systematic Reviews; Publication date to 2010/12/31; Humans; English | 38
#39 | Search (#33 NOT #22) Filters: Systematic Reviews; Publication date to 2010/12/31; Humans | 45
#43 | Search #32 AND #34 Filters: Publication date to 2010/12/31; Humans | 430
#44 | Search #32 AND #34 Filters: Publication date to 2010/12/31; Humans; English | 400
#45 | Search (#44 OR #38) Filters: Publication date to 2010/12/31; Humans; English | 426

Cochrane=35

Review s=5=3 new

DARE=6=2 new

Cochrane Central Register of Controlled Trials=56=30

Embase=114=91 English=64

Database Total=99

Both Databases KQ 1 Calcium Alone=525

KQ 2 PubMed (January 1, 2011 through May 25, 2016)

| Search Term | Results
#1 | Search (((“Drug-Related Side Effects and Adverse Reactions”[Mesh])) OR ((“Dietary Supplements/adverse effects”[Mesh] OR “Dietary Supplements/toxicity”[Mesh]))) OR ((((((“Mortality”[Mesh]) OR “Neoplasms”[Mesh]) OR “Urinary Calculi”[Mesh]) Or “Nephrolithiasis”[Mesh]) OR “Cardiovascular Diseases”[Mesh]) OR “Cerebrovascular Disorders”[Mesh]) | 4936092
#2 | Search (((“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH OR (prospective*[All Fields] AND cohort[All Fields] aNd (study[All Fields] OR studies[All Fields])))) Or “Observational Study” [Publication Type] | 1889594
#3 | Search (((((“Controlled Clinical Trial” [Publication Type]) OR “Clinical Trial, Phase IV” [Publication Type]) OR “Clinical Trial, Phase III” [Publication Type]) OR “Comparative Study” [Publication Type])) OR ((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2143507
#4 | Search ((((“Vitamin D/adverse effects”[Mesh] OR “Vitamin D/drug therapy”[Mesh] OR “Vitamin D/poisoning”[Mesh] OR “Vitamin D/therapeutic use”[Mesh] OR “Vitamin D/therapy”[Mesh] OR “Vitamin D/toxicity”[Mesh]))) OR ((“Calcium/adverse effects”[Mesh] OR “Calcium/poisoning”[Mesh] OR “Calcium/therapeutic use”[Mesh] OR “Calcium/therapy”[Mesh] OR “Calcium/toxicity”[Mesh]))) OR ((“Calcium Compounds/adverse effects”[Mesh] OR “Calcium Compounds/poisoning”[Mesh] OR “Calcium Compounds/therapeutic use”[Mesh] OR “Calcium Compounds/therapy”[Mesh] OR “Calcium Compounds/toxicity”[Mesh])) | 36152
#5 | Search (#1 AND #4) | 6231
#8 | Search (#1 AND #4) Filters: Systematic Reviews; Publication date from 2011/01/01; Humans | 124
#9 | Search (#1 AND #4) Filters: Systematic Reviews; Publication date from 2011/01/01; Humans; English | 115
#10 | Search (#1 AND #4) Filters: Publication date from 2011/01/01; Humans; English | 1325
#11 | Search (#2 AND #10) Filters: Publication date from 2011/01/01; Humans; English | 323
## | Total before English removed | 334
#12 | Search (#3 AND #10) Filters: Publication date from 2011/01/01; Humans; English | 226
## | Total before English removed | 230
#13 | Search (#11 OR #12) Filters: Publication date from 2011/01/01; Humans; English | 456
#23 | Search (#9 OR #13) | 552

Cochrane=39 New

Review s=7=4 New

DARE=1=0 New

Cochrane Central Register of Controlled Trials=47=35 New

Embase=228=223 English=213 New

Database Total=252

Both Databases KQ 2=804

Calcium Alone PubMed (Database inception through 2010)

| Search Term | Results
#1 | Search (((“Drug-Related Side Effects and Adverse Reactions”[Mesh])) OR ((“Dietary Supplements/adverse effects”[Mesh] OR “Dietary Supplements/toxicity”[Mesh]))) OR ((((((“Mortality”[Mesh]) OR “Neoplasms”[Mesh]) OR “Urinary Calculi”[Mesh]) OR “Nephrolithiasis”[Mesh]) OR “Cardiovascular Diseases”[Mesh]) OR “Cerebrovascular Disorders”[Mesh]) | 4936092
#2 | Search (((“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])))) OR “Observational Study” [Publication Type] | 1889594
#3 | Search (((((“Controlled Clinical Trial” [Publication Type]) OR “Clinical Trial, Phase IV” [Publication Type]) OR “Clinical Trial, Phase III” [Publication Type]) OR “Comparative Study” [Publication Type])) oR ((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2143507
#4 | Search (((((“Calcium/adverse effects”[Mesh] OR “Calcium/poisoning”[Mesh] OR “Calcium/therapeutic use”[Mesh] OR “Calcium/therapy”[Mesh] oR “Calcium/toxicity”[Mesh]))) OR ((“Calcium Compounds/adverse effects”[Mesh] OR “Calcium Compounds/poisoning”[Mesh] OR “Calcium Compounds/therapeutic use”[Mesh] OR “Calcium Compounds/therapy”[Mesh] OR “Calcium Compounds/toxicity”[Mesh]))))) | 21689
#5 | Search (#1 AND #4) | 3661
#7 | Search “Vitamin D”[Mesh] | 47935
#8 | Search (#5 NOT #7) | 2930
#11 | Search (#5 NOT #7) Filters: Systematic Reviews; Publication date to 2010/12/31; Humans Total | 64
#12 | Search (#5 NOT #7) Filters: Systematic Reviews; Publication date to 2010/12/31; Humans; English | 62
#13 | Search (#5 NOT #7) Filters: Publication date to 2010/12/31; Humans; | 1589
## | Search (#5 NOT #7) Filters: Publication date to 2010/12/31; Humans | 1974
#14 | Search (#2 AND #13) Filters: Publication date to 2010/12/31; Humans; English | 312
## | Total before English removed | 337
#15 | Search (#3 AND #13) Filters: Publication date to 2010/12/31; Humans; English | 308
## | Total before English removed | 358
#16 | Search (#14 OR #15) Filters: Publication date to 2010/12/31; Humans; English | 518
#18 | Search (#12 OR #16) Filters: Publication date to 2010/12/31; Humans; English | 567

Cochrane=13

Review s=10=3

DARE=1=1 New

Cochrane Central Register of Controlled Trials=10=9

Embase=91=80 New

Database Total=93

Both Databases KQ 2 Calcium Alone=660

### Registry Searches (through November 16, 2016)

ClinicalTrials.gov

“Vitamin D” And Fracture=57

Calcium AND Fracture=26 unique not already picked up by Vitamin D search

WHO ICTRP

“Vitamin D” And Fracture=3 unique, not already picked up by clinicaltrials.gov

Calcium AND Fracture=1 unique, not already picked up by clinicaltrials.gov

NICE=0

Total=87 unique records

Update Search KQ 1 PubMed (May 26, 2016 through March 21, 2017)

| Terms | Results
#2 | Search “Vitamin D”[Mesh] OR “Vitamin D”[tw] | 71201
#3 | Search “Calcium”[Mesh] OR “Calcium Compounds”[Mesh] OR “Calcium”[tw] | 550586
#4 | Search (#2 OR #3) | 593840
#5 | Search ((Fracture, Bone (MeSH) OR fracture[tw])) | 168951
#6 | Search (#4 AND #5) | 7989
#7 | Search (#4 AND #5) Filters: Humans | 5820
#8 | Search (#4 AND #5) Filters: Humans; English | 5078
#9 | Search (#4 AND #5) Filters: Publication date from 2016/03/01; Humans; English | 85
#12 | Search (#9 AND #11) Filters: Systematic Reviews | 7
#13 | Search (#9 AND #11) | 7
#14 | Search ((((“Controlled Clinical Trial” [Publication Type] OR “Clinical Trial, Phase IV” [Publication Type] OR “Clinical Trial, Phase III” [Publication Type]) OR “Meta-Analysis” [Publication Type]) OR “Comparative Study” [Publication Type])) Or (((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2256005
#15 | Search (#9 AND #14) | 11
#16 | Search (((“Cohort Studies”[Mesh]) OR “Epidemiologic Studies”[Mesh]) OR “Prospective Studies”[Mesh]) OR “Observational Study” [Publication Type] | 1980834
#17 | Search (#9 AND #16) | 23
#18 | Search (#13 OR #15 OR #17) | 34

Cochrane=73

Review s=5 + 2 New

DARE=0=New

Cochrane Central Register of Controlled Trials=68=61 new

Embase=English=88=64 new

Total Database=161

KQ 2 PubMed (May 26, 2016 through March 21, 2017)

| Search Term | Results
#2 | Search ((((“Drug-Related Side Effects and Adverse Reactions”[Mesh])) OR ((“Dietary Supplements/adverse effects”[Mesh] OR “Dietary Supplements/toxicity”[Mesh]))) OR ((((((“Mortality”[Mesh]) OR “Neoplasms”[Mesh]) OR “Urinary Calculi”[Mesh]) Or “Nephrolithiasis”[Mesh]) OR “Cardiovascular Diseases”[Mesh]) OR “Cerebrovascular Disorders”[Mesh])) | 5098289
#3 | Search (((“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])))) Or “Observational Study” [Publication Type] | 2002948
#4 | Search (((((“Controlled Clinical Trial” [Publication Type]) OR “Clinical Trial, Phase IV” [Publication Type]) OR “Clinical Trial, Phase III” [Publication Type]) OR “Comparative Study” [Publication Type])) oR ((((“Randomized Controlled Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) | 2190914
#5 | Search ((((“Vitamin D/adverse effects”[Mesh] OR “Vitamin D/drug therapy”[Mesh] OR “Vitamin D/poisoning”[Mesh] OR “Vitamin D/therapeutic use”[Mesh] OR “Vitamin D/therapy”[Mesh] OR “Vitamin D/toxicity”[Mesh]))) OR ((“Calcium/adverse effects”[Mesh] OR “Calcium/poisoning”[Mesh] OR “Calcium/therapeutic use”[Mesh] OR “Calcium/therapy”[Mesh] OR “Calcium/toxicity”[Mesh]))) OR ((“Calcium Compounds/adverse effects”[Mesh] OR “Calcium Compounds/poisoning”[Mesh] OR “Calcium Compounds/therapeutic use”[Mesh] OR “Calcium Compounds/therapy”[Mesh] OR “Calcium Compounds/toxicity”[Mesh])) | 37372
#6 | Search (#2 AND #5) | 6428
#7 | Search (#2 AND #5) Filters: Systematic Reviews | 279
#8 | Search (#2 AND #5) Filters: Systematic Reviews; Humans | 279
#9 | Search (#2 AND #5) Filters: Systematic Reviews; Humans; English | 256
#10 | Search (#2 AND #5) Filters: Systematic Reviews; Publication date from 2016/03/01; Humans; English | 7
#11 | Search (#2 AND #5) Filters: Publication date from 2016/03/01; Humans; English | 71
#12 | Search (#3 AND #11) Filters: Publication date from 2016/03/01; Humans; English | 21
#13 | Search (#4 AND #11) Filters: Publication date from 2016/03/01; Humans; English | 10
#14 | Search (#12 OR #13) Filters: Publication date from 2016/03/01; Humans; English | 27
#15 | Search (#10 OR #14) Filters: Publication date from 2016/03/01; Humans; English | 33

Cochrane=19

Review s=3=2 New

DARE=0

Cochrane Central Register of Controlled Trials=16=New

Embase=English=31=27 New

Database Total=78

### Registry Searches (through March 21, 2017)

ClinicalTrials.gov

(Vitamin D OR Calcium) AND Fracture=3

WHO ICTRP

(Vitamin D OR Calcium) AND Fracture=0

NICE=1

Total=198 unique records

### Appendix B3 Eligibility Criteria for Study Selection

Include or Exclude Question | Exclusion Code | Reason for Exclusion | Inclusion Criteria | Exclusion Criteria
1. Does the article represent original research? | X1 | Not original research | Published or unpublished original research. | Nonsystematic (narrative) review, letters or editorials, articles with no original data.
2. Does the study include an intervention of interest? | X2 | Ineligible or no intervention | Supplementation with vitamin D2 or D3 alone or in combination with calcium or supplementation with calcium alone. Any dosage, route, or frequency. | Short-term supplementation use (<1 month); vitamin D preparations or metabolites designed for treatment not supplementation (e.g., calcitriol, alphacalcitriol, calcifediol); synthetic vitamin D analogs (i.e., doxercalciferol, paricalcitol, falecalcitriol, oxacalcitriol, alfacalcidol); multivitamin supplements that include vitamin D or calcium, unless the independent effects of vitamin D, calcium, or both can be evaluated; foods or beverages fortified with vitamin D, calcium, or both; and vitamin D obtained through natural or artificial ultraviolet light exposure.
3. Does the study report on the population of interest? | X3 | Ineligible population | Community-dwelling adults with no known disorders related to bone metabolism. Mixed populations will be included if no more than 20% of the study population has any of the excluded conditions. Study populations with 20%-50% having a known condition will be considered in sensitivity analyses. | Children or adolescents age <18 years; pregnant or lactating women; studies for which patient eligibility is determined by testing to identify vitamin D deficiency or bone measurement testing, with selection based on low vitamin D or bone density level; studies with inclusion criteria designed to assemble populations with a specific condition or a group of closely related conditions, such as those with:; - osteoporosis, or who take antiresorptive agents, or have a prior history of osteoporotic fractures, or have long-term use of systemic corticosteroids or other medications associated with osteoporosis (e.g., aromatase inhibitors, androgen deprivation therapy, antiretroviral therapy);; - a history of falls or considered at high risk for falls;; - medical conditions associated with vitamin D deficiency (e.g., hyperparathyroidism, rickets, calcium or phosphorus metabolism disorders, malabsorptive disorders, celiac disease, cystic fibrosis, short gut syndrome, cholestatic liver disease, hepatic failure, cirrhosis, chronic kidney disease, scleroderma, lupus, dermatomyositis);; - bone disorders (e.g., osteogenesis imperfecta, osteopetrosis, osteitis deformans);; - active cancer or history of cancer (excluding nonmelanoma skin cancer);; - known coronary artery disease; and; - nephrolithiasis or nephrocalcinosis.
4. Is the study conducted in a clinical or community setting of interest? | X4 | Ineligible setting | Community and primary care-relevant settings, including assisted and independent living facilities. | Skilled nursing facilities; postacute care and rehabilitation facilities
5. Does the study report on outcomes of interest? | X5 | Ineligible or no outcomes | KQ 1: Total primary (i.e., incident) fractures at any site other than face, skull, finger, toe, and heel; total primary (i.e., incident) major osteoporotic fracture, defined as fracture of the hip; vertebral (clinical), proximal humerus, distal radius, and morphometric vertebral fractures; fracture-related morbidity (e.g., fracture nonunion) and mortality. KQ 2: All-cause mortality, symptomatic acute or chronic vitamin D or calcium toxicity, incident symptomatic nephrolithiasis, incident cancer (other than nonmelanoma skin cancer), incident cardiovascular disease (myocardial infarction, stroke, peripheral artery disease), and other harms reported as being definitely or probably related to study intervention. | KQ 1: Recurrent osteoporotic fracture (i.e., preventing a second fracture in patients known to have a previous osteoporotic fracture); change in BMD; other intermediate measures of bone or muscle strength or quality. KQ 2: Asymptomatic outcomes (soft-tissue calcification, nephrocalcinosis, artery calcification, hypercalcemia, hypercalciuria).
6. Does the study use a study design of interest? | X6 | Ineligible study design | KQ 1: RCTs; systematic reviews that use study selection criteria similar to this review. KQ 2: RCTs; systematic reviews that use study selection criteria similar to this review; prospective cohort or case-control studies, if they:; - were designed specifically to evaluate the use of vitamin D or calcium supplementation and; - adequately measured and controlled for nonsupplemental sources of vitamin D or calcium. | Study designs not listed as specifically included (e.g., case reports, case series, studies without a comparison group).
7. Does the study use a comparator of interest? | X7 | Ineligible or no comparator | Pacebo, no treatment, or lower- or higher-dose vitamin D or calcium regimens. | Intervention and comparison arms that do not allow for evaluation of the independent contribution of vitamin D or calcium, either alone or combined (e.g., studies assessing a multicomponent intervention that includes vitamin D as one of several components compared with no intervention would not be eligible unless the comparison arm included all of the other intervention components except vitamin D).
8. Does the study provide the intervention over a time period of interest? | X8 | Ineligible timing | KQ 1: Intervention duration of ⩾1 month KQ 2: Any duration | KQ 1: Intervention duration of <1 month KQ 2: No exclusions
9. Does the study include countries with an HDI similar to the United States? | X9 | Ineligible country | Studies conducted in countries categorized as “very high” on the HDI (as defined by the United Nations Development Programme). | Studies conducted in countries not categorized as “very high” on the HDI (as defined by the United Nations Development Programme).
10. Is article published in English? | X10 | Not published in English | Studies must be published in English. | Studies not published in English.
11. Is article a study protocol? | X11 | Study protocol | Study protocols are not eligible for inclusion. | Study protocols that do not contain any results data.

Abbreviations: BMD=bone mineral density; HDI=Human Development Index; KQ=key question; RCT=randomized controlled trial.

## Appendix B4 USPSTF Quality Rating Criteria

### RCTs and Cohort Studies

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

#### Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: [underlined: U.S. Preventive Services Task Force Procedure Manual.] Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. Available at: https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes