# Appendix A Supplemental Background Information

Appendix A Table 1 Serum Vitamin D Level Reference Ranges

Serum Level (nmol/L) | Equivalent Range in ng/ml | NAM Description^*^ | Qualitative Term Used to Describe This Range^†^
<30 nmol/L | <12 ng/ml | Persons with levels in this range are at risk of deficiency relative to bone health outcomes | Severe deficiency
Between 30-50 nmol/L | Between 12-20 ng/ml | Some, but not all, persons in this range are at risk of deficiency relative to bone health outcomes | Deficiency
Between 50-75 nmol/L | Betw een 20-30 ng/dl | Most, but not all, persons with levels in this range are sufficient relative to bone health outcomes | Some refer to this range as insufficiency; others contend this range is sufficiency.
>75 nmol/L | >30 ng/ml | Persons with levels in this range do not consistently have an increased benefit relative to bone health outcomes | Sufficiency
Above 125 nmol/L | Above 50 ng/ml | Levels in this range may be cause for concern | –

* As described in: Dietary Reference Intakes for Calcium and Vitamin D. IOM (Institute of Medicine). 2011 Washington, DC: The National Academies Press.^5^

† These are not terms attributed by NAM; rather, these are descriptors commonly found in the literature describing these ranges. Experts disagree about the terms that should be used to describe these ranges, whether these ranges adequately reflect the evidence, and whether these ranges reflect clinical thresholds for action related to supplementation.

Abbreviations: NAM=National Academy of Medicine (formerly Institute of Medicine); ng/ml=nanogram per milliliter; nmol/L=nanomole per liter.

## Appendix A Summary of Findings From Contextual Questions

### Contextual Question 1. What are the effects of vitamin D supplementation alone or combined with calcium on change in vitamin D status?

#### Summary of Findings

For the question related to vitamin D supplementation and change in vitamin D status, the 2014 updated AHRQ evidence report^17^ identified one systematic review of 76 studies and 13 relevant randomized, controlled trials (RCTs) that were new since the 2009 AHRQ evidence report.^15^

The report investigators presented bubble plots of the association between supplementation and status, overall and for subgroups, using data from 44 RCTs with 50 comparisons among adults and children. Among the adult populations studied, about three quarters of the included studies were among community-dwelling populations, and the mean baseline serum 25[OH] D levels among these studies was in the sufficiency range. There was an increase in serum concentrations of 25[OH] D with vitamin D supplementation in all studies. The authors did not report a summary measure of effect for dose response because of substantial heterogeneity that was attributed to the following: wide variation in the dosages of vitamin D; various adherence rates; differences in calcium intake; different vitamin D assays and measurement; differences in baseline serum 25[OH] D levels; or lack of adjustment for skin pigmentation or background sun exposure. We identified three additional RCTs, newly published since the 2014 AHRQ Evidence Report, which evaluated the association between vitamin D supplementation and serum concentrations of vitamin D.^137-139^ All three trials reported an increase in serum vitamin D concentrations with vitamin D supplementation despite differences in patient population, dosages, frequency, and duration.

#### Detailed Findings From AHRQ Evidence Reports

The 2014 AHRQ Evidence Report relied on a new (since 2009) systematic review published in The Journal of Clinical Endocrinology and Metabolism of 12,203 participants from 76 randomized placebo controlled and open-label trials of vitamin D supplementation.^140^ In these trials, daily vitamin D intake ranged from 200 IU to 10,000 IU (mean=800 IU); most vitamin D was administered orally. Of the 76 trials, 58 (76%) were among community-dwelling participants, 24 of which had a primary endpoint of serum 25[OH] D changes. Three fourths of participants were 50 to 79 years of age and all were Caucasian. The median (range) baseline serum 25[OH] D level was lower among institutionalized participants (26.2 [11.7–53.9] nmol/L) than among community-dwelling participants (48.2 [17.7–90.6] nmol/L). There was a general increase in the serum concentration of vitamin D with supplementation. A meta-regression showed an average increase of 1.95 nmol/L in serum concentration of vitamin D for each 40 IU of vitamin D supplemented; review authors found considerable variation in response for similar doses of vitamin D intake (i.e., three- to four-fold variations). Being institutionalized or of an older age did not affect the dose response relationship between supplementation and serum 25[OH] D levels. Cosupplementation with calcium resulted in nonsignificant smaller increases in serum levels of 25[OH] D than supplementation with vitamin D alone, and there were smaller increases in serum levels of 25[OH] D with ergocalciferol (D_2_) than with cholecalciferol (D_3_).

The 2014 AHRQ Evidence Report also relied on 13 new (since 2009) RCTs that evaluated vitamin D intake via supplements among adults age 19 years or older. These RCTs also demonstrated a general increase in serum concentration of 25[OH] D with supplementation. Results varied by age group, baseline vitamin D status, dose, duration, and assay method.

#### Detailed Findings From Studies Published After the 2014 AHRQ Evidence Report

We identified three additional RCTs, new since the 2014 AHRQ Evidence Report that evaluated the association between vitamin D supplementation and serum concentrations of vitamin D.^137-139^ All trials reported an increase in serum vitamin D concentrations with vitamin D supplementation; study populations, dosage, frequency, and duration varied across the trials. In a small trial in Argentina among 33 healthy participants age 24 to 46 years, both vitamin D_2_ and vitamin D_3_ were effective in increasing serum levels of vitamin D after a loading dose of 100,000 IU. At baseline, the mean serum 25[OH] D levels were 56.4, 40.7, and 60.7 nmol/L in the placebo, vitamin D_2_, and vitamin D_3_ groups, respectively. After 7 days, the absolute increment increase over baseline 25[OH] D levels was 50.7 nmol/L for D_2_ and 41.7 nmol/L for D_3_ and no participants remained in the deficient category (i.e., <49.9 nmol/L). The percentage increase from baseline was higher among participants with lower baseline levels. Subsequent daily supplementation with 4,800 IU vitamin D_2_ or D_3_ plus 500 mg calcium resulted in a sustained elevation of serum levels over 21 days; by day 77, there was no difference between the D_2_ and placebo groups, while the D_3_ group had higher serum 25[OH] D levels than both (p<0.04).^137^

In another trial in the United States, 118 premenopausal women, ages 18 to 50 years, with bacterial vaginosis received nine doses of 50,000 IU D_3_ or placebo over 24 weeks. At baseline, 71 percent of women randomized to the D_3_ group were deficient in vitamin D (i.e., <49.9 nmol/L) and after 24 weeks, only 16 percent remained deficient. In the placebo group, the percentage of women who were vitamin D deficient decreased from 68 percent at baseline to 57 percent at 24 weeks.^139^

Finally, a small trial in Nebraska evaluated 1,000 IU, 5,000 IU, and 10,000 IU of daily vitamin D_3_ over 21 weeks in winter among 62 obese (but generally healthy) participants, age 19 to 68 years.^138^ The mean baseline 25[OH] D level among participants was 58.2 nmol/L (standard deviation (SD) 25.7 nmol/L). Serum 25[OH] D levels increased among participants in all groups, although there was substantial variability (mean increases of 31.0 nmol/L [SD 24.2 nmol/L], 69.4 nmol/L [SD 25.5 nmol/L], and 126.5 nmol/L [SD 40.9 nmol/L] in the 1,000 IU, 5,000 IU, and 10,000 IU groups, respectively). When authors compared results to a similar study among nonobese participants, they reported that the vitamin D dose response was 30 percent lower in obese than in nonobese participants.^138^

### Contextual Question 2. What is the association between vitamin D status and fracture outcomes?

#### Summary of Findings

Findings from observational studies regarding the association between vitamin D status as measured by serum 25 [OH] D levels and fracture risk are mixed. Some studies demonstrated a significant negative relationship (lower serum levels associated with increased risk), fewer studies demonstrated no association, and a few studies demonstrated an unclear or complex association (i.e., a “J” shaped risk curve). Effect estimates for many studies were imprecise, with confidence intervals that span the null effect. The 2007 AHRQ Evidence Report^14^ included 15 studies; these were summarized in both the 2009 AHRQ evidence report^15^ and in the 2011 review for the USPSTF^2^ with a conclusion of “mixed effects” on fracture incidence. The 2014 update to the AHRQ Evidence Report^17^ identified eight new observational studies, seven of which are relevant to this question. Findings from these new studies were also inconsistent with respect to effect on several fracture types (osteoporotic, nonvertebral, and hip) overall and among subgroups identified by race and ethnicity. These studies were conducted among heterogeneous populations that were followed for a varied number of years.^17^ We identified eight additional observational studies published since the 2014 AHRQ Evidence Report that evaluated the association between serum concentrations of vitamin D and fracture risk over periods from 1 to 19.6 years. The findings from these studies were largely consistent with the conclusions of the prior Evidence Reports, with some studies demonstrating a higher risk of fracture in association with lower serum 25 [OH] D levels and fewer studies demonstrating no effect. This body of evidence is limited by differences in the ways in which vitamin D exposure categories are defined.

#### Detailed Findings From AHRQ Evidence Reports

Findings from 3 prospective cohort and 12 case-control studies, first reported in the 2007 AHRQ Evidence Report^14^ and summarized in both the 2009 AHRQ Evidence Report Update^15^ and 2011 update for the USPSTF,^2^ were inconsistent. One of three cohort studies reported higher fracture rates with lower serum 25[OH] D levels, and nine of 12 case-control studies reported lower serum 25[OH] D levels among cases when compared with controls.^14^

The 2014 AHRQ Evidence Report relied on seven observational studies, new since 2009, to evaluate the association between vitamin D status and fracture risk: two studies evaluated the risk of total osteoporotic fractures, two studies evaluated the risk of nonvertebral fractures, and five studies evaluated the risk of hip fractures.^17^ Studies were assessed for quality with a checklist designed for nutritional epidemiology studies using STROBE (Strengthening the Reporting of Observational Studies in Epidemiology) and graded (A, B, or C) according to the grading system in the AHRQ Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews.

Total Fractures. Two “A-quality” cohort studies among healthy, community-dwelling postmenopausal women evaluated total fractures over mean followup periods of 5.2 and 8.6 years. The study conducted in Saudi Arabia reported an increased risk of total osteoporotic fractures (RR, 1.25 [95% CI, 0.91 to 1.70]) for women with serum 25[OH] D levels less than 17.9 nmol/L as compared with higher levels. Among white women in the observational phase of the Women’s Health Initiative (WHI), women with serum 25[OH] D levels greater than 50 nmol/L were 18 percent (serum 25[OH] D: 50 to <75 nmol/L) and 64 percent (serum 25[OH] D: ≥75 nmol/L) less likely to have a fracture than women with levels less than 50 nmol/L. Results among subgroups of women identified by race were inconsistent.

Nonvertebral Fractures. Two “B-quality” studies of nonvertebral fractures, one a nested case-control study among 777 older men (mean age 74 years) and the other a prospective cohort among 2,494 men and women, found no significant associations between serum 25[OH] D levels and nonvertebral fracture risk over periods of 4.6 and 2 years, respectively.

Hip Fractures. Five prospective cohorts (3 “A-quality” and 2 “B-quality”) with median follow up periods of 6.4 to 11 years reported inconsistent results regarding an association between serum 25[OH] D and hip fractures. The WHI observational study reported a 33 percent increased risk for every decrease of 25 nmol/L of serum 25[OH] D among postmenopausal women over 7.1 years. This finding is consistent with the Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) among 21,774 men and women (mean age 72 years); there was a 38 percent increase in risk for hip fracture among participants with serum 25[OH] D less than 42.2. nmol/L compared with participants with levels greater than or equal to 67.9 nmol/L. Nonsignificant increases in risk of hip fractures with lower serum 25[OH] D levels were reported in three other cohort studies; in the National Health and Nutrition Examination Survey (NHANES) III, serum levels of 25 [OH] D were a predictor of hip fracture risk within 10 years of followup, but not after 10 years.

#### Detailed Findings From Studies Published After the 2014 AHRQ Evidence Report

We identified eight additional observational studies, new since the 2014 AHRQ Evidence Report that evaluated the association between serum concentrations of vitamin D and fracture risk (Appendix A Table 2).^141-148^ Four of these studies reported an increased fracture risk in association with lower serum 25 [OH] D levels^142,^ ^143,^ ^147,^ ^148^; one study reported no association between serum levels and fracture risk^144^; one study reported a J-shaped association between serum levels and fracture risk^145^; and two studies reported mixed findings depending on fracture type and level of vitamin D insufficiency.^141,^ ^146^ Populations, fracture type, followup time, and definitions of vitamin D deficiency and sufficiency varied across these studies.

Total Fractures. Four prospective cohort studies^142,^ ^144,^ ^145,^ ^147^ evaluated serum 25[OH] D levels and the risk of incident fractures over followup periods of 1 to almost 20 years; mean baseline serum 25[OH] D levels ranged from 49.9 to 62.0 nmol/L in the studies, and findings were inconsistent. In the Atherosclerosis Risk in Communities (ARIC) study, baseline serum 25[OH] D levels were higher among white participants (mean 63.9 nmol/L) than among black participants (mean 45.4 nmol/L); 23 percent of white and 61 percent of black participants had serum levels less than 49.9 nmol/L. There was a 21 percent increase in risk (HR, 1.21 [95% CI, 1.05 to 1.39]) of incident hospitalized fractures after 19.6 years among participants with baseline serum levels less than 49.9 nmol/L compared with levels greater than or equal to 49.9 nmol/L. These findings held true among white, but not black participants when the analysis was stratified by race, and for nonusers of vitamin D supplements at baseline.^142^ In prospective cohort studies among older residents of Germany over 1 year^147^ and of Sweden over 10 years,^144^ there were no differences in incident fracture by baseline serum 25[OH] D levels. In the Swedish Osteoporotic Prospective Risk Assessment (OPRA) cohort there was an increase in risk among women with continuously low (<50 nmol/L) serum 25[OH] D levels over 10 years compared with women with continuously high (>75 nmol/L) serum 25[OH] D levels (HR, 1.7 [95% CI, 1.1 to 2.6]).^144^ Finally, there was a U-shaped association between serum 25[OH] D levels and incident fractures (confirmed by radiographic reports) among community-dwelling men, age 70 years or older, in the Australian Concord Health Ageing in Men Project (CHAMP) over a mean 4.3 years.^145^ Hazard ratios were significantly increased for men with baseline serum levels in the first and the fifth quintiles (3 to 36 nmol/L and 72 to 148 nmol/L, respectively) when compared to the fourth quintile (>59 to 72 nmol/L); this relationship was similar among men who were not supplementing with vitamin D at baseline.^145^

Nonvertebral Fractures. There was no association between serum 25[OH] D levels and nonvertebral fracture risk in the Osteoporotic Fractures in Men (MrOS) case-cohort study.^141^ In a hospital-based case-control study in Germany, where controls were orthopedic patients presenting with back pain without fracture, there was a significant difference in serum 25[OH] D levels; 78 percent of cases with nonvertebral fractures and only 52 percent of controls were categorized as vitamin D deficient (<30 nmol/L) (p=0.032). Results remained the same after adjusting for gender, renal failure, and other potential confounders.^143^

Hip Fractures. Four prospective cohort studies^142,^ ^144,^ ^146,^ ^148^ and one case-cohort study^149^ evaluated serum 25[OH] D levels and the risk of hip fractures over followup periods of 5 to almost 20 years; mean baseline serum 25[OH] D levels ranged from 46.8 to 62.2 nmol/L and findings were relatively consistent among participants with the lowest serum 25[OH] D levels across the studies. The Health 2000 Survey in Finland reported a 46 percent increase in the risk of hip fractures over a mean 8.4 years for each serum 25[OH] D reduction of 17.5 nmol/L among men age 50 years or older (HR, 1.46 [95% CI, 1.15 to 1.83]).^148^ A significant increase in hip fracture risk was associated with depleted (<30 nmol/L) but not inadequate (30 to <50 nmol/L) or high (>75 nmol/L) levels of serum 25[OH] D in a random selection of Iceland’s population over a mean 5.4 years in the Ages Gene/Environment Susceptibility (AGES) study. Authors suggested that 15 percent of fractures may have been attributable to depleted vitamin D levels.^146^ In Sweden’s OPRA study, there were no differences in baseline serum 25[OH] D levels among those with and without hip fractures after 10 years, but there was a significant increase in hip fracture risk among women with continuously low serum 25[OH] D levels (HR, 2.7 [95% CI, 1.4 to 5.3]).^144^ Hip fracture risk was also elevated in the ARIC study among participants with depleted serum 25[OH] D levels (<49.9 nmol/L)^142^ and in the MrOS case-cohort study, where participants with serum levels in the first quartile (7.8 to 52.17 nmol/L) were compared with all other participants.^141^

Appendix A Table 2 Results Of Studies Published Since The 2014 AHRQ Evidence Report^17^ Evaluating The Association Between Serum Vitamin D Levels And Fractures

Author (Year) Study | Study Design Country | Population (N) Mean Age (SD) | Baseline Serum 25[OH]D levels | Length of Follow-up | Serum 25[OH] D Comparisons | Outcome (N) | Result(s)
Bleicher, 2014^145^ Concord Health and Ageing in Men Project (CHAMP) | Prospective cohort Australia | Community-dwelling men, age 70 years and older (1,705) 77 (5.5) | Mean 55.8 nmol/L | Mean 4.3 yrs | Quintiles: 1: 3-36 nmol/L 2: >36-48 nmol/L 3: >48-59 nmol/L 4: >59-72 nmol/L 5: >72-148 nmol/L | Incident fractures confirmed by radiographic reports, excluding pathological fractures and fractures of hands, feet, and head (123) | 1: HR, 3.5 (95% CI, 1.7 to 7.0)^*^ 2: HR, 1.9 (95% CI, 0.9 to 4.0)^*^ 3: HR, 1.4 (95% CI, 0.6 to 3.0)^*^ 4: Reference 5: HR, 2.7 (95% CI, 1.3 to 5.4)^*^
Buchebner, 2014^144^ Osteoporotic Prospective Risk Assessment (OPRA) Cohort | Prospective cohort Sweden | Random subset of women, age 75 years, in the longitudinal population-based cohort (1,044)^†^ 75 (0.1) | Mean 62.0 nmol/L Low (<50 nmol/L): 28% Intermediate (50-75 nmol/L): 49% High (>75 nmol/L): 23% | 10 years | Category of serum 25[OH]D at baseline Low: <50 nmol/L Intermediate: 50-75 nmol/L High: >75 nmol/L | Hip fractures (126) | Fracture Incidence Low: 14.8% Intermediate: 12.4% High: 9.7% p=0.20
Buchebner, 2014^144^ Osteoporotic Prospective Risk Assessment (OPRA) Cohort | Prospective cohort Sweden | Random subset of women, age 75 years, in the longitudinal population-based cohort (1,044)^†^ 75 (0.1) | Mean 62.0 nmol/L Low (<50 nmol/L): 28% Intermediate (50-75 nmol/L): 49% High (>75 nmol/L): 23% | 10 years | Category of serum 25[OH]D at baseline Low: <50 nmol/L Intermediate: 50-75 nmol/L High: >75 nmol/L | Major osteoporotic fractures (334) | Low: 35.2% Intermediate: 31.8% High: 33.1% p=0.18
Kauppi, 2013^148^ Health 2000 Survey Followup | Prospective cohort Finland | Participants of the Health 2000 Survey, age 50 years and older at baseline, with calcaneal quantitative ultrasound data (3,305) 63 (9.8) | 46.8 nmol/L | Mean 8.4 years | Reduction of 17.5 nmol/L [1 SD of 25[OH] D] | First hip fractures (89) | HR, 1.46 (95% CI, 1.15 to 1.83)^‡^ for participants with lower serum levels compared to higher levels
Maier, 2015^143^ | Hospital-based case-control Germany | Cases were patients admitted to the hospital with a vertebral fracture (246); Controls were orthopedic patients presenting with back pain without a fracture^*^ (392) Cases: 69 (8.5) Controls: 63 (11) | NA | NA | Cases versus controls | Serum 25[OH] D levels | Significant difference in serum 25[OH] D levels between cases and controls (p=0.036) [underlined: Holick Standards] Vitamin D Sufficiency= ≥70 nmol/L 89% of cases had abnormally low levels (mean, 38.6 nmol/L [SD, 18.2 nmol/L]) compared to 60% of controls (mean, 49.1 nmol/L [SD, 20.8 nmol/L]) (p=0.036) [underlined: National Osteoporosis Society Thresholds] Deficient: <30 nmol/L Inadequate: 30-50 nmol/L Adequate: >50 nmol/L 78% of cases were deficient (mean, 38.6 nmol/L [SD, 23.7 nmol/L]) compared to 52% of controls (mean, 49.2 nmol/L [SD, 26.2 nmol/L]) (p=0.032)
Rothenbacher, 2013 ^147^ Activity and Function in the Elderly in Ulm (ActiFE Ulm) Study | Prospective cohort Germany | Population-based cohort of noninstitutionalized residents of Ulm and adjacent regions in Southern Germany, age 65 years or older (1,385) 75.6 (6.5) | 49.9 nmol/L Deficient (<50 nmol/L): 684 (49%) Insufficient (50 to <75 nmol/L): 574 (41%) Normal (≥75 nmol/L): 127 (9%) | 1 year | Category of serum 25[OH] D levels at baseline Deficient: <50 nmol/L Insufficient: 50-<75 nmol/L Normal: ≥75 nmol/L | Incident fractures reported via a falls calendar (44) | Fracture rate per 1,000 person-years Deficient: 35 (95% CI, 23 to 53) Insufficient: 36 (95% CI, 22 to 56) Normal: 8 (95% CI, 0 to 45)
Steingrimsdottir, 2014^146^ Ages Gene/Environment Susceptibility (AGES) Study | Prospective Cohort Iceland | Random selection from national registry of men and women living in Reykjavik, age 66 to 96 years (5,461) 76 (NR) | Men: 57 nmol/L Women: 51 nmol/L Depleted (<30 nmol/L): 938 (17%) Insufficient (30- <50 nmol/L): 1,620 (30%) Sufficient (50-<75 nmol/L): 1,989 (36%) High (⩾75 nmol/L): 914 (17%) | Mean 5.4 years | Category of serum 25[OH]D at baseline Depleted: <30 nmol/L Inadequate: 30-<50 nmol/L Sufficient: 50-<75 nmol/L High: ⩾75 nmol/L | Incident hip fractures, confirmed from medical and radiological records (261) | Depleted: HR, 2.08 (95% CI, 1.51 to 2.87)^§^ Inadequate: HR, 1.11 (95% CI, 0.80 to 1.53)^§^ Sufficient: Reference High: HR, 0.94 (95% CI, 0.62 to 1.41)^§^
Swanson, 2015^141^ Osteoporotic Fractures in Men Study (MrOS) | Case-cohort US | Ambulatory men, age 65 years and older, without bilateral hip replacements (1,000)^‖^ 74.6 (6.2) | 62.2 (±19.5) Nonvertebral fracture cases: 61.2 nmol/L (SD, 19.2 nmol/L) Hip fracture cases: 52.2 nmol/L (SD, 19.2 nmol/L) | Mean 5.1 years | 1 SD increase in serum 25[OH] D | Incident nonvertebral fractures (432) | HRs ranged from 0.97 to 1.02 in base and multivariable analyses, all nonsignificant
Swanson, 2015^141^ Osteoporotic Fractures in Men Study (MrOS) | Case-cohort US | Ambulatory men, age 65 years and older, without bilateral hip replacements (1,000)^‖^ 74.6 (6.2) | 62.2 (±19.5) Nonvertebral fracture cases: 61.2 nmol/L (SD, 19.2 nmol/L) Hip fracture cases: 52.2 nmol/L (SD, 19.2 nmol/L) | Mean 5.3 years | 1 SD increase in serum 25[OH]D 1^st^ quartile (7.8 to 52.17 nmol/L) vs all other quartiles combined | Incident hip fractures (81) | HR, 0.69 (95% CI, 0.52 to 0.91)^¶^ HR, 2.05 (95% CI, 1.28 to 3.29)^¶^
Takiar, 2015^142^ Atherosclerosis Risk in Communities (ARIC) | Prospective cohort US | Middle-aged adults (12,781) 57 (5.7) | All: 59.2 nmol/L White: 63.9 nmol/L Black: 45.4 nmol/L | Mean 19.6 years | <49.9 nmol/L vs ⩾:49.9 nmol/L at baseline | Incident hospitalized fractures (1,122) | HR, 1.21 (95% CI, 1.05 to 1.39)
Takiar, 2015^142^ Atherosclerosis Risk in Communities (ARIC) | Prospective cohort US | Middle-aged adults (12,781) 57 (5.7) | All: 59.2 nmol/L White: 63.9 nmol/L Black: 45.4 nmol/L | Mean 19.6 years | <49.9 nmol/L vs ⩾49.9 nmol/L at baseline | Hip fractures (267) | HR, 1.35 (95% CI, 1.02 to 1.79)

* Adjusted for age, country of birth, BMI, physical activity, season of blood draw, previous low-trauma fracture after age 50 (10% of men), calcium supplement, and vitamin D supplement.

† The number of women evaluated at 5 years was 715 and at 10 years was 382.

‡ Adjusted for gender, age, height, weight, BMI, serum 25[OH] D, quantitative ultrasound index, alcohol consumption, smoking status, and physical activity.

§ Adjusted for age at recruitment, sex, height, BMI, current smoking, season of blood sampling, alcohol intake, and current physical activity.

‖ Includes 679 participants from the random cohort, including 111 nonvertebral fractures, and 321 nonvertebral fracture cases.

¶ Adjusted for age, race, site, season, physical activity, height, and weight.

Abbreviations: BMI=body mass index; CI, confidence interval; HR=hazard ratio; N=number; NA=not applicable; NR=not reported; nmol/L=nanomol e per liter; SD=standard deviation; U.S.=United States; 25[OH] D=vitamin D.

Appendix A Table 3 Estimates of Current Vitamin D and Calcium Intake Compared With Recommended Dietary Allowance for Adults Age >20 Years

Nutrient | % Reporting Supplement Use (SE)^*^,^†^ | Average Intake From Supplements^*^ (SE) | Average Dietary Intake Among Users of Supplements^*^ (SE) | Average Dietary Intake Among Nonusers of Supplements^*^ (SE) | Recommended Dietary Allowance^‡^
Vitamin D
Men | 27 (1.7) | 1,224 IU (4.4) | 248 IU (22.8) | 208 IU (8) | 600 IU 800 IU (> age 70)
Women | 35 (2.0) | 1,588 IU (148) | 160 IU (6) | 156 IU (6) | 600 IU 800 IU (> age 70)
Calcium
Men | 26 (1.7) | 338 mg (15.7) | 1,168 mg (40.0) | 1,099 mg (19.6) | 1,000 mg 1,200 mg (> age 70)
Women | 33 (2.0) | 605 mg (28.0) | 1,021 mg (26.8) | 1,010 mg (14.5) | 1,000 mg 1,200 mg (> age 50)

* Based on NHANES 2011 -2012 24-hour dietary recall and includes both single vitamin or mineral supplement and multivitamin or mineral supplement.^44^

† Other authors used NHANES data to estimate the prevalence of single supplement use based on past 30-day self-reported recall. They reported a prevalence of vitamin D use among adults of 19 percent (95% CI, 17 to 22), and a prevalence of calcium use of 35 percent (95% CI, 33 to 37) based on 2011 -12 NHANES data.^52^

‡ Based on: Dietary Reference Intakes for Calcium and Vitamin D. IOM (Institute of Medicine). 2011 Washington, DC: The National Academies Press.^5^

Abbreviations: IU=international units; mg=milligram; NHANES=National Health and Nutrition Examination Survey; SE=standard error.

Appendix A Table 4 Summary of Recommendations for Vitamin D and Calcium Intake

Organization (Year) | Recommendation^*^
American Academy of Family Physicians (2013)^150^ | Same as current USPSTF recommendation
American Congress of Obstetricians and Gynecologists (2012)^151^ | Same as NAM recommendations
National Academy of Medicine (formerly Institute of Medicine)^5^ | Vitamin D 600 IU/d age 19-70; 800 IU/D age >70 Calcium: 1,000 mg/d age 19-50 for women and age 19-70 for men; 1,200 mg/d > age 50 for women and age >70 for men
National Osteoporosis Foundation (2014)^30^ | Vitamin D: 800-1,000 IU/d age >50 Calcium: same as NAM recommendation
American Association of Clinical Endocrinologists (2016)^152^ | Vitamin D: Assess for deficiency, maintain serum 25 [OH] D levels ⩾30 ng/ml (75 nmol/L) Calcium: 1,200 mg/d (diet and/or supplement) for women age >50
Osteoporosis Canada (2010)^153^ | Vitamin D: 400 -1,000 IU/d supplementation for adults at low risk for vitamin D deficiency, 800-1,000 IU/d for adults > 50 at moderate risk of deficiency Calcium: 1,200 mg/d (through diet and supplements) for adults age >50
American College of Rheumatology (2010)^154^ | These recommendations apply to patients receiving glucocorticoid therapy Vitamin D: 800-1,000 IU/d or amount required to achieve therapeutic levels Calcium: 1,200-1,500 mg/d from diet and supplements
American Association of Orthopedic Surgeons (2012)^155^ | Same as NAM recommendations
Endocrine Society (2011)^156^ | Vitamin D: Same as NAM recommendation, higher doses may be required to treat deficiency Calcium: None

* Some of the recommendations are specific to general dietary intake for all persons, while some are specific to persons with osteoporosis or who have risks for secondary osteoporosis.

Abbreviations: d=day; IU=international units; mg=milligram; NAM=National Academy of Medicine (formerly Institute of Medicine); ng/ml=nanogram per milliliter; nmol/L=nanomole per liter; USPSTF=U.S. Preventive Services Task Force.

Appendix A Table 5 Related USPSTF Recommendations

Vitam in D and Calcium Supplementation (2013)^1^
Population | Community-dwelling men or premenopausal women | Community-dwelling postmenopausal women
Recommendation | I | I | D
Intervention | Vitamin D/Calcium | Vitamin D_3_ >400 IU Calcium >1,000 mg | Vitamin D_3_ ⩽400 IU Calcium ⩽1,000 mg
Balance of benefits and harms | Inadequate evidence to judge | Inadequate evidence to judge | No effect on incidence of fracture ⩾ no net benefit
Vitam in D Screening (2015)^54^
Population | Community-dwelling Adults
Recommendation | I
Intervention | Screening for vitamin D deficiency and treatment if deficient
Balance of benefits and harms | Inadequate evidence to judge
Falls Prevention Older Adults: Interventions (2018)^62^
Population | Community-dwelling adults age ⩾65 who are at increased risk for falls
Recommendation | B | C | D
Intervention | Exercise interventions | Multifactorial interventions | Vitamin D supplementation
Balance of benefits and harms | Exercise interventions have a moderate benefit in preventing falls in older adults at increased risk for falls; harms are no greater than small. | Multifactorial interventions have a small benefit in preventing falls in older adults at increased risk for falls; harms are no greater than small. | Vitamin D supplementation has no benefit in preventing falls in older adults; harms of supplementation are small to moderate.
Vitamin Supplementation to Prevent Cancer and Cardiovascular Disease: Counseling (2014)^58^
Population | Healthy adults without special nutritional needs
Recommendation | I | I | D
Intervention | Use of multivitamins to prevent cardiovascular disease or cancer | Single- or paired-nutrient supplements for prevention of cardiovascular disease or cancer | Use of β-carotene or vitamin E for prevention of cardiovascular disease or cancer
Balance of benefits and harms | Inadequate evidence to judge | Inadequate evidence to judge | Evidence of harms related to β-carotene and evidence of no effect related to vitamin E ->no net benefit
Screening for Osteoporosis (2011)^56^
Population | Women age 65 or over | Women younger than 65 with fracture risk equivalent to 65-year-old woman | Men
Recommendation | B | B | I
Intervention | BMD assessment using DXA | BMD assessment using DXA | N/A
Balance of benefits and harms | Screening with DXA has at least moderate benefit. | | Balance of harms and benefits cannot be determined.

Abbreviations: BMD=bone mineral density; DXA=dual-energy x-ray absorptiometry; IU=international units; mg=milligram; USPSTF=U.S. Preventive Services Task Force.