# References

1 Stanford JL, Stephenson RA, Coyle LM, et al. Prostate Cancer Trends 1973-1995. SEER Program, National Cancer Institute. NIH Pub. No. 99-4543. Bethesda, MD. 1999. [pmcid: 325679].
2 United States Preventive Services Task Force. Guide to Clinical Preventive Services. Second Ed. Alexandria, Va: International Medical Publishing, Inc. 1996:119-134. [pmcid: 161086].
3 American College of Physicians. Screening for prostate cancer. Ann Intern Med. 1997;126:480-484. [pmid: 9072936].
4 American Academy of Family Physicians. Summary of AAFP Policy Recommendations & Age Charts. December, 2001; accessed June 3, 2002. Web Page. Available at: http://www.aafp.org/exam/pos_gen_guide.html.
5 American Urological Association. Prostate-specific antigen (PSA) best practice policy. Oncology. 2000;14:267-272, 277-278, 280. [pmid: 10736812].
6 Smith RA, von Eschenbach AC, Wender R, et al. American Cancer Society guidelines for the early detection of cancer: update of early detection guidelines for prostate, colorectal, and endometrial cancers. Also: update 2001--testing for early lung cancer detection. CA Cancer J Clin. 2001;51:38-75. quiz. 77. 80.
7 American Cancer Society. Prostate Cancer: National Estimates. 2000. Available at: http://www3.cancer.org/cancerinfo/sitecenter.asp?SCDoc=42074&CTID=8&PNT=0&SCS=4&SCSS=3&SCP=8%2E3%2E4%2E42071 (http://www3.cancer.org/cancerinfo/sitecenter.asp?SCDoc=42074&CTID=8&PNT=0&SCS=4&SCSS=3&SCP=/hstatImg/3724/8%2E3%2E4%2E42071): Accessed April 2000. [pmcid: 384376].
8 Newschaffer CJ, Otani K, McDonald MK, Penberthy LT. Causes of death in elderly prostate cancer patients and in a comparison nonprostate cancer cohort. J Natl Cancer Inst. 2000;92:613-621. [pmid: 10772678].
9 Hankey BF, Feuer EJ, Clegg LX, et al. Cancer surveillance series: interpreting trends in prostate cancer--part I: Evidence of the effects of screening in recent prostate cancer incidence, mortality, and survival rates. J Natl Cancer Inst. 1999;91:1017-1024. [pmid: 10379964].
10 Ross RK, Schottenfeld D. Prostate Cancer. In: Schottenfeld D, Fraumeni, JF Jr, Eds. Cancer Epidemiology and Prevention. 2nd Ed. New York, NY: Oxford University Press. 1996:1180-1206. [pmcid: 163287].
11 Stat bite: Average years of life lost from cancer. J Natl Cancer Inst. 2001.
12 Greenlee R, Hill-Harmon M, Murray T, Thun M. Cancer Statistics, 2001. CA Cancer J Clin. 51:15-36. [pmid: 11577478].
13 US. Congress OTA. Costs and Effectiveness of Prostate Cancer Screening in Elderly Men. Washington, DC: U.S. Government Printing Office. 1995. [pmcid: 441483].
14 Ries L, Eisner M, Kosary C, et al. SEER Cancer Statistics Review, 1973-1997. Natl Cancer Inst. 2000. NIH Pub. No. 00-2789:393.
15 Ross KS, Carter HB, Pearson JD, Guess HA. Comparative efficiency of prostate-specific antigen screening strategies for prostate cancer detection. JAMA. 2000;284:1399-1405. [pmid: 10989402].
16 Wynder EL, Mabuchi K, Whitmore WF Jr. Epidemiology of cancer of the prostate. Cancer. 1971;28:344-360. [pmid: 5109447].
17 Bostwick DG. Grading prostate cancer. Am J Clin Pathol. 1994;102:S38-56. [pmid: 7524306].
18 Bostwick DG. Gleason grading of prostatic needle biopsies. Correlation with grade in 316 matched prostatectomies. Am J Surg Pathol. 1994;18:796-803. [pmid: 8037294].
19 Harris RP, Helfand M, Woolf SH, et al Current Methods of the U.S. Preventive Services Task Force. A review of the process Am J Prev Med. 2001 20(Suppl 3):21 35 11306229
20 Labrie F, Candas B, Dupont A, et al. Screening decreases prostate cancer death: first analysis of the 1988 Quebec prospective randomized controlled trial. Prostate. 1999;38:83-91. [pmid: 9973093].
21 Friedman G, Hiatt R, Quesenberry C, Selby J. Case-control study of screening for prostatic cancer by digital rectal examinations. Lancet. 1991;337:1526-1529. [pmid: 1675379].
22 Richert-Boe KE, Humphrey LL, Glass AG, Weiss NS. Screening digital rectal examination and prostate cancer mortality: a case-control study. J Med Screen. 1998;5:99-103. [pmid: 9718529].
23 Jacobsen SJ, Bergstralh EJ, Katusic SK, et al. Screening digital rectal examination and prostate cancer mortality: a population-based case-control study. Urology. 1998;52:173-179. [pmid: 9697778].
24 Weiss NS, Friedman GD, van den Eeden S. Digital rectal examination and mortality from prostate cancer. Urology. 1999;53:863-864. [pmid: 10197878].
25 Concato J. What is a screening test? Misclassification bias in observational studies of screening for cancer. J Gen Intern Med. 1997;12:607-612. [pmid: 9346456].
26 Concato J, Peduzzi P, Kamina A, Horwitz RI. A nested case-control study of the effectiveness of screening for prostate cancer: research design. J Clin Epidemiol. 2001;54:558-564. [pmid: 11377115].
27 Tarone RE, Chu KC, Brawley OW. Implications of stage-specific survival rates in assessing recent declines in prostate cancer mortality rates. Epidemiology. 2000;11:167-170. [pmid: 11021614].
28 Feuer EJ, Merrill RM, Hankey BF. Cancer surveillance series: interpreting trends in prostate cancer--part II: Cause of death misclassification and the recent rise and fall in prostate cancer mortality. J Natl Cancer Inst. 1999;91:1025-1032. [pmid: 10379965].
29 Brawley OW. Prostate carcinoma incidence and patient mortality: the effects of screening and early detection. Cancer. 1997;80:1857-63. [pmid: 9351560].
30 Meyer F, Moore L, Bairati I, Fradet Y. Downward trend in prostate cancer mortality in Quebec and Canada. J Urol. 1999;161:1189-1191. [pmid: 10081867].
31 Roberts RO, Bergstralh EJ, Katusic SK, Lieber MM, Jacobsen SJ. Decline in prostate cancer mortality from 1980 to 1997, and an update on incidence trends in Olmsted County, Minnesota. J Urol. 1999;161:529-533. [pmid: 9915441].
32 Oliver SE, Gunnell D, Donovan JL. Comparison of trends in prostate-cancer mortality in England and Wales and the USA. Lancet. 2000;355:1788-1789. [pmid: 10832832].
33 Etzioni R, Legler JM, Feuer EJ, Merrill RM, Cronin KA, Hankey BF. Cancer surveillance series: interpreting trends in prostate cancer.--part III: Quantifying the link between population prostate-specific antigen testing and recent declines in prostate cancer mortality. J Natl Cancer Inst. 1999;91:1033-1039. [pmid: 10379966].
34 Legler JM, Feuer EJ, Potosky AL, Merrill RM, Kramer BS. The role of prostate-specific antigen (PSA) testing patterns in the recent prostate cancer incidence decline in the United States. Cancer Causes Control. 1998;9:519-527. [pmid: 9934717].
35 Gann P, Hennekens C, Stampfer M. A prospective evaluation of plasma prostate-specific antigen for detection of prostatic cancer. JAMA. 1995;273:289-294. [pmid: 7529341].
36 Schmid H.P., McNeal J.E., Stamey T.A Observations on the Doubling Time of Prostate Cancer Cancer. 1993 71(6):2031 2040 7680277
37 Tovar-Guzman V, Hernandez-Giron C, Lopez-Rios O, Lazcano-Ponce EC. Prostate cancer mortality trends in Mexico, 1980-1995. Prostate. 1999;39:23-27. [pmid: 10221262].
38 Levi F, La Vecchia C, Boyle P. The rise and fall of prostate cancer. Eur J Cancer Prev. 2000;9:381-385. [pmid: 11201675].
39 Albertsen PC, Walters S, Hanley JA. A comparison of cause of death determination in men previously diagnosed with prostate cancer who died in 1985 or 1995. J Urol. 2000;163:519-523. [pmid: 10647669].
40 Cole P, Rodu B. Declining cancer mortality in the United States. Cancer. 1996;78:2045-2048. [pmid: 8918396].
41 Bartsch G, Horninger W, Klocker H, et al. Decrease in prostate cancer mortallity following introduction of prostaste specific antigen (PSA) screening in the Federal State of Tyrol, Austria. J Urol. 2000;163.
42 Bartsch G, Horninger W, Klocker H, et al. Prostate cancer mortality after introduction of prostate-specific antigen mass screening in the Federal State of Tyrol, Austria(1). Urology. 2001;58:417-24. [pmid: 11549491].
43 Schroder FH, van der Cruijsen-Koeter I, de Koning HJ, Vis AN, Hoedemaeker RF, Kranse R. Prostate cancer detection at low prostate specific antigen. J Urol. 2000;163:806-812. [pmid: 10687982].
44 Catalona WJ, Richie JP, Ahmann FR, et al. Comparison of digital rectal examination and serum prostate specific antigen in the early detection of prostate cancer: results of a multicenter clinical trial of 6,630 men. J Urol. 1994;151:1283-1290. [pmid: 7512659].
45 Richie J.P., Catalona W.J., Ahmann F.R., et al. Effect of patient age on early detection of prostate cancer with serum prostate specific cancer with serum prostate specific antigen and digital rectal examination. Urology. 1993;42:365-374. [pmid: 7692657].
46 Chodak GW, Thisted RA, Gerber GS, et al. Results of conservative management of clinically localized prostate cancer. N Engl J Med. 1994;330:242-248. [pmid: 8272085].
47 Albertsen PC, Hanley JA, Gleason DF, Barry MJ. Competing risk analysis of men aged 55 to 74 years at diagnosis managed conservatively for clinically localized prostate cancer. JAMA. 1998;280:975-80. [pmid: 9749479].
48 Johansson J, Holmberg L, Johansson S, Bergstrom R, Adami H. Fifteen-year survival in prostate cancer. A prospective, population-based study in Sweden. JAMA. 1997;277:467-471. [pmid: 9020270].
49 Roach M, Lu J, Pilepich MV, et al. Four prognostic groups predict long-term survival from prostate cancer following radiotherapy alone on Radiation Therapy Oncology Group clinical trials [published erratum appears in Int J Radiat Oncol Biol Phys 2000 Aug 1;48(1):313]. Intl J Radiat Oncol Biol Phys. 2000;47:609-615.
50 Pound CR, Partin AW, Eisenberger MA, Chan DW, Pearson JD, Walsh PC. Natural history of progression after PSA elevation following radical prostatectomy. JAMA. 1999;281:1591-1597. [pmid: 10235151].
51 Woolf SH. Defining clinically insignificant prostate cancer. JAMA. 1996;276:28-29. [pmid: 8667530].
52 Keetch DW, Catalona WJ, Smith DS. Serial prostatic biopsies in men with persistently elevated serum prostate specific antigen values. J Urol. 1994;151:1571-1574. [pmid: 7514690].
53 Djavan B, Zlotta A, Remzi M, et al. Optimal predictors of prostate cancer on repeat prostate biopsy: a prospective study of 1,051 men. J Urol. 2000;163:1144-1149. [pmid: 10737484].
54 Rabbani F, Stroumbakis N, Kava BR, Cookson MS, Fair WR. Incidence and clinical significance of false-negative sextant prostate biopsies. J Urol. 1998;159:1247-1250. [pmid: 9507846].
55 Levine M.A., Ittman M., Melamed J., Lepor H. Two consecutive sets of transrectal ultrasound guided sextant biopsies of the prostate for the detection of prostate cancer. J Urol. 1998;159:471-476. [pmid: 9649265].
56 Terris MK. Sensitivity and specificity of sextant biopsies in the detection of prostate cancer: preliminary report. Urology. 1999;54:486-489. [pmid: 10475359].
57 McNaughton Collins M, Ransohoff DF, Barry MJ. Early detection of prostate cancer. Serendipity strikes again. JAMA. 1997;278:1516-1519. [pmid: 9363972].
58 Mettlin C, Murphy GP, Babaian RJ, et al. The results of a five-year early prostate cancer detection intervention. Investigators of the American Cancer Society National Prostate Cancer Detection Project. Cancer. 1996;77:150-159. [pmid: 8630923].
59 Jacobsen SJ, Bergstralh EJ, Guess HA, et al. Predictive properties of serum-prostate-specific antigen testing in a community-based setting. Arch Intern Med. 1996;156:2462-2468. [pmid: 8944739].
60 Meigs JB, Barry MJ, Oesterling JE, Jacobsen SJ. Interpreting results of prostate-specific antigen testing for early detection of prostate cancer. J Gen Intern Med. 1996;11:505-512. [pmid: 8905498].
61 Oesterling J, Jacobsen S, Chute C, et al. Serum prostate-specific antigen in a community-based population of healthy men. Establishment of age-specific reference ranges. JAMA. 1993;270:860-864. [pmid: 7688054].
62 Morgan TO, Jacobsen SJ, McCarthy WF, Jacobson DJ, McLeod DG, Moul JW. Age-specific reference ranges for prostate-specific antigen in black men. N Engl J Med. 1996;335:304-310. [pmid: 8663870].
63 Mettlin C, Littrup PJ, Kane RA, et al. Relative sensitivity and specificity of serum prostate specific antigen (PSA) level compared with age-referenced PSA, PSA density, and PSA change. Data from the American Cancer Society National Prostate Cancer Detection Project. Cancer. 1994;74:1615-1620. [pmid: 7520352].
64 Catalona WJ, Southwick PC, Slawin KM, et al. Comparison of percent free PSA, PSA density, and age-specific PSA cutoffs for prostate cancer detection and staging. Urology. 2000;56:255-260. [pmid: 10925089].
65 Oesterling JE. Age-specific reference ranges for serum PSA. N Engl J Med. 1996;335:345-346. [pmid: 8663860].
66 Catalona WJ, Hudson MA, Scardino PT, et al. Selection of optimal prostate specific antigen cutoffs for early detection of prostate cancer: receiver operating characteristic curves. J Urol. 1994;152:2037-42. [pmid: 7525995].
67 Labrie F., DuPont A., Suburu R., et al. Serum prostate specific antigen as pre-screening test for prostate cancer. J Urol. 1992;147:846-852. [pmid: 1371560].
68 Catalona WJ, Smith DS, Ornstein DK. Prostate cancer detection in men with serum PSA concentrations of 2.6 to 4.0 ng/mL and benign prostate examination. Enhancement of specificity with free PSA measurements. JAMA. 1997;277:1452-1455. [pmid: 9145717].
69 Schroder F, Tribukait B, Bocking A, et al. Clinical utility of cellular DNA measurements in prostate carcinoma. Consensus Conference on Diagnosis and Prognostic Parameters in Localized Prostate Cancer. Stockholm, Sweden, May 12-13, 1993. Scand J Urol Nephrol Suppl. 1994;162:51-63. [pmid: 7529429].
70 Lodding P, Aus G, Bergdahl S, et al. Characteristics of screening detected prostate cancer in men 50 to 66 years old with 3 to 4 ng./ml. prostate specific antigen. J Urol. 1998;159:899-903. [pmid: 9474178].
71 Babaian RJ, Johnston DA, Naccarato W, Ayala A, Bhadkamkar VA, Fritsche HA HA Jr. The incidence of prostate cancer in a screening population with a serum prostate specific antigen between 2.5 and 4.0 ng/ml: relation to biopsy strategy. J Urol. 2001;165:757-60. [pmid: 11176461].
72 Catalona WJ, Ramos CG, Carvalhal GF, Yan Y. Lowering PSA cutoffs to enhance detection of curable prostate cancer. Urology. 2000;55:791-795. [pmid: 10840078].
73 Benson M.C., Whang I.S., Pantuck A., Ring K., Kaplan S.A., Olsson C.A. Prostate Specific Antigen Density: A Means of Distinguishing Benign Prostatic Hypertrophy and Prostate Cancer. J Urol. 1992;147:815-816. [pmid: 1371554].
74 Benson MC, Whang IS, Olsson CA, McMahon DJ, Cooner WH. The use of prostate specific antigen density to enhance the predictive value of intermediate levels of serum prostate specific antigen. J Urol. 1992;147:817-821. [pmid: 1371555].
75 Littrup PJ The American Cancer Society's National Prostate Cancer Detection Project Can J Oncol. 1994 4Suppl 1:65 69 8853493
76 Bangma CH, Grobbee DE, Schroder FH. Volume adjustment for intermediate prostate-specific antigen values in a screening population. Eur J Cancer. 1995;31A:12-14. [pmid: 7535074].
77 Catalona WJ, Richie JP, deKernion JB, et al. Comparison of prostate specific antigen concentration versus prostate specific antigen density in the early detection of prostate cancer: receiver operating characteristic curves. J Urol. 1994;152:2031-2036. [pmid: 7525994].
78 Rommel FM, Agusta VE, Breslin JA, et al. The use of prostate specific antigen and prostate specific antigen density in the diagnosis of prostate cancer in a community based urology practice. J Urol. 1994;151:88-93. [pmid: 7504748].
79 Beemsterboer PM, Kranse R, de Koning HJ, Habbema JD, Schroder FH. Changing role of 3 screening modalities in the European randomized study of screening for prostate cancer (Rotterdam). Intl J Cancer. 1999;84:437-441.
80 Stenman UH, Hakama M, Knekt P, Aromaa A, Teppo L, Leinonen J. Serum concentrations of prostate specific antigen and its complex with alpha 1-antichymotrypsin before diagnosis of prostate cancer. Lancet. 1994;344:1594-1598. [pmid: 7527116].
81 Stenman UH, Leinonen J, Alfthan H, Rannikko S, Tuhkanen K, Alfthan O. A complex between prostate-specific antigen and alpha 1- antichymotrypsin is the major form of prostate-specific antigen in serum of patients with prostatic cancer: assay of the complex improves clinical sensitivity for cancer. Cancer Res. 1991;51:222-226. [pmid: 1703033].
82 Mettlin C, Chesley AE, Murphy GP, et al. Association of free PSA percent, total PSA, age, and gland volume in the detection of prostate cancer. Prostate. 1999;39:153-158. [pmid: 10334103].
83 Catalona WJ, Beiser JA, Smith DS. Serum free prostate specific antigen and prostate specific antigen density measurements for predicting cancer in men with prior negative prostatic biopsies. J Urol. 1997;158:2162-2167. [pmid: 9366336].
84 Catalona WJ, Partin AW, Slawin KM, et al. Use of the percentage of free prostate-specific antigen to enhance differentiation of prostate cancer from benign prostatic disease: a prospective multicenter clinical trial. JAMA. 1998;279:1542-47. [pmid: 9605898].
85 Reissigl A, Klocker H, Pointner J, et al Usefulness of the ratio free/total prostate-specific antigen in addition to total PSA levels in prostate cancer screening Urology. 1996 48(Suppl 6A):62 66 8973702
86 Bangma CH, Kranse R, Blijenberg BG, Schroder FH. The value of screening tests in the detection of prostate cancer. Part II: Retrospective analysis of free/total prostate-specific analysis ratio, age-specific reference ranges, and PSA density. Urology. 1995;46:779-84. [pmid: 7502415].
87 Catalona WJ, Smith DS, Wolfert RL, et al. Evaluation of percentage of free serum prostate-specific antigen to improve specificity of prostate cancer screening. JAMA. 1995;274:1214-1220. [pmid: 7563511].
88 Bangma CH, Blijenberg BG, Schroder FH. Prostate-specific antigen: its clinical use and application in screening for prostate cancer. Scand J Clin Lab Invest. 1995;221:35-44.
89 Hoffman RM, Clanon DL, Littenberg B, Frank JJ, Peirce JC. Using the free-to-total prostate-specific antigen ratio to detect prostate cancer in men with nonspecific elevations of prostate-specific antigen levels. J Gen Intern Med. 2000;15:739-748. [pmid: 11089718].
90 Brawer MK, Meyer GE, Letran JL, et al. Measurement of complexed PSA improves specificity for early detection of prostate cancer. Urology. 1998;52:372-378. [pmid: 9730446].
91 Brawer MK, Cheli CD, Neaman IE, et al. Complexed prostate specific antigen provides significant enhancement of specificity compared with total prostate specific antigen for detecting prostate cancer. J Urol. 2000;163:1476-80. [pmid: 10751861].
92 Okihara K, Fritsche HA, Ayala A, Johnston DA, Allard WJ, Babaian RJ. Can complexed prostate specific antigen and prostatic volume enhance prostate cancer detection in men with total prostate specific antigen between 2.5 and 4.0 ng./ml. J Urol. 2001;165:1930-6. [pmid: 11371884].
93 Zhang WM, Finne P, Leinonen J, Salo J, Stenman UH. Determination of prostate-specific antigen complexed to alpha(2)-macroglobulin in serum increases the specificity of free to total PSA for prostate cancer. Urology. 2000;56:267-272. [pmid: 10925092].
94 Carter H, Pearson J, Metter E, et al. Longitudinal evaluation of prostate-specific antigen levels in men with and without prostate disease. JAMA. 1992;267:2215-20. [pmid: 1372942].
95 Smith DS, Catalona WJ. Rate of change in serum prostate specific antigen levels as a method for prostate cancer detection. J Urol. 1994;152:1163-1167. [pmid: 7520949].
96 Morote J, Raventos CX, Lorente JA, Enbabo G, Lopez M, de Torres I. Intraindividual variations of total and percent free serum prostatic-specific antigen levels in patients with normal digital rectal examination. Eur Urol. 1999;36:111-115. [pmid: 10420031].
97 Littrup PJ, Kane RA, Mettlin CJ, et al. Cost-effective prostate cancer detection. Reduction of low-yield biopsies. Investigators of the American Cancer Society National Prostate Cancer Detection Project. Cancer. 1994;74:3146-3158. [pmid: 7526969].
98 Hoogendam A, Buntinx F, de Vet HCW. The diagnostic value of digital rectal examination in primary care screening for prostate cancer: a meta-analysis. Fam Pract. 1999;16:621-627. [pmid: 10625141].
99 Schroder FH, van der Maas P, Beemsterboer P, et al. Evaluation of the digital rectal examination as a screening test for prostate cancer. Rotterdam section of the European Randomized Study of Screening for Prostate Cancer. J Natl Cancer Inst. 1998;90:1817-1823. [pmid: 9839522].
100 Candas B, Cusan L, Gomez JL, et al. Evaluation of prostatic specific antigen and digital rectal examination as screening tests for prostate cancer. Prostate. 2000;45:19-35. [pmid: 10960839].
101 Smith DS, Catalona WJ. Interexaminer variability of digital rectal examination in detecting prostate cancer. Urology. 1995;45:70-74. [pmid: 7529449].
102 Maattanen L, Auvinen A, Stenman UH, et al. European randomized study of prostate cancer screening: first-year results of the Finnish trial. Br J Cancer. 1999;79:1210-1214. [pmid: 10098761].
103 Labrie F, Candas B, Cusan L, et al. Diagnosis of advanced or noncurable prostate cancer can be practically eliminated by prostate-specific antigen. Urology. 1996;47:212-217. [pmid: 8607237].
104 Horninger W, Reissigl A, Rogatsch H, et al. Prostate cancer screening in the Tyrol, Austria: experience and results. Eur J Cancer. 2000;36:1322-1335. [pmid: 10882875].
105 Martin E, Lujan M, Sanchez E, Herrero A, Paez A, Berenguer A. Final results of a screening campaign for prostate cancer. Eur Urol. 1999;35:26-31. [pmid: 9933791].
106 Labrie F, Dupont A, Suburu R, et al. Optimized strategy for detection of early stage. curable prostate cancer: role of prescreening with prostate-specific antigen. Clin Invest Med. 1993;16:425-439. [pmid: 7516831].
107 Horninger W, Reissigl A, Rogatsch H, et al. Prostate cancer screening in Tyrol, Austria: experience and results. Eur Urol. 1999;35:523-538. [pmid: 10325519].
108 Hoedemaeker RF, Rietbergen JB, Kranse R, Schroder FH, van der Kwast TH. Histopathological prostate cancer characteristics at radical prostatectomy after population based screening. J Urol. 2000;164:411-415. [pmid: 10893598].
109 Horninger W, Reissigl A, Klocker H, et al. Improvement of specificity in PSA-based screening by using PSA-transition zone density and percent free PSA in addition to total PSA levels. Prostate. 1998;37:133-137. discussion. 138. 139.
110 Hoedemaeker RF, Rietbergen JB, Kranse R, van der Kwast TH, Schroder FH. Comparison of pathologic characteristics of T1c and non-T1c cancers detected in a population-based screening study, the European Randomized Study of Screening for Prostate Cancer. World J Urol. 1997;15:339-345. [pmid: 9436283].
111 Humphrey PA, Keetch DW, Smith DS, Shepherd DL, Catalona WJ. Prospective characterization of pathological features of prostatic carcinomas detected via serum prostate specific antigen based screening. J Urol. 1996;155:816-820. [pmid: 8583583].
112 Epstein JI, Walsh PC, Carmichael M, Brendler CB. Pathologic and clinical findings to predict tumor extent of nonpalpable (stage T1c) prostate cancer. JAMA. 1994;271:368-374. [pmid: 7506797].
113 Murphy GP, Natarajan N, Pontes JE, et al. The national survey of prostate cancer in the United States by the American College of Surgeons. J Urol. 1982;127:928-934. [pmid: 7086995].
114 Smith DS, Catalona WJ, Herschman JD. Longitudinal screening for prostate cancer with prostate-specific antigen. JAMA. 1996;276:1309-1315. [pmid: 8861989].
115 Carter HB, Epstein JI, Chan DW, Fozard JL, Pearson JD. Recommended prostate-specific antigen testing intervals for the detection of curable prostate cancer. JAMA. 1997;277:1456-60. [pmid: 9145718].
116 Essink-Bot ML, de Koning HJ, Nijs HG, Kirkels WJ, van der Maas PJ, Schroder FH. Short-term effects of population-based screening for prostate cancer on health-related quality of life. J Natl Cancer Inst. 1998;90:925-931. [pmid: 9637143].
117 Lerman C, Trock B, Rimer BK, Jepson C, Brody D, Boyce A. Psychological side effects of breast cancer screening. Health Psychol. 1991;10:259-267. [pmid: 1915212].
118 Rietbergen JB, Kruger AE, Kranse R, Schroder FH. Complications of transrectal ultrasound-guided systematic sextant biopsies of the prostate: evaluation of complication rates and risk factors within a population-based screening program. Urology. 1997;49:875-880. [pmid: 9187694].
119 Byar DP, Corle DK. VACURG randomised trial of radical prostatectomy for stages I and II prostatic cancer. Veterans Administration Cooperative Urological Research Group. Urology. 1981;17:7-11. [pmid: 7010763].
120 Graversen PH, Nielsen KT, Gasser TC, Corle DK, Madsen PO. Radical prostatectomy versus expectant primary treatment in stages I and II prostatic cancer. A fifteen-year follow-up. Urology. 1990;36:493-498. [pmid: 2247914].
121 Wasson JH, Cushman CC, Bruskewitz RC, Littenberg B, Mulley AG Jr, Wennberg JE. A structured literature review of treatment for localized prostate cancer. Prostate Disease Patient Outcome Research Team. Arch Fam Med. 1993;2:487-493. [pmid: 8118564].
122 Iversen P, Madsen PO, Corle DK. Radical prostatectomy versus expectant treatment for early carcinoma of the prostate. Twenty-three year follow-up of a prospective randomized study. Scand J Urol Nephrol. 1995;172:65-72.
123 Akakura K, Isaka S, Akimoto S, et al. Long-term results of a randomized trial for the treatment of Stages B2 and C prostate cancer: radical prostatectomy versus external beam radiation therapy with a common endocrine therapy in both modalities. Urology. 1999;54:313-318. [pmid: 10443731].
124 Holmberg L, Bill-Axelson A, Helgesen F, et al. A randomized trial comparing radical prostatectomy with watchful waiting in early prostate cancer. N Engl J Med. 2002;347:781-9. [pmid: 12226148].
125 Zincke H, Bergstralh EJ, Blute ML, et al. Radical prostatectomy for clinically localized prostate cancer: long-term results of 1,143 patients from a single institution. J Clin Oncol. 1994;12:2254-2263. [pmid: 7964940].
126 Zincke H, Oesterling JE, Blute ML, Bergstralh EJ, Myers RP, Barrett DM. Long-term (15 years) results after radical prostatectomy for clinically localized (stage T2c or lower) prostate cancer. J Urol. 1994;152:1850-1857. [pmid: 7523733].
127 Walsh PC, Partin AW, Epstein JI. Cancer control and quality of life following anatomical radical retropubic prostatectomy: results at 10 years. J Urol. 1994;152:1831-1836. [pmid: 7523730].
128 Paulson D. Impact of radical prostatectomy in the management of clinically localized disease. J Urol. 1994;152:1826-1830. [pmid: 7523729].
129 Krongrad A, Lai H, Lai S. Survival after radical prostatectomy. JAMA. 1997;278:44-46. [pmid: 9207337].
130 Lu-Yao GL, Yao SL. Population-based study of long-term survival in patients with clinically localised prostate cancer. Lancet. 1997;349:906-910. [pmid: 9093251].
131 Gerber GS, Thisted RA, Scardino PT, et al. Results of radical prostatectomy in men with clinically localized prostate cancer. JAMA. 1996;276:615-619. [pmid: 8773633].
132 Barry MJ, Albertsen PC, Bagshaw MA, et al. Outcomes for men with clinically nonmetastatic prostate carcinoma managed with radical prostactectomy, external beam radiotherapy, or expectant management: a retrospective analysis. Cancer. 2001;91:2302-14. [pmid: 11413519].
133 Hanks GE. Conformal radiotherapy for prostate cancer. Ann Med. 2000;32:57-63. [pmid: 10711579].
134 Asbell SO, Martz KL, Shin KH, et al. Impact of surgical staging in evaluating the radiotherapeutic outcome in RTOG :77-06, a phase III study for T1BN0M0 (A2) and T2N0M0 (B) prostate carcinoma. Intl J Rad Oncol Biol Phys. 1998;40:769-782.
135 Blasko JC. Brachytherapy. Urology. 2000;55:306-308. [pmid: 10699598].
136 Hochstetler JA, Kreder KJ, Brown CK, Loening SA. Survival of patients with localized prostate cancer treated with percutaneous transperineal placement of radioactive gold seeds: stages A2, B, and C. Prostate. 1995;26:316-324. [pmid: 7784271].
137 Schellhammer PF, Moriarty R, Bostwick D, Kuban D. Fifteen-year minimum follow-up of a prostate brachytherapy series: comparing the past with the present. Urology. 2000;56:436-439. [pmid: 10962309].
138 Lundgren R, Nordle O, Josefsson K. Immediate estrogen or estramustine phosphate therapy versus deferred endocrine treatment in nonmetastatic prostate cancer: a randomized multicenter study with 15 years of followup. The South Sweden Prostate Cancer Study Group. J Urol. 1995;153:1580-1586. [pmid: 7714978].
139 Granfors T, Modig H, Damber JE, Tomic R. Combined orchiectomy and external radiotherapy versus radiotherapy alone for nonmetastatic prostate cancer with or without pelvic lymph node involvement: a prospective randomized study. J Urol. 1998;159:2030-2034. [pmid: 9598512].
140 Schmidt JD, Gibbons RP, Murphy GP, Bartolucci A. Evaluation of adjuvant estramustine phosphate, cyclophosphamide, and observation only for node-positive patients following radical prostatectomy and definitive irradiation. Investigators of the National Prostate Cancer Project. Prostate. 1996;28:51-57. [pmid: 8545281].
141 Bolla M, Gonzalez D, Warde P, et al. Improved survival in patients with locally advanced prostate cancer treated with radiotherapy and goserelin. N Engl J Med. 1997;337:295-300. [pmid: 9233866].
142 Pilepich MV, Winter K, John MJ, et al. Phase III radiation therapy oncology group (RTOG) trial 86-10 of androgen deprivation adjuvant to definitive radiotherapy in locally advanced carcinoma of the prostate. Int J Radiat Oncol Biol Phys. 2001;50:1243-1252. [pmid: 11483335].
143 Corn BW, Winter K, Pilepich MV. Does androgen suppression enhance the efficacy of postoperative irradiation? A secondary analysis of RTOG 85-31. Radiation Therapy Oncology Group. Urology. 1999;54:495-502. [pmid: 10475361].
144 Pilepich MV, Buzydlowski JW, John MJ, Rubin P, McGowan DG, Marcial VA. Phase II trial of hormonal cytoreduction with megestrol and diethylstilbestrol in conjunction with radiotherapy for carcinoma of the prostate: outcome results of RTOG 83-07. Intl J Rad Oncol Biol Phy. 1995;32:175-180.
145 Pilepich MV, Caplan R, Byhardt RW, et al. Phase III trial of androgen suppression using goserelin in unfavorable- prognosis carcinoma of the prostate treated with definitive radiotherapy: report of Radiation Therapy Oncology Group Protocol 85-31. J Clin Oncol. 1997;15:1013-1021. [pmid: 9060541].
146 Messing EM, Manola J, Sarosdy M, Wilding G, Crawford ED, Trump D. Immediate hormonal therapy compared with observation after radical prostatectomy and pelvic lymphadenectomy in men with node-positive prostate cancer. N Engl J Med. 1999;341:1781-1788. [pmid: 10588962].
147 Medical Research Council Prostate Cancer Working Party Investigators Group. Immediate versus deferred treatment for advanced prostatic cancer: initial results of the Medical Research Council Trial. The Medical Research Council Prostate Cancer Working Party Investigators Group. Brit J Urol. 1997;79:235-246. [pmid: 9052476].
148 Merrill RM, Feuer EJ, Warren JL, Schussler N, Stephenson RA. Role of transurethral resection of the prostate in population-based prostate cancer incidence rates. Am J Epidemiol. 1999;150:848-860. [pmid: 10522656].
149 Endrizzi J, Optenberg S, Byers R, Thompson IM Jr. Disappearance of well-differentiated carcinoma of the prostate: effect of transurethral resection of the prostate, prostate-specific antigen, and prostate biopsy. Urology. 2001;57:733-736. [pmid: 11306392].
150 Albertsen PC, Fryback DG, Storer BE, Kolon TF, Fine J. Long-term survival among men with conservatively treated localized prostate cancer. JAMA. 1995;274:626-31. [pmid: 7637143].
151 Brasso K, Friis S, Juel K, Jorgensen T, Iversen P. Mortality pf Patients with Clinically Localized Prostate Cancer Treated with Observation for 10 Years or Longer: A Population Based Registry Study. J Urol. 1999;161:524-528. [pmid: 9915440].
152 Sandblom G, Dufmats M, Varenhorst E. Long-term survival in a Swedish population-based cohort of men with prostate cancer. Urology. 2000;56:442-447. [pmid: 10962312].
153 Wilt TJ, Cowper DC, Gammack JK, Going DR, Nugent S, Borowsky SJ. An evaluation of radical prostatectomy at Veterans Affairs Medical Centers: time trends and geographic variation in utilization and outcomes. Med Care. 1999;37:1046-1056. [pmid: 10524371].
154 Lu-Yao GL, McLerran D, Wasson J, Wennberg JE. An assessment of radical prostatectomy. Time trends, geographic variation, and outcomes. The Prostate Patient Outcomes Research Team. JAMA. 1993;269:2633-2636. [pmid: 8487445].
155 Robinson JW, Dufour MS, Fung TS. Erectile functioning of men treated for prostate carcinoma. Cancer. 1997;79:538-544. [pmid: 9028365].
156 Litwin MS. Editorial Comments. J Urol. 2000;163:1806-1807.
157 Madalinska JB, Essink-Bot ML, de Koning HJ, Kirkels WJ, van der Maas PJ, Schroder FH. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer. J Clin Oncol. 2001;19:1619-1628. [pmid: 11250990].
158 Litwin MS, Melmed GY, Nakazon T. Life after radical prostatectomy: a longitudinal study. J Urol. 2001;166:587-592. [pmid: 11458073].
159 Siegel T, Moul JW, Spevak M, Alvord WG, Costabile RA. The development of erectile dysfunction in men treated for prostate cancer. J Urol. 2001;165:430-435. [pmid: 11176390].
160 Krupski T, Petroni GR, Bissonette EA, Theodorescu D. Quality-of-life comparison of radical prostatectomy and interstitial brachytherapy in the treatment of clinically localized prostate cancer. Urology. 2000;55:736-742. [pmid: 10792092].
161 Stanford JL, Feng Z, Hamilton AS, et al. Urinary and sexual function after radical prostatectomy for clinically localized prostate cancer: the Prostate Cancer Outcomes Study. JAMA. 2000;283:354-360. [pmid: 10647798].
162 Litwin MS, Flanders SC, Pasta DJ, Stoddard ML, Lubeck DP, Henning JM. Sexual function and bother after radical prostatectomy or radiation for prostate cancer: multivariate quality-of-life analysis from CaPSURE. Cancer of the Prostate Strategic Urologic Research Endeavor. Urology. 1999;54:503-508. [pmid: 10475362].
163 Talcott JA, Rieker P, Clark JA, et al. Patient-reported symptoms after primary therapy for early prostate cancer: results of a prospective cohort study. J Clin Oncol. 1998;16:275-283. [pmid: 9440753].
164 Talcott JA, Rieker P, Propert KJ, et al. Patient-reported impotence and incontinence after nerve-sparing radical prostatectomy. J Natl Cancer Inst. 1997;89:1117-1123. [pmid: 9262249].
165 Helgason AR, Adolfsson J, Dickman P, Arver S, Fredrikson M, Steineck G. Factors associated with waning sexual function among elderly men and prostate cancer patients. J Urol. 1997;158:155-159. [pmid: 9186344].
166 Shrader-Bogen CL, Kjellberg JL, McPherson CP, Murray CL. Quality of life and treatment outcomes: prostate carcinoma patients' perspectives after prostatectomy or radiation therapy. Cancer. 1997;79:1977-1986. [pmid: 9149026].
167 Fossa SD, Woehre H, Kurth KH, et al Influence of urological morbidity on quality of life in patients with prostate cancer Eur Urol. 1997 31(Suppl 3):3 8 9101208
168 Helgason AR, Adolfsson J, Dickman P, Fredrikson M, Arver S, Steineck G. Waning sexual function--the most important disease-specific distress for patients with prostate cancer. Brit J Cancer. 1996;73:1417-1421. [pmid: 8645589].
169 Litwin MS, Hays RD, Fink A, et al. Quality-of-life outcomes in men treated for localized prostate cancer. JAMA. 1995;273:129-135. [pmid: 7799493].
170 Potosky A.L., Legler J., Albersen P.C., et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: Results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. 2000;92:1582-1592. [pmid: 11018094].
171 Litwin M.S. Health-related quality of life after treatment for localized prostate cancer. Cancer. 1995;75:2000-2003.
172 Walsh PC, Marschke P, Ricker D, Burnett AL. Patient-reported urinary continence and sexual function after anatomic radical prostatectomy. Urology. 2000;55:58-61. [pmid: 10654895].
173 Steineck G, Helgesen F, Adolfsson J, et al. Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. 2002;347:790-6. [pmid: 12226149].
174 Adolfsson J, Helgason AR, Dickman P, Steineck G. Urinary and bowel symptoms in men with and without prostate cancer: results from an observational study in the Stockholm area. Eur Urol. 1998;33:11-16. [pmid: 9471035].
175 Fransson P, Widmark A. Self-assessed sexual function after pelvic irradiation for prostate carcinoma. Comparison with an age-matched control group. Cancer. 1996;78:1066-1078. [pmid: 8780545].
176 Roach, M., III, Chinn DM, Holland J, Clarke M. A pilot survey of sexual function and quality of life following 3D conformal radiotherapy for clinically localized prostate cancer. Intl J Rad Oncol Biol Phys. 1996;35:869-874.
177 Hamilton AS, Stanford JL, Gilliland FD, et al. Health outcomes after external-beam radiation therapy for clinically localized prostate cancer: results from the Prostate Cancer Outcomes Study. J Clin Oncol. 2001;19:2517-2526. [pmid: 11331331].
178 Beard CJ, Propert KJ, Rieker PP, et al. Complications after treatment with external-beam irradiation in early-stage prostate cancer patients: a prospective multiinstitutional outcomes study. J Clin Oncol. 1997;15:223-29. [pmid: 8996146].
179 Fowler, FJ, Jr., Barry MJ, Lu-Yao G, Wasson JH, Bin L. Outcomes of external-beam radiation therapy for prostate cancer: a study of Medicare beneficiaries in three surveillance, epidemiology, and end results areas. J Clin Oncol. 1996;14:2258-2265. [pmid: 8708715].
180 Widmark A, Fransson P, Tavelin B. Self-assessment questionnaire for evaluating urinary and intestinal late side effects after pelvic radiotherapy in patients with prostate cancer compared with an age-matched control population. Cancer. 1994;74:2520-2532. [pmid: 7923010].
181 Nguyen LN, Pollack A, Zagars GK. Late effects after radiotherapy for prostate cancer in a randomized dose-response study: results of a self-assessment questionnaire. Urology. 1998;51:991-997. [pmid: 9609638].
182 Dearnaley DP, Khoo VS, Norman AR, et al. Comparison of radiation side-effects of conformal and conventional radiotherapy in prostate cancer: a randomised trial. Lancet. 1999;353:267-272. [pmid: 9929018].
183 Lee WR, McQuellon RP, Harris-Henderson K, Case LD, McCullough DL. A preliminary analysis of health-related quality of life in the first year after permanent source interstitial brachytherapy (PIB) for clinically localized prostate cancer. Intl J Rad Oncol Biol Phys. 2000;46:77-81.
184 Stock RG, Kao J, Stone NN. Penile erectile function after permanent radioactive seed implantation for treatment of prostate cancer. J Urol. 2001;165:436-439. [pmid: 11176391].
185 Gelblum DY, Potters L, Ashley R, Waldbaum R, Wang XH, Leibel S. Urinary morbidity following ultrasound-guided transperineal prostate seed implantation. Intl J Radiat Oncol Biol Phys. 1999;45:59-67.
186 Fulmer BR, Bissonette EA, Petroni GR, Theodorescu D. Prospective assessment of voiding and sexual function after treatment for localized prostate carcinoma: comparison of radical prostatectomy to hormonobrachytherapy with and without external beam radiotherapy. Cancer. 2001;91:2046-2055. [pmid: 11391584].
187 Brandeis JM, Litwin MS, Burnison CM, Reiter RE. Quality of life outcomes after brachytherapy for early stage prostate cancer. J Urol. 2000;163:851-57. [pmid: 10687991].
188 Chaikin DC, Broderick GA, Malloy TR, Malkowicz SB, Whittington R, Wein AJ. Erectile dysfunction following minimally invasive treatments for prostate cancer. Urology. 1996;48:100-104. [pmid: 8693628].
189 Lee WR, McQuellon RP, Case LD, deGuzman AF, McCullough DL. Early quality of life assessment in men treated with permanent source interstitial brachytherapy for clinically localized prostate cancer. J Urol. 1999;162:403-406. [pmid: 10411047].
190 Seaward SA, Weinberg V, Lewis P, Leigh B, Phillips TL, Roach M3. Improved freedom from PSA failure with whole pelvic irradiation for high-risk prostate cancer. Int J Rad Oncol Biol Phys. 1998;42:1055-1062.
191 Benoit RM, Naslund MJ, Cohen JK. Complications after prostate brachytherapy in the Medicare population. Urology. 2000;55:91-96. [pmid: 10654901].
192 Aronson N, Seidenfeld J, Samson DJ, et al. Relative effectiveness and cost-effectiveness of methods of androgen suppression in the treatment of advanced prostate cancer. Evidence Report/Technology Assessment No. 4. AHCPR Publication No. 99-E0012. Rockville, MD: Agency for Health Care Policy and Research. May 1999.
193 Potosky AL, Knopf K, Clegg LX, et al. Quality-of-life outcomes after primary androgen deprivation therapy: results from the Prostate Cancer Outcomes Study. J Clin Oncol. 2001;19:3750-3757. [pmid: 11533098].
194 Potosky AL, Reeve BB, Clegg LX, et al. Quality of life following localized prostate cancer treated initially with androgen deprivation therapy or no therapy. J Natl Cancer Inst. 2002;94:430-7. [pmid: 11904315].
195 Fowler FJJ, McNaughton Collins M, Walker Corkery E, Elliott DB, Barry MJ. The impact of androgen deprivation on quality of life after radical prostatectomy for prostate carcinoma. Cancer. 2002;95:287-95. [pmid: 12124828].
196 Strum SB, McDermed JE, Scholz MC, Johnson H, Tisman G. Anaemia associated with androgen deprivation in patients with prostate cancer receiving combined hormone blockade. Br J Urol. 1997;79:933-941. [pmid: 9202563].
197 Daniell HW, Dunn SR, Ferguson DW, Lomas G, Niazi Z, Stratte PT. Progressive osteoporosis during androgen deprivation therapy for prostate cancer. J Urol. 2000;163:181-186. [pmid: 10604342].
198 Bokhour BG, Clark JA, Inui TS, Silliman RA, Talcott JA. Sexuality after treatment for early prostate cancer: exploring the meanings of "erectile dysfunction". J Gen Intern Med. 2001;16:649-655. [pmid: 11679031].
199 Barry MJ, Fleming C, Coley CM, Wasson JH, Fahs MC, Oesterling JE. Should Medicare provide reimbursement for prostate-specific antigen testing for early detection of prostate cancer? Part IV: Estimating the risks and benefits of an early detection program. Urology. 1995;46:445-61. [pmid: 7571211].
200 Lubke W.L., Optenberg S.A., Thompson I.M. Analysis of the First-Year Cost of a Prostate Cancer Screening and Treatment Program in the United States. J Natl Cancer Inst. 1994;86:1790-1792. [pmid: 7966418].
201 Fleming C, Wasson JH, Albertsen PC, Barry MJ, Wennberg JE. A decision analysis of alternative treatment strategies for clinically localized prostate cancer. Prostate Patient Outcomes Research Team. JAMA. 1993;269:2650-2658. [pmid: 8487449].
202 Krahn MD, Mahoney JE, Eckman MH, Trachtenberg J, Pauker SG, Detsky AS. Screening for prostate cancer. A decision analytic view. JAMA. 1994;272:773-780. [pmid: 7521400].
203 Kattan MW, Cowen ME, Miles BJ. A decision analysis for treatment of clinically localized prostate cancer. J Gen Intern Med. 1997;12:299-305. [pmid: 9159699].
204 Coley CM, Barry MJ, Fleming C, Fahs MC, Mulley AG. Early detection of prostate cancer. Part II: Estimating the risks, benefits, and costs. American College of Physicians. Ann Int Med. 1997;126:468-479. [pmid: 9072935].
205 Oliver SE, May MT, Gunnell D. International trends in prostate-cancer mortality in the "PSA ERA". Int J Cancer. 2001;92:893-898. [pmid: 11351313].
206 Furuya Y, Akakura K, Akimoto S, Ichikawa T, Ito H. Radiotherapy for local progression in patients with hormone-refractory prostate cancer. Intl J Urol. 1999;6:187-191.
207 Schmidt JD, Gibbons RP, Murphy GP, Bartolucci A. Adjuvant therapy for clinical localized prostate cancer treated with surgery or irradiation. Eur Urol. 1996;29:425-433. [pmid: 8791049].
208 Bratt O, Elfving P, Flodgren P, Lundgren R. Morbidity of pelvic lymphadenectomy, radical retropubic prostatectomy and external radiotherapy in patients with localised prostatic cancer. Scand J Urol Nephrol. 1994;28:265-271. [pmid: 7817168].
209 Badalament RA, Bahn DK, Kim H, Kumar A, Bahn JM, Lee F. Patient-reported complications after cryoablation therapy for prostate cancer. Urology. 1999;54:295-300. [pmid: 10443728].
210 Barry MJ, Fleming C, Coley CM, Wasson JH, Fahs MC, Oesterling JE. Should Medicare provide reimbursement for prostate-specific antigen testing for early detection of prostate cancer? Part III: Management strategies and outcomes. Urology. 1995;46:277-289. [pmid: 7544931].
211 Kattan MW, Stapleton AM, Wheeler TM, Scardino PT. Evaluation of a nomogram used to predict the pathologic stage of clinically localized prostate carcinoma. Cancer. 1997;79:528-537. [pmid: 9028364].