# Appendix B. Evidence Tables

## Appendix B. Evidence table glossary

Appendix B. Evidence Tables

Abbr. | Definition
+ | Positive
ADT | Apparent diffusion tensor
Agg | Aggressive
APC | Annual percent change
AUC | Area under ROC curve
Av | Average
BPH | Benign prostatic hyperplasia
Bx | Biopsy
Ca | Cancer
CI | Confidence Interval
CT | Computerized tomography
DES | Diethylstilbestrol
Diff | Difference
DRE | Digital rectal examination
Dxed | Diagnosed
EBRT | External beam radiation therapy
Endpts | Endpoints
ERSPC | European Randomized Study of Screening for Prostate Cancer
F/U | Follow-up
Fxn | Function
Gy | Gray
HRQol | Health-related quality of life
IVP | Intravenous pyelogram
LHRH | Luteinizing hormone-releasing hormone
LR | Likelihood ratio
LUTS | Lower urinary tract symptoms
m-y | Months-years
MRI | Magnetic resonance imaging
Mos | Months
NCHS | National Center for Health Statistics
Nonagg | Non-aggressive
Ns | Not statistically significant
OR | Odds Ratio
PC | Prostate Cancer
PFS | Progression free survival
QALY | Quality adjusted life year
OR | Odds ratio
Qol | Quality of life
P | Probability
PC | Prostate cancer
PPV | Positive predictive value
PSA | Prostate specific antigen
Rad | Radiation
Rand | Randomization
RCT | Randomized controlled trial
ROC | Receiver operator characteristic
RP | Radical prostatectomy
SEER | Surveillance, Epidemiology, and End Results Program
Std | Standard
TRUS | Transrectal ultrasound
TURP | Transurethral resection of the prostate
Tx | Treatment
UCLA | University of California at Los Angeles
US | United States
WW | Watchful Waiting
XRT | Radiation therapy
Yrs | Years

Evidence Table 1A: Health outcomes of screening in reducing mortality RCTs (Key Question 1)Appendix B. Evidence Tables

Citation | Study Population Selection | Study Population Description | Intervention | Results | Comments
Design | Study Population Selection | Study Population Description | Intervention | Results | Comments
Labrie F et al., 1999^ 20 ^ | Men registered in the 1985 electoral rolls of Quebec City were randomized to screening or no screening Study conducted from 1/1/89 through 12/31/96 | 46,173 men aged 45-80 years 30,956 invited to be screened; 7,155 (23%) screened; Av age 60+/−7 Of 15,237 controls, 14,255 (93.6%) were not screened; Av age 58+/-9 | Screening by PSA and DRE PSA cutpoint >3.0 ng/ml Screen test positive had TRUS and biopsy | Primary outcome was death from prostate cancer as recorded in the death registry of the province health dept. In the screened group, (including all screened men from both groups) the death rate was 13.7/10^5^ m-y. In the unscreened group, the death rate was 41.6/1010^5^ m-y The authors conclude that screening resulted in a 67% reduction in death rate incidence | No sociodemographic comparison of the two groups was presented Men in the screened group were followed an av 3.8 years; whereas men in the control group were followed an av 7.4 years The death rates from other causes for the two groups were not presented or compared No intention to treat analysis Quality: poor

Evidence Table 1B: Health outcomes of screening, case-control studies (Key Question 1)Appendix B. Evidence Tables

Citation | Cases | Controls | Measurements (exposure, confounders) | Results | Comments
Jacobsen SJ et al., 1998^ 23 ^ Population-based case-control Study of DRE and PC mortality Olmstead County, MN Study | N=173 Men with PC on death certificate between 1976 and 1991, verified by chart review (116 had PC listed as immediate or underlying cause of death) | N=346 2 men with registration numbers closest to each case, matched to date of birth and duration of medical record (all cases and controls in Olmsted County database) | Reviewed medical records for 10 years before index (diagnosis) date for evidence of DRE and findings from DRE Also abstracted obstructive urologic symptoms and comorbidity score (reliability high) | Controls more likely to have had DRE in years 2-10 before index year than cases: OR=0.51 (0.31-0.84) OR=0.53 (0.32-1.06) if cases restricted to those with PC as immediate or underlying cause of death OR=0.31 in men without urologic symptoms Results not changed by comorbidity score adjustment For only DRE in years 1-3, OR=0.76 If had DRE in years 4-6, no association for DRE in years 1-3 (OR=1.11) | Alternative explanation: "healthy screenee bias," men being screened may have had lower probability of dying of PC Could have missed DREs not recorded in medical record Study occurred before widespread PSA screening Disagreement about excluding DREs in the year before diagnosis Quality: good
Richert-Boe KE et al., 1998^ 22 ^ Matched case-control study among patients at Kaiser Northwest | N=150 Men who died from PC between 1981-1990, age 40-84 when PC diagnosed, members of plan for at least 2 years, verified by chart review Excluded men whose death not due to PC | N=299 2 controls randomly selected from Kaiser members, matched according to age and entry into health plan | Medical record review of all DREs between enrollment in plan and index date (date of diagnosis of case) Findings of DRE and urologic symptoms also recorded Blinded reviewer categorized each DRE as screening or due to any of several symptoms Analyzed only screening DREs Reliability high | About half of fatal PCs were poorly differentiated, and half were stage D at diagnosis 77% of cases and 80% of controls had had a screening DRE during the 10yrs ending just before index date (OR=0.84; 0.48-1.46) | Study done before widespread PSA screening Could not adjust for family history No analysis reported for all DRE Only 58% of case subjects and 12% of controls with suspicious findings on DRE went on to have a biopsy Quality: good

Evidence Table 1C: Health outcomes for screening, ecologic studies (Key Question 1)Appendix B. Evidence Tables

Citation | Study Population | | Measurements | Results | Comments
Design | Selection | Description | Measurements | Results | Comments
Etzioni R et al.. 1999^ 33 ^ 7 year population-based cohort (computer simulation model) | US lifetables SEER data | Medicare population from 1988-1994^ 34 ^ | Incidence data: Dissemination of PSA testing and prostate cancer detection in Medicare population from 1988-94 Mortality data: Allcause mortality rates from U.S. lifetables; prostate cancer specific rates from SEER Computer simulation model:; - PSA-tests and patients with early diagnosis;; - Identifying tested individuals;; - Identifying individuals with an early diagnosis;; - Lead time and survival;; - Prostate cancer deaths without PSA testing;; - same as previous with testing;; - Cancer deaths prevented because of PSA testing | Complete data only for 71-84 year old men Only very short lead times (time by which diagnosis is advanced by screening) of < 3 years produce a decline in mortality in model and would explain the reduction in mortality rates after 1991 due to screening Projected mortality trends in the absence of PSA screening are not consistent with pre-1991 increasing trends for lead times of 5 or 7 years | Screening rates described as probabilities for the year 1998; no actual screening rates reported Cancer detection rate for first and consecutive tests as well as relative survival estimated; death rates from other causes and lead-time reported Study populations not described; information about clinical stage and histologic grade missing Problem of eliminating:; a. clinically identified patients with cancer (whose diagnosis would have occurred regardless of use of test); b. patients with genuine early diagnosis; Medicare did not reimburse for PSA testing in model years: possible underestimation of true PSA screening Study uses computer model; not substitute for RCT Population of analysis is 71-84 years old; important data from younger men are missing Quality: good
Feuer, EJ et al., 1999^ 28 ^ | SEER Data Death Certificate Data | Men newly diagnosed with PC living in 5 SEER areas from 1973-1995 | PC incidence and mortality from 5 SEER areas from 1973-1995 Analyzed contribution to mortality rate changes of PC cases diagnosed since start of PSA testing (1987) | More than 50% of mortality rates come from men dying within 3 years of diagnosis Cases diagnosed after 1987 were major cause of rise and fall in PC mortality in late 1989s and early 1990s Attribution bias, due to attributing cause of death to PC in men who actually die of something else, may be partly responsible for rise and fall in PC mortality | Quality: good
Hankey BF et al., 1999^ 9 ^ 23 year population-based cohort | Data from SEER and National Center for Health Statistics | 229,556 PC cases as described in SEER (1973-95) Age: 50-85+ | Incidence data: SEER Program; coding for age, stage, grade Mortality data: (1969-95) from NCHS represents overall prostate ca mortality in US APC for incidence and mortality measured | Increased incidence for whites and blacks from 1975-85 (2.35 APC); in 1989 APC ranged from 17.0 to 18.4; decreasing incidence from 1992 on with APC (−12.8 to −14.0) Increased mortality from 1969-80 (0.7 to 1.6); 1981-88 (3.1 to 3.2); decreased mortality from 1991 on (−1.9 to −1.7) Incidence/age: calendar period effect (all age groups started to decline in 1990) Incidence/stage: decrease of incidence for all 3 stages Incidence/grade: decrease of incidence for all 3 grades; especially fast for well-differentiated tumors | Screening effect is proposed; decrease of incidence of distant stage disease since 1991, after not being perturbed by screening; calendar period effect (see Incidence results) No actual screening rates are reported for the study period Good confounder adjustment: age, race, grade, stage Quality: good
Meyer, F et al. 1999^ 30 ^ Ecologic Study | Population data | Men in Quebec who died of prostate cancer between 1976 and 1997 Men in Canada who died of prostate cancer between 1976 and 1996 | PC incidence and mortality, 1976-1996/97 | PC mortality increased 1.5%-1.7% per year until 1991 After 1991, mortality decreased moderately until 1995, when it decreased more rapidly Overall decline in mortality between 1991-1997 in Quebec was 23% (p=0.01) Overall decline in Canada was 9.6% (p=0.03) Larger decrease for men younger than 75 compared with older than 75 | Because of short time interval between increased screening and decreased mortality, authors believe cause is better treatment Quality: good
Roberts, RO et al. 1999^ 31 ^ Ecologic Study | Population data from computerized database | Men living in Olmsted County, Minnesota | PC mortality from 1980-1997 PC incidence since 1992 | PC mortality increased from 25.8/100,000 men in 1980 to 34/100,000 in 1992 Mortality declined to 19.4/100,000 in 1997 (22% decline; 95% CI, 49% decline to 17% increase) Incidence peaked at 209/100,000 in 1992, declined to 108-132/100,000 in 1993-95 | Mortality dropped to levels lower than in years before PSA testing Suggest that screening is playing a role Quality: good
Bartsch, G et al. 2001^ 42 ^ Ecologic Study | All residents in Tyrol, Austria compared with rest of country | 65,123 men between 45-75 years | Mass PSA screening project initiated in Tyrol in 1993 Used age-referenced PSA cutpoints >80% of men with abnormal test had biopsy Treatments primarily RP or EBRT No mass screening program in rest of Austria | Dramatic increase in incidence of PC in Tyrol, 1988-92 No information on incidence in rest of country PC mortality decreased in Tyrol (1993-1999) more than rest of country (p=0.0004) | Because we have no information about screening in rest of country, and because we have no comparison of treatment Quality: fair
Oliver, SE et al. 2001^ 205 ^ Ecologic Study | Population data | Male residents of England, Wales, and USA PSA screening is less common and even discouraged in UK | PC incidence and mortality from 1970-97 More screening in USA than UK | Much larger increase in incidence in USA compared to UK from 1989-92, then a larger decline in USA Mortality was higher in USA until 1985, when mortality was same in the 2 countries Since 1993, mortality higher in UK Decline in mortality in USA 1993-97 was 3.8% compared with 1.7% in UK (statistically significant) | Because mortality declined in both countries after 1993, authors suggest cause may be disease management Quality: good

Evidence Table 2A: Yield of screening (Key Question 2)Appendix B. Evidence Tables

Citation | Participants | Screening Test and Gold Standard | Results | Comments
Gann PH et al., 1995^ 35 ^ | Nested case-control study 22,071 physicians between ages 40 and 84 in 1982 520 cases of PC were reported by 1992 366 of the cases of PC and supplied a blood sample For each PC case, selected 3 controls | PSA (>4.0) Gold std: follow-up x10 yrs. | | "Aggressive Cancers" = stage C or D (i.e., extracapsular) + Gleason 7 or higher Of 366 total PCs, 183 (50%) classified as aggressive Quality: good
  Follow-up | Sensitivity | Specificity
  1 yr. | | 83%
  2-3 yrs. | 100%- | 86%
  3-4 yrs. | 56% | 98%
  Agg.-nonagg | 92%-67%
  Agg.-nonagg | 73%-33%
  Overall detected in 0-5 yrs. 73% | 50% | 88%
  Area under ROC curve for cancers diagnosed in 5 yrs: 0.85
  Av lead time: 5.5 yrs.
Meigs, JB, Barry MJ et al., 1996^ 60 ^ | Men with organ-confined PC (N=276) Unselected men from the community who were not found to have PC by screening and biopsy of positive screens (N=305) Men with LUTS and BPH coming to prostatectomy (and were found not to have PC) (N=173) Men with BPH enrolled in the North American finasteride trial (N=770) | PSA test Biopsy is gold standard | Overall LR+ for men with PSA 4.1-6.0 = 3.4 for unselected men and 1.4 for men with BPH Men with LUTS had lower LR+ than men without LUTS In cancer group, 39.2% of men with organ-confined PC and PSA < 4.0 | Quality: good

Evidence Table 2B: Yield of screening, studies of screening programs (Key Question 2)Appendix B. Evidence Tables

Citation | Population | Test Abnormals (% of Screened) | Biopsies % Screened | Cancers % Screened % Biopsies | Staging, Grading
Citation | Screened, Participation Rate, Age | Test Abnormals (% of Screened) | Biopsies % Screened | Cancers % Screened % Biopsies | Staging, Grading
Martin E et al., 1999^ 105 ^ | N=2,576 screened 18% participation Men ages 50+ City in Spain | DRE: (3.6%) PSA>4: (6.5%) One or other: (8.7%) % abnormal screens: Ages 50-55 (3.3%) Ages 66-70 (17.0%) | 225 (8.7%) Ages 50-54: 3.3% Ages 66-70: 17.0% | Overall 33: Screened: 1.3% Biopsies: 14.7% Ages 50-54: Screened: 0-2% Biopsies: 6.1% Ages 66-70: Screened: 2.4% Biopsies: 14.3% | Clinically: 60.6% organ confined 12.1% Metastatic Histologically: 67% Well differentiated 27% Moderate 6% Poor Quality: good
Horninger W et al., 2000^ 104 ^ | N=21,078 screened 32% participation Men 45-75 Living in Tyrol | PSA, age referenced standard: 1618 abnormal (7.7%) PSA>4: 8.9% | 778 (48.1% of positive test) (3.7% of screened) Biopsies/screened: Ages 50-59: 1.5% Ages 70-75: 11% | 197 Screened: 1.2% Biopsies: 25.3% Ages 50-59: Screened: 0.3% Biopsies: 19.7% Ages 70-75: Screened: 3.0% Biopsies: 27.5% | 135 (68.5%) of all cancers had RP 95 (70.4%) path organ confined Quality: good
Maattanen L et al., 1999^ 102 ^ | N=15,685 screened (69% participation) Ages 55-67 | PSA >4.0: 1342 (8.6%) PSA 3-3.9: ~15% had +DRE (DRE only given to men with PSA 3-3.9) PSA 3-3.9: 801 (5.1%) of all men | 1,236 biopsies (7.9% screened) from abnormal PSA | PSA >4.0: 386 cancers Screened: (2.5%) Biopsies: (29%) 22 additional cancers from DRE in men with PSA 3-3.9: Screened: (2.7%) Biopsies: (~18%) | 84% of cancers Gleason 2-6 16% Gleason 7-10 No staging data given Quality: good
Schroder, F et al., 2000^ 43 ^ | N=10,523 screened (uncertain participation) Ages 55-74 Living in Rotterdam | PSA >4.0: 1312 (12.5%) PSA >4.0 +DRE+TRUS: biopsied any abnormality | 2,499 total biopsies (23.7%) PSA > 4.0: 1,184 (47%) PSA< 4.0: 1,315 (52.6%) due to DRE or TRUS | 478 total cancers found: Screened: (4.5%) Biopsies: (19%) 351 due to PSA > 4.0 Screened: (3.3%) Biopsies: (29.6%) PSA<4.0: 127 due to DRE/TRUS: Screened with PSA<4.0: (1.4%) Biopsies: (9.7%) | 166 (34.7%) patients with cancers had RP PSA > 4.0: 116 cancers 44% Gleason 4-6 51.7% Gleason 7 4.3% Gleason 8-10 68% organ confined 9.7% overall pathologically metastatic Quality: good
Labrie F et al., 1992^ 67 ^ Labrie F et al., 1993^ 106 ^ Labrie F et al., 1999^ 20 ^ Labrie F et al., 1996^ 103 ^ (1^st^ visit data) Quebec | N=7,350 screened (23.1% participation) Ages 45-80 Living in Quebec City | PSA (>3.0) and DRE 1451 PSA >3.0 19.7% of screened | 761 biopsies (10.4% of screened) | 252 Cancers 222 (88%)found by PSA >3.0 and 119 (47%) by DRE Screened: 3.4% Biopsies: 33% (17.4% of abnormal tests) Of 222 cancers found by PSA > 3.0 Screened: 3.0% (2.5% age 55-60; 6.9% age 65-70) Of 119 found by DRE Screened: 1.6% 196 cancers found in men with PSA >4.0 Screened: 2.7% | Of 228 cancers clinically staged, 70% organ confined; 10.5% metastatic Quality: good
Catalona, WJ et al., 1994^ 44 ^ Richie JP et al., 1993^ 45 ^ | N= 6,630 men Ages 50+ from advertisements in 6 communities | PSA>4.0: 983 Screened: 14.8% +DRE: 982 Screened: 14.8% Positive on at least one test: 1,710 (25.8%) | 1,167 biopsies: Screened: (17.6%) Abnormal: (68.2%) 686 biopsies due to PSA and 683 due to DRE | 264 cancers: Screened: (4.0%) Biopsies: (2.3%) Screened for PSA > 4.0: (3.3%) Screened for +DRE: (2.2%) | Clinically, 99% cancers were organ confined 162 (61%) cancer patients had RP 71% pathologically organ confined No distant metastases beyond pelvic lymph nodes PSA>4.0 found 75% of organ confined cancers DRE found 56% of organ confined cancers Quality: good

Evidence Table 3: Harms of screening (Key Question 3)Appendix B. Evidence Tables

Citation | Participants | Measurements | Results | Comments
Essink-Bot, ML et al., 1998^ 116 ^ | Men ages 55-74 Initially: 600 participants in Rotterdam ERSPC, group invited to be screened Attrition to 541 after screening 235 of 500 non-participants | SF-36 EQ-5D, European quality of life instrument STAI to measure state and trait anxiety Visual analogue scale for overall health Pain and physical discomfort of screening DRE, TRUS, biopsy Limitations in week after biopsy | Negative screening test group (pre to post test): Small improvement in mental health on SF-36 Decrease in anxiety False positive screening test group (pretest to post biopsy) Small improvements in bodily pain and general health perceptions Small decrease in anxiety Entire group Anxiety increased mostly in those with high trait anxiety DRE: 52% some discomfort/pain TRUS 39% some discomfort/pain Biopsy: 98% some discomfort/pain 4% used pain killers 4-6% interfered with function | High response rate from participant group Quality: good

Evidence Table 4: Efficacy of treatment with radical prostatectomy (Key Question 4)Appendix B. Evidence Tables

Citation | Participants | Measurements | Intervention | Results | Comments
Citation | Number/Description | Measurements | Intervention | Results | Comments
Akakura et al., 1999^ 123 ^ | 100 of 243 eligible men aged less than 75 years without obvious enlargement of pelvic nodes by CT or MR with newly diagnosed Stage B or C prostate cancer enrolled Between 1989 and 1993, eligible men recruited from 6 Japanese hospitals 5 of 100 excluded before randomization for other reasons | Outcomes were progression (local growth of tumor and/or appearance of distal metastasis) and cause-specific survival (death after progression was considered as cancer death) | All participants received endocrine therapy for 8 weeks before RP or EBRT and were continued on it 46 men were randomized to receive RP with pelvic lymph node dissection; 49 men received EBRT | 4 (9%) in RP group and 12 (25%) in EBRT group developed disease progression. 5-year progression free survival was 91% in the RP group and 81% in the EBRT group (p=0.044); at 5 years, cause-specific survival was 97% in the surgery group and 85% in the XRT group (p=0.024) 5-year overall survival rate was 86% in the RP group and 76% in the EBRT group (p=Ns) | Only 41% of those eligible enrolled Rising PSA not included as disease progression Patients were only followed for approximately 5 years Quality: good but small
Iversen P et al., 1995^ 122 ^ RCT comparing RP plus oral placebo to oral placebo alone (i.e. expectant treatment). | 76 men aged 50-84 years (mean 65.9) with Stage A PC and 66 men aged 44-78 years (mean 62.3) with Stage B disease were enrolled From 15 VA hospitals between 1967-1975 18 men randomized to placebo only and 13 men randomized to RP not evaluable for follow up because they refused treatment, were misstaged, or violated the protocol | The main endpoint was overall survival, including all causes of death Survival status updated by contacting the participating hospitals, patients or their relatives, or by Vital Records offices Could not ascertain cause of death | 39 men with Stage A and 29 men with Stage B disease randomized to oral placebo only; other 74 men randomized to RP and placebo Median length of follow up was 23 years | For all patients, the median survival in the RP group was 10.6 years compared to 8 years in the placebo group (p=Ns) Within each stage, age adjusted survival comparison by treatment was not significant | How these patients specifically recruited not reported Major loss to follow-up Quality: poor
Holmberg L et al., 2002^ 124 ^ RCT of RP versus watchful waiting | 695 men with newly diagnosed clinically localized prostate cancer; mean age 64-65 5.2% detected by screening > 45% initial PSA > 10 | Prostate cancer specific mortality All-cause mortality Independent endpoint committee | RP with lymph node dissection WW no treatment until symptoms or signs of progression | Prostate cancer specific mortality: no difference at 5 years (4.6% WW vs 2.6% RP); 8 years (13.6% WW vs 7.1% RP); Relative hazard 0.50 (0.27-0.91) No difference in all cause mortality | About 75% of men had palpable prostate cancer. Quality: good

Evidence Table 5A: Efficacy of treatment with androgen deprivation therapy (Key Question 6)Appendix B. Evidence Tables

Citation | Description | How recruited? | Measurements | Interventions/co-Interventions | Results | Conclusions (by authors) | Quality comments
Design | Description | How recruited? | Measurements | Interventions/co-Interventions | Results | Conclusions (by authors) | Quality comments
Granfors et al., 1998^ 139 ^ RCT comparing XRT with and without orchiectomy in men with and without lymph node disease | 400 men expected to be enrolled, but study terminated due to an interim analysis revealing high rate of progression in group treated with XRT alone 91 men with Stage B and C enrolled; mean patient age 68.8 years (49.2-75.3) Patients with early stage and well or moderately well differentiated lymph node negative tumors were excluded | Men with newly diagnosed PC between 1986 and 1991 in three urologic clinics were invited to participate | Patients were followed for 3 years with history and DRE; bone scans done when clinical progression or suspicion of metastatic disease Progression defined as occurrence of clinically evident local tumor growth or bone or other metastases | All patients underwent bilateral staging pelvic lymphadenectomy and were randomized to XRT with or without orchiectomy with stratification for tumor and nodal status 45 patients were in the XRT and orchiectomy (combined) group and 46 in the XRT alone group. XRT was begun a few weeks after orchiectomy. All patients received XRT to pelvis and a boost to the prostatic area | Patient characteristics of groups similar; patients followed for median of 9.3 years (6.0-11.4) XRT alone group, progression occurred in 61% (44% of node negative and 84% of node postive) patients for combined group, progression occurred in 31% (32% of node negative and 30% of node positive) patients 44% of XRT alone group and 27% of combined group died of PC (p=0.06); overall, 61% of XRT alone group and 38% of combined group died (p=0.02) (statistically significant for node + but not for node − disease) | Immediate androgen deprivation is better than deferred endocine treatment for clinically localized PC, particularly in patients with positive lymph nodes Lymph node staging for clinically localized PC is extremely important | Unclear how men were recruited, but once enrolled there was good follow up Diagnosing disease progression was subjective, and criteria for attributing death to prostate cancer were not described One of a few studies to clearly stratify, analyze, and report results regarding nodal status Quality: good
Schmidt et al., 1996^ 207 ^ RCT composing adjuvant therapy (cyclophosphamide estramustine or observation) in two protocols, as part of the National Prostate Cancer Project, clinically localized PC | 184 men enrolled in Protocol 900 and 235 enrolled in Protocol 1000 Follow up information was available for 170 and 233 men respectively No description of participants, 29% of those in Protocol 900 and 63% of those in Protocol 1000 had positive pelvic lymph nodes | Recruitment was not described | Outcomes: recurrence rates (metastatic disease, increases in serum acid phosphatase, and increases in PSA), median PFS (not defined), and overall survival. | Protocol assignment at the discretion of the investigator Protocol 900 included patients receiving radical surgery or cryosurgery; Protocol 1000 included patients receiving XRT Men in both protocols randomized to cyclophosphamide for up to 2 yrs (C), estramustine phophate for up to 2 yrs (E), or observation (O) | Follow up information available for 403 patients (92%) for an average 11 years For Protocol 900 (prostatectomy), overall recurrence rate 53%, (71% in those with positive nodes); differences among adjuvant treatments not statistically significant for with and without nodal disease For Protocol 1000 (XRT), overall recurrence rate 66%, (82% in those with positive nodes); differences among adjuvant treatments not statistically significant in negative node group; in positive node group rates of recurrence for C, E, and O were 75%, 57%, and 66% respectively, and were significantly different In Protocol 900, the PFS for Groups C, E, and O were 79, 155, and 104 months (p=0.13); in Protocol 1000, the PFS for Groups C, E, and O were 35, 52, and 46 months (p=0.18) | Overall survival and PFS greater in Protocol 900 (prostatectomy) compared to Protocol 1000 (XRT) A beneficial effect of estramustine observed | Entry into one protocol versus the other was not randomized Groups had different rates of positive nodes, but no other comparison between the two groups upon entry was presented, so comparing the two groups is of little value Randomization to aduvant therapy within the protocols and follow up appears well done, but the evaluators do not appear to have been blinded to the treatment received Paper essentially two studies: one to compare adjuvant treatments in men having prostatectomy, and one comparing adjuvant treatments in men receiving XRT Paper does not evaluate or discuss the primary treatment (prostatectomy versus XRT) Quality: fair
Lundgren et al., 1995^ 138 ^ RCT comparing immediate to deferred endocrine treatment of clinically localized PC | 285 men previously untreated PC; Mean age 70 years; 99 men had Stage A, 107 had Stage B; 22 Stage C 57 excluded after randomization (mostly for protocal violations and incorrect randomization) | Patients from 5 urological or surgical clinics in Sweden were eligible | Patients followed with DRE, blood work, bone scan, and prostate biopsy | Diagnosis and tumor differentiation determined by TURP or by prostate biopsy 81 patients to receive polyestradiol plus ethinylestradiol (PE); 93 patients to receive estramustine (E); and 98 patients deferred endocrine treatment D Progression defined as appearance of metastases, poorly differentiated cancer, local progression with pain and/or ureteral dilitation remaining after TURP. (D) | More Stage B tumors in the E group and more Stage C tumors in the D group. Overall 125 (55%) had disease progression Metastasis in 22%: 17% in group PE, 20% in group E, and 28% in group 46 (20%) died from PC: 12% in PE group, 18% in E group, and 28% in D group (p=0.03) Overall, 128 patients (56%) died from any cause: 53% in PE group, 54% in E group, and 60% in D group (p=0.48). | More people died from PC in the deferred group than in the immediate treatment groups After 10 years of follow up, the probability in the deferred treatment group of dying of PC was 26% and that of dying of intercurrent disease was 25% The probability of dying from PC is higher than that previously reported, and men with at least 10 years life expectancy should receive early treatment | 57 patients regarded as nonevaluable, created dissimilarities among treatment groups Unclear how cause of death determined or attributed PC Study provides good information on natural history of PC. Although deferred treatment group had higher rates of death from PC, overall survival rates not different Quality: fair
Pilepich, M.V., et al., 1995^ 144 ^ RCT | 203 patients assessed Median f/u time of 107.8 mos. Actual median f/u of alive pts. was 78.9 mos. March 1983-June 1986 198 pts. total randomized to Megestrol Acetate (n=100) or DES (n=98) Eligible if had locally advanced prostate CA, stage B (42 Megace group, 45 DES group) or stage C (58 Megace, 53 DES) 90% compliance in Megestrol, 82% in DES arm | No mention of recruitment specifics | Endpts = tumor clearance rate (rand. To 1st tumor-free assess.), effect of rx on serum testosterone levels, evaluation of loco-regional control (prog. Of clinc. Detectable disease or + biopsy after 2nd post-rad. year), incidence of distant mestastases (end pt. of metast=occurrence of disease outside pelvic region), survival (failure=death from any cause), and assessment of effects of tx on sexual fxn | Megestrol 40 mg 3x daily po DES 1 mg 3x daily po All received radiotherapy 44-46 Gy, 1.8-2 Gy daily to regional lymphatics, followed by boost to prostatic are of 20-25 Gy, 1.8-2 Gy daily, to a total of 65-70 Gy Tumor response assessed clinically and by CT Serum test. levels recorded: "throughout trial" | Median increase in test. levels higher in DES (94.5% vs. 77%, p<0.0001) No difference in tumor clearance No diff. in loco-regional occurrence (no p value from Fig. 2) Difference in metastatic rate not significant (p= 0.73) Survival rates not different and appear to be insignificant from Fig. 4, but no p values Return of sexual potency @ 1 year= 81% Megestrol arm, 58% DES arm | Comparable efficacy in tx using Megestrol or DES DES appears more effective @ suppressing testosterone, but also associated with higher incidnce of drug-related toxicity | No mention of blinding, in either randomization or assessment of results Need p values or CI's for several figures Survival as death from any cause suspect No median age of subjects (or age range) Quality: fair
Bolla, Michel, et al., 1997^ 141 ^ Prospective RCT | 415 men Median age of 71 years. (51-80) Recruited from may 1987-september 1995 14 subjects lost to follow-up (10 from radiotherapy group, 4 from combined tx group) 208 rand to external irrad. Only 207 to ext. irrad & goserelin tx 99% irradiation only compliance; -96% combined therapy compliance | Specific recruitment methods Not mentioned; patients referred from various Institutions by dx of locally advanced prostate CA (T1 or T2) and WHO grade 3 | Median follow-up: 45 mos Main outcome: overall survival @ date of death or most recent f/u Disease free interval from date of randomization to date of local or regional failure PSA progression: PSA level increase of 1.5 ng/ml in 2 successive observations | Irradiation groups: Planning target vol. 1 received 50 Gy once daily 5 times/week for 5 weeks (whole pelvis) Planning target vol. 2 received 20 Gy once daily 5x/week for 2 weeks (prostate and seminal vesicles) Goserelin administered 3.6 mg SQ every 4 weeks starting on 1st irradiation day through 3 years | Kaplan-Meier estimates of overall survival @ 5 years=79% (combined tx group, 95% CI 72-86%); 62% in radiotherapy (95% CI 52-72%) 85% disease free @five years in combined tx (95% CI 78-92%); in radiotherapy group 48% (95% CI 38-58%) P<0.001 in all results | Adjunctive therapy with goserelin @ beginning of external irradiation through 3 years can improve 5 year overall survival of patients with locally advanced PC | Impressive attention to instrument calibration Use of a run-in period to assess future compliance Data analysed according to intention to treat principle Unclear about "minimization technique" of randomization Specific characteristics re: CA stage good, but other confounders Not addressed in much detail Quality: good
Messing, Edward, et al., 1999^ 146 ^ Prospective RCT | 100 men enrolled (1988-1993) who had undergone radical prostatectomy and pelvic lymphadenectomy @ no more than stage T2 100 men randomized (2 ineligible after randomization) Initial accrual goal of 220 subjects Median age=65.6 Median follow-up of 7.1 years | Recruited from various institutions by dx (specific recruitment methods not mentioned) | Observation of immediate antiandrogen therapy; followed subjects until signs of elevated serum PSA levels noted | Immediate group given 3.6 mg goserelin SQ every 28 days Observation group followed until signs of progression CA noted other than elevated serum PSA levels | Overall survival @7.1 years Immediate group vs observation: 89% in immediate group 62% in observation only group (p=0.02) PC specific survival was 97% vs. 63% (immediate vs. observation) [p=0.001] Progression-free survival rate was 84% vs. 37% (immediate vs. observation) [p<0.001] Unable to determine 95% CI from tables | Early, immediate hormonal therapy significantly increases the chances of survival | Temporal issues re: not using PSA levels as part of inclusion criteria interesting, but addressed lack of centralized review of pathologic findings undermines internal validity Cox model used to manage confounders Needs more discussion of consequences of falling short of initial accrual goal No blinded assessment of outcome Quality: good
Pilepich MV et al., 1997^ 145 ^ RCT comparing adjuvant hormonal treatment with XRT to XRT alone | 977 patients with locally advanced PC were enrolled Patients who had either a perineal or retropublic prostatectomy were eligible if there were positive surgical margins or seminal vesicle involvement In both groups, about 15% had Gleason score 2-5, 54% 6-7 and 31% 8-10 29% of the immediate hormonal treatment group and 26% of the hormones at relapse had positive nodes About 15% in both groups had prostatectomies 32 patients were deemed ineligible Median follow up was 4.5 yrs (range 0.2 to 8.8 yrs) | Between 1987-1992, patients were entered by a telephone call to the study headquarters within the first week of starting XRT Multicenter study of the Radiation Therapy Oncology Group | Disease free survival was defined as survival in the absence of local or regional failure, or distant metastasis Local failure was defined as persistence of the palpable tumor beyond 24 months after study entry, reappearance or progression of palpable tumor, or biopsy proven disease 2 or more years after study entry Regional failure required clinical or radiographic Evidence or tumor in the pelvis Time to local recurrence or to distant metastasis was measured from the date of randomization to the occurrence of either event Absolute survival was measured from the date of randomization to the date of death or most recent follow-up evaluation | Patients were randomized to receive XRT alone (488) or with adjuvant hormonal treatment (489) For all, the prostatic bed received 44-46 Gy in 1.8-2.0 Gy fractions with a prostatic target volume boost of 20-25 Gy using a multiple field technique. Goserelin 3.6 mg SQ was begun during the last week of XRT in the intervention group and upon relapse in the control group | 16% of the combined group and 29% of the hormones at relapse group had local failure at 5 yrs (p<0.01). 17% of the combined group and 30% of the hormones at relapse group had metastatic disease at 5 yrs (p<0.01). 60% of the combined group and 44% of the hormones at relapse group were disease free at 5 yrs (p<0.01). Survival for patients with Gleason score 2-7 was 76% at 5 years and not different between the groups. Survival at 5 years for patients with Gleason score 8-10 was 65% in the combined treatment group and 55% in the hormone at relapse group (p=0.03). | Adjuvant goserelin is associated with a remarkable improvement in local control and disease free survival The beneficial adjuvant effect appears to be more prominent in patients with high grade lesions An improvement in overall survival was observed only in patients with the most unfavorable lesions (Gleason 8-10), and is most prominent in those patients who did not undergo prostatectomy before radiotherapy | Potential bias in how patients were selected to participate in study Potential bias in identification of clinical failure Unclear if an intention to treat analysis was done, or how many in the treatment upon relapse group received treatment Quality: fair
Medical Research Council Prostate Cancer Working Party Investigators Group.^ 147 ^ | 934 patients with local disease considered too advanced for curative treatment or asymptomatic metastatic disease who had not previously received hormonal treatment. 10 men were younger than 60 years and 82 men were older than 80 years. | From an unknown number of urologists' clinics in the UK. How participating urologists were selected was not described. | Survival, disease progression (as measured by need for TURP), and complications (spinal cord compression, pathologic fracture, ureteric obstruction, extra-skeletal metastasis) Annual survey forms were sent to those enrolled Information on cause of death was obtained from National Health Service records Used intention to treat analysis | 469 men were randomized to immediate treatment (orchiectomy or LHRH analogue) and 465 men to deferred treatment (same treatment once clinician detected indication) 55% of the immediate group and 52% of the deferred group had non-metastatic disease confirmed by bone scan | 347 men in the deferred group subsequently received treatment Indications for treatment included pain (52%), local progression (46%), and increasing tumor marker level (7%) Of the 244 patients in the deferred group with non-metastatic disease, 169 were later treated, 50% of whom began treatment within 27 months For those with non-metastatic disease, 38% of the immediate group and 59% of the deferred group developed metastases or died from PC (p<0.01); 18% of the immediate group and 26% of the deferred group developed complications; and 62% of deaths in the immediate group and 70% in the deferred group were from prostate cancer (p<0.01) 14% of the immediate group and 58% of the deferred group underwent TURP | Those most likely to benefit from deferred treatment are elderly men with non-metastatic disease Progression of disease will be arrested or slowed in patients treated immediately The data presented provide consistent support for the benefits of immediate treatment | Length of follow-up wasn't reported There was no protocol for management of the patient other than hormonal treatment, nor guidelines for indications for treatment in the deferred group Patients were stratified based only on metastasis, and no information on tumor grade or stage was included There was no blinding of clinicians. The need for TURP may not be the optimal method of evaluating progression Quality: fair
Corn BW et al. 1999^ 143 ^ | 139 patients with locally advanced disease who had either a perineal or retropublic prostatectomy Mean age was 66 years In the immediate hormone treatment group, 65% had Gleason 2-7 and 35% 8-10, and median PSA was 3.2 Hormone treatment in relapse group, 58% had Gleason 2-7, 42%had Gleason 8-10, and median PSA 1.6 31% had positive nodes in both groups | Between 1987-1992, patients were entered by a telephone call to the study headquarters within the first week of starting XRT Multicenter study of the Radiation Therapy Oncology Group | Disease free survival was defined as survival in the absence of local or regional failure, or distant metastasis Local failure was defined as persistence of the palpable tumor beyond 24 months after study entry, reappearance or progression of palpable tumor, or biopsy proven disease 2 or more years after study entry Regional failure required clinical or radiographic evidence or tumor in the pelvis. Time to local recurrence or to distant metastasis was measured from the date of randomization to the occurrence of either event. Freedom from biochemical relapse (FFBR) was also computed for various PSA thresholds | Patients were randomized to receive XRT alone or with adjuvant hormonal treatment For all, the prostatic bed received 60-65 Gy in 1.8-2.0 Gy fractions using a multiple field technique Goserelin 3.6 mg SQ was begun during the last week of XRT in the intervention group and upon relapse in the control group | Using a PSA threshold of 0.5 ng/ml at 5 years, the FFBR was 65% for men who received combination therapy compared to 42% for men receiving XRT alone (p<0.01) In a multivariate model, combined treatment was an independent predictor of remaining FFBR with an endpoint PSA <4 ng/ml (p=0.05), <1 ng/ml (p<0.01), or <0.5 ng/ml (p<0.01) No differences evident between the two groups in rates or clinically diagnosed local progression, distant relapse, or absolute survival | The benefit of combination treatment after surgery was evident after evaluating a spectrum of biochemical outcomes No benefit was seen, among those patients treated with combination therapy after surgery, relative to other classic oncologic end points Experimental arm of the study, although tolerable and biochemically beneficial, cannot be viewed as standard of care | Potential bias in how patients were selected to participate in study Potential bias in identification of clinical failure Unclear if an intention to treat analysis was done, or how many in the treatment upon relapse group received treatment Quality: good

Evidence Table 5B: Efficacy of treatment with androgen deprivation therapy (Key Question 6): systematic reviewAppendix B. Evidence Tables

Citation | Studies | Results | Comments
Aronson N et al., 1999^ 192 ^ | Systematic literature review from 1966-March, 1998 Only accepted RCTs Meta-analysis Studied men with advanced cancer (both metastatic and locally advanced) | No difference for patients treated by LHRH agonist vs. orchiectomy or DES No difference in survival among patients treated with different LHRH agonists Trend toward lower survival in patients treated with nonsteroidal anti-androgens compared with LHRH agonists, orchiectomy, or DES Adverse effects: Withdrawals: 0-4%% LHRH agonists nonsteroidal anti-androgens: 4-10% Erectile dysfunction more common with LHRH agonists and orchiectomy then nonsteroidal anti-androgens, but can't quantify differences Hot flashes more common and Gynecomastia less common among patients treated with LHRH agonists | Quality: good (doesn't include most recent articles on ADT efficacy in locally advanced PC)

Evidence Table 6: Efficacy of watchful waiting (Key Question 7)Appendix B. Evidence Tables

Citation | Participants | Evaluation | Initial Treatment | Results | Comments
Chodak, GW et al., 1994^ 46 ^ | Pooled analysis from 6 cohort studies of 828 men with clinically localized PC treated conservatively | Clinical evaluation at baseline Histologic grading | Watchful waiting for all | Relative disease-specific survival at 10years: Grade 1 or 2: 87% Grade 3: 34% Metastasis-free survival among those who hadn't died of other causes: Grade 1: 81% Grade 2: 58% Grade 3: 26% | Unclear if these patients are comparable to screen-detected Quality: good
Albertsen, PC et al., 1998^ 47 ^ | N=767 men Ages 55-74 at diagnosis from CT tumor registry, diagnosed from 1971-1984 and not tested 26% diagnosed by needle biopsy 71% diagnosed by TURP or open prostatectomy Excluded men with missing data | Clinical evaluation at baseline Histologic grading Evaluation did not include CT or MRI | Watchful waiting or immediate/deferred hormonal | Probability of dying of PC at 15 years: 33% of men had Gleason 2-5 56% had Gleason 6-7 10% had Gleason 8-10 10% of men with Gleason 8-10 accounted for 25% of PC deaths Over 10 years, 23 died from PC and 39% from competing hazards No difference in survival between those detected by needle biopsy and those detected by TURP or prostatectomy | Unclear if these patients are comparable to screen-detected Uncertain why these men chose watchful waiting Quality: good
  Gleason | Ages 55-59 | Ages 70-74
  2-4 | 4% | 7%
  5 | 6% | 11%
  6 | 18% | 30%
  7 | 70% | 42%
  8-10 | 87% | 60%
Johansson, JE, 1997^ 48 ^ | N=648 consecutive men diagnosed with PC from March 1977-February 1984 at medical center in Sweden: 84% diagnosed by palpable nodules 16% by surgery for BPH Only 6 lost to follow-up Mean age=72 years | Physical Exam Chest x-ray IVP Bone scan Bone x-rays for abnormal bone scan No nodal staging Baseline Evaluation found: 47% localized 28% locally advanced 25% metastatic Mean follow-up=14 years Patients reassessed at 2-12 month intervals | Of localized cancers (n=300): 0.7% had RP 25% had radiation or hormonal treatment 74% had no treatment Of locally advanced and metastatic cancers (n=342) All treated hormonally | At the end of study, 84% of participants had died: 31.3% of all participants had died of Additional participants, PC a contributing cause of death: 5.5% of participants 6.5% of deaths % of deaths due to PC: 44% participants younger than 61 25% older than 80 at diagnosis Overall corrected 15-year survival: 71.8% without initial metastasis 5.7% with initial metastasis Of men with initial localized cancers: 12% developed metastasis 11% died of PC Corrected 15-year survival: 80.9% No difference in survival between treated and untreated | Excellent prognosis for men with localized cancer with well/moderately differentiation Quality: good
Brasso K et al., 1999^ 151 ^ | All men ages 84 or younger at diagnosis (1943-1986) Used data only for those men who survived 10 or more years 4.5%-9.3% survived 10+ years Median age 68 | Data from Danish Cancer Registry Information on stage but not grade | Usual care for localized PC in Demark is deferred hormonal treatment | Mean survival=14.1 years Patients with clinically localized PC at diagnosis: mean survival=15.3 years Overall mortality=69.2% Death directly due to PC=42.7% PC as contributing cause of death=19.1% PC was direct or contributing cause of death in 61.3% of deaths among men with clinically localized cancer and 75.9% of men with advanced PC Annual risk of death from PC remained stable at about 3% | Data totally depends on accuracy of stage and death certificate data Unclear if these patients are comparable to screen-detected Quality: good
Sandblom, G et al., 2000^ 152 ^ | N=813 Population-based cohort of men diagnosed with PC between 1974-1986 No screening done Excluded cases diagnosed at autopsy Mean age at diagnosis: 73 years (296 men younger than age 70) | Bone scan Physical exam and history 47% had localized tumors | RP or radiation given in selected patients under age 70 with localized tumors Most asymptomatic localized tumors treated with watchful waiting | 94% died before December 1997 39% of all men died of PC 42% of all deaths were due to PC (includes deaths thought due to PC by either death certificate or research team) At 15 years, survival of those treated with watchful waiting was better than men treated in any other way At 20 years, survival of watchful waiting group slightly less than men treated definitively 10-year disease-specific survival for men with localized PC treated with watchful waiting: Grade 1: 90% Grade 2: 74% Grade 3: 59% | Uncertain if these patients are similar to those found by screening Quality: good
Lu-Yao, GL and Yao, SL, 1997^ 130 ^ | Data from 59,876 SEER registry patients Ages 50-70 with clinically localized PC diagnosed between 1983-1992, and accompanying death certificate data from the states (previously validated for prostate cancer deaths) Mean length of follow-up=44.5 mos. | Cancers classified into 4 histologic grades: 1 (Gleason 2-4) 2 (Gleason 5-7) 3 (Gleason 8-10) Unknown; pathologically staging for men with RP and clinical staging for others | RP, radiation, or conservative management from SEER program | 10-year mortality for men with grade 1 PC who received conservative treatment was about the same as an age-matched control group For men with grade 2 disease, 10-year relative survival (relative to age-matched controls) for mean treated conservatively was 0.78, while the prostatectomy and radiation-treated groups were about the same as the age matched control group For men treated conservatively with grade 3 disease, the 10-year relative survival was 0.35 (radiation group 0.63 and prostatectomy group 0.87) | Uncertain if these patients are similar to screening-detected Quality: good

Evidence Table 7: Harms of treatment (Key Question 8)Appendix B. Evidence Tables

Citation | Participants | Measurements | Results | Comments
Robinson, JW et al., 1997^ 155 ^ | Comprehensive literature review and meta-analysis of rates of erectile dysfunction associated with RP and EBRT 40 articles found Pretreatment sexual function must be known | 18 studies used chart reviews Questionnaires used in 5 studies, interviews in 8 studies Physiologic measures used in 2 studies | Logistic regression model Probability of maintaining normal erectile function: RP: 0.42 EBRT: 0.69 (p<0.0001) | Quality: fair (included some studies with measurements of uncertain validity)
Fowler, FJ et al., 1996^ 179 ^ | N=373 Sample of Medicare beneficiaries who had RP for PC Patients treated with EBRT from SEER registries | Self-administered mailed questionnaire several years after treatment | 91% response rate for RP patients 83% response rate for EBRT patients Sexual function (% inadequate erection for intercourse) Age < 70 RP: 89% EBRT: 67% Age > 70 RP: 88% EBRT: 73% Urinary function (% wearing pads) RP: 32% EBRT: 7% Bowel function (% medium/big problem with frequent bowel movements) RP: 3% EBRT: 10% | Quality: good
Widmark, A et al., 1994^ 180 ^ Fransson, P. and Widmark, A., 1996^ 175 ^ | Umea, Sweden N=200 patients with PC treated by EBRT N=200 age-matched controls | Pre-tested mailed questionnaire, some linear-analog and some multiple responses | 93% response rate in PC group 71% response rate in control group Sexual function: (% failure to achieve erection) EBRT+ADT: 87% Control: 12% EBRT: 56% Urinary function (% leakage quite a bit/very much) Control: 4% EBRT: 15% Bowel function (% have problems with intestine quite a bit/very much) Control: 5% EBRT: 30% | Quality: good
Helgason, AR et al., 1996^ 168 ^ Helgason, AR et al., 1997^ 165 ^ Adolfsson, Jet al., 1998^ 174 ^ | Stockholm area N=431 men with PC treated in various ways N=435 age-matched controls | Self-administered questionnaire assessing urinary, bowel, sexual function | Response rate 79% in PC group and 73% in control group Sexual function: (% distressed with erection capacity) Control: 63% RP: 82% EBRT: 81% ADT: 63% Urinary function (% with any leakage) Control: 14% RP: 65% EBRT: 33% No Rx: 30% Bowel function (% urgency) Control: 10% RP: 10% EBRT: 35% No Rx: 18% | Quality: fair (uncertain validation of questionnaire)
Litwin, MS et al., 1995^ 169 ^ Litwin MS, 2000^ 171 ^ | N=214 with clinically localized PC treated in different ways N=273 aged-matched controls without PC Retrospective cross-sectional study Patients from large managed-care population | HRQol surveys Self-administered mailed questionnaires Prostate-targeted functional items | 79% response rate among PC patients 46% responses rate in control group No group differences in potential confounders Sexual function (% poor/very poor) Control: 46% Watchful waiting: 49% RP: 79% EBRT: 71% Urinary function (% frequent dribbling/no control) Control: 6% Watchful waiting: 9% RP: 21% EBRT: 8% Bowel function (% rectal urgency 1+times/day) Control: 13% Watching waiting: 18% RP: 13% EBRT: 23% No differences among groups in overall Qol measures | Quality: fair (low response rate in control group)
Stanford, JL et al., 2000^ 161 ^ Potosky AL et al., 2000^ 170 ^ | Patients diagnosed with PC in 6 SEER areas, random sample of 5,672 patients 83.5% contacted and invited to participate 62.3% completed 6 and/or 12-month survey (N=3,533) 2^nd^ study reports on subset of 1,591 patients given 6,12 and/or 24-month surveys | Mailed, self-administered questionnaire at 6, 12, and 24 months after diagnosis Patients asked to recall baseline (before treatment) function | Sexual function (% sexual function moderate to big problem) % erections not firm enough for intercourse) Urinary function (% frequency of incontinence > 2/day) 2^nd^ study: (24-month survey) (% wore pads to stay dry) RP: 28.3% EBRT: 2.5% % erection insufficient for intercourse RP: 82.1% EBRT: 50.3% % bowel urgency) RP: 16.1% EBRT: 30.5% | Quality: fair (low response rate)
  | Baseline | 24 Months
  All RP ages: | 17.9% | 41.9%
  | Baseline | 24 Months
  All RP ages: | 15.8% | 59.9%
  Age < 60: | 7.4% | 61%
  75-79: | 51.4% | 80.9%
  | Baseline | 24 Months
  All RP ages: | 2.6% | 11.9%
  Age < 60: | 1.7% | 10.0%
  75-79: | 4.1% | 40.8%
Talcott, JA et al., 1998^ 163 ^ Talcott, JA et al., 1997^ 164 ^ | Men with newly diagnosed PC, nonmetastatic; 398 approached; 80 refused and 29 did not complete baseline questionnaire Final N=287 (72%) 48.4% had EBRT 44.8% had RP 6.5% no Tx | Previously validated self-administered questionnaire before treatment and at 3 and 12 months afterward | Sexual function (% erections inadequate for intercourse) Urinary function (% wearing pads) Bowel function (% bowel urgency or tenderness) Nerve-sparing RP resulted in same amount of sexual or urinary dysfunction as non-nerve sparing RP | Quality: good
  | Baseline | 12 Months
  RP: | 32% | 93%
  EBRT: | 45% | 67%
  | Baseline | 12 Months
  RP: | 3% | 35%
  EBRT: | 1% | 5%
  | Baseline | 12 Months
  RP: | 7% | 6%
  EBRT: | 1% | 19%
Brandeis, JM et al., 2000^ 187 ^ | N=48 men with clinically localized PC treated at UCLA with brachytherapy N=74 similar men treated with RP Retrospective cross-sectional study Literature controls | Self-administered mailed questionnaires 3-17 months after treatment 86% response rate from brachytherapy patients 73% response rate from RP patients General quality of life questionnaires and symptom specific questionnaires | RP patients younger RP and brachytherapy patients similar in general quality of life measures Urinary bother scores (higher scores=better outcomes): RP: 74 Brachy: 65 Controls: 86 Bowel bother: RP: 90 Brachy: 81 Controls: 89 Sexual bother: RP: 34 Brachy: 39 Controls: 53 | Quality: good
Lee, W R et al., 1999^ 189 ^ | 46 men with clinically localized PC consecutively treated with brachytherapy Complete information on 44 | Self-administered questionnaire, validated Completed before treatment and at 1 and 3 months after treatment | Modest decrease in quality of life at 1 month, returning to baseline at 3 months Score of lower urinary tract symptoms (I-PSS) mean at: T_0_: 8.3 T_1_: 19.7 T_3_: 15.4 indicating an increase in symptoms | Quality: fair (no absolute percentage of patients having various degrees of problems given)
Steineck, G et al., 2002^ 173 ^ One point survey of men in an RCT comparing RP and WW | 326 of 376 eligible men (87%) responses from survey about 4 years after randomization Mean age 64-65 | Validated scales, some disease-specific and some general | Erectile dysfunction: 80% RP 45% WW Urinary Leakage: 49% RP 21% WW Weak urinary stream: 28% RP 44% WW No difference in anxiety, bowel function, depression, subjective quality of life | No pre-treatment measure Quality: good

Evidence Table 8: Cost-effectiveness of screening (Key Question 9)Appendix B. Evidence Tables

Citation | Methods | Results | Comments
Barry MJ et al., 1995^ 210 ^ Coley CM et al., 1997^ 204 ^ | MEDLINE search for studies of efficacy of treatment Developed decision analysis for one-time PSA and DRE screening of men ages 50 years and older Markov models Efficacy assumptions favorable for screening | With favorable assumptions, one-time screening would increase discounted average life-expectancy by 7-11 days for screened men ages 50-69 and 3 days for men ages 70-79, but with considerable iatrogenic morbidity With favorable assumptions, dollars per life-year saved (no adjustment for iatrogenic morbidity): Age 50-59: $12,491 Age 60-69: $18,769 Age 70-79: $65,909 Relaxation of favorable assumptions about treatment efficacy and cancer-specific mortality lead to dramatically increased cost-effectiveness ratios, still without adjusting for iatrogenic morbidity | Quality: good
Kattan MW et al., 1997^ 211 ^ | Built on Barry and Coley model after analysis showed it to be accurate Markov model All patients begin with localized PC, compares RP with watchful waiting Utilities come from small interview study of men without PC using time trade-off concerning relevant health states Secondary Monte-Carlo sensitivity analysis | Quality of life adjustment downgrades watchful waiting benefit because of concern about living with cancer QALY benefit of RP over watchful waiting for men with PC: These numbers are not discounted; with discounting, RP benefit is reduced If more recent morbidity figures are used, RP benefit is reduced | Authors conclude that men under 70 do better with RP, but that men ages 70 and over face a toss-up (unless higher co-morbidity, in which watchful waiting is superior) Quality: good
  Age | Grade | Benefit
  60 | poor | 2.43 years
  60 | moderate | 1.16 years
  60 | well | 0.90 years
  75 | poor | 1.05 years
  75 | moderate | .042 years
  75 | well | 0.28 years