# Appendix A. Acknowledgements

## Acknowledgements

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (Task No. 3). We acknowledge at AHRQ the continuing support of Jacqueline Besteman, J.D., M.A., Director of the AHRQ Evidence-based Practice Center Program and David Atkins, M.D., M.P.H., Director of the Clinical Prevention Program for the US Preventive Services Task Force. We especially want to thank our USPSTF liaisons: Cynthia D. Mulrow, M.D., M.P.H., University of Texas at San Antonio, San Antonio, TX; Paul S. Frame, M.D., Tri-County Family Medicine, Cohocton, New York, and Albert Siu, M.D., M.S.P.H., The Mount Sinai Medical Center, New York, NY.

The investigators deeply appreciate the considerable support and contributions of staff of Research Triangle Institute, including Linda Lux, M.P.A., and Sonya Sutton, B.S.P.H., for substantive and editorial work on this systematic review, and Loraine Monroe, for superior secretarial assistance. In addition, we are indebted to staff from the University of North Carolina at Chapel Hill and the Cecil G. Sheps Center for Health Services Research, including Timothy S. Carey, M.D., M.P.H., Director of the Sheps Center and Co-Director of the RTI-UNC Evidence-based Practice Center; Anne Jackman, M.S.W., Lynn Whitener, M.S.L.S., Dr.P.H., and Carol Krasnov.

We also owe our thanks to our external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of this systematic evidence review: Michael Barry, M.D., Massachusetts General Hospital, Boston, MA; Barry Kramer, Journal of the National Cancer Institute, Baltimore, MD; Richard Hoffman, M.D., M.P.H., Albuquerque VA Medical Center, Albuquerque, NM; Curtis Mettlin, M.D., Roswell Park Cancer Institute, Buffalo, NY; Marc B. Garnick, M.D., Beth Israel Deaconess Medical Center, Boston, MA; David Lush, M.D., Medical College of Pennsylvania Hospital, Philadelphia, PA; Theodore Geniats, M.D., University of California, San Diego, La Jolla, CA; Ian M. Thompson, M.D., University of Texas Health Sciences Center at San Antonio, San Antonio, TX; and John W. Freightner, M.D., M.Sc., F.C.F.P, Canadian Task Force on Preventive Health Care, London, Ontario, Canada.