# Discussion

## Context

Screening for prostate cancer is a controversial topic. National groups disagree about recommendations. An important reason for the disagreement is that no well-conducted randomized controlled trial (RCT) comparing screening with no screening has yet been completed, although 2 large RCTs are in progress (the National Cancer Institute Prostate, Lung, Colorectal, and Ovary [PLCO] trial and the European Randomized Study of Screening for Prostate Cancer [ERSPC]). This review considers the indirect evidence available now to guide the USPSTF in making a recommendation about screening while the field awaits the results of the 2 trials.

## Major Findings and Limitations of the Literature

Prostate-specific antigen (PSA) and, to a lesser extent, digital rectal examination (DRE) can detect prostate cancer at an earlier stage than it would be detected clinically. Nevertheless, because some prostate cancers are clinically important and some are not, a major problem in considering the utility of screening is the heterogeneity of prostate cancer itself.

The large discrepancy between prostate cancer diagnoses and deaths indicates that at least some cancers detected by screening are unimportant clinically. Because of a lack of precision about the prognosis of prostate cancers of various types, research has not defined well the most appropriate target of screening, i.e., those cancers that will cause clinical symptoms and death and can be treated better by earlier detection.

The efficacy of various types of treatment for clinically localized prostate cancer is largely unknown. We lack direct evidence that such treatments as radical prostatectomy (RP), external beam radiation therapy (EBRT), brachytherapy, or androgen deprivation therapy (ADT) are effective for screen-detected clinically localized cancer. RP improves prostate cancer-specific mortality after 8 years in men with clinically-detected cancer, but its effect on all-cause mortality is uncertain. ADT is probably effective in prolonging survival in locally advanced cancer.

Each treatment for prostate cancer is associated with various potential harms, including sexual, urinary, and bowel dysfunction. The magnitude of harms is best documented for RP, EBRT, and ADT, and least well documented for brachytherapy.

The costs of a screening program for prostate cancer are potentially large. If treatment is highly efficacious, then for men ages 50 to 69 years the cost-effectiveness of screening may be reasonable; if treatment is less efficacious, the results may be net harm and high costs. Assuming that any potential benefit to screening accrues only after some years, men ages 70 to 75 years and older or with less than a 10 year life expectancy are unlikely to benefit.

### Benefits and Harms

Ideally, we would present here an outcomes table, providing information about the estimated benefits and harms of screening 1000 men in different age groups. Although we could estimate the harms of various modalities of treatment (see key question 8) with reasonable certitude, the uncertainties about the benefits are too great. Thus, completing such a table would necessarily be based on assumptions that have little basis in evidence, and we caution against attempting to do so at this juncture.

We can contrast the potential trade-off between benefits and harms for men by age. We know that older men (e.g., age 70 years or older) have a higher incidence (and, among men who have not been screened, a higher prevalence) of prostate cancer than younger men (e.g., ages 50 to 69 years). We also know that a higher percentage of older men will have an abnormal PSA or DRE screening test, partly because of an increased prevalence of BPH. Thus, the number of men offered a biopsy will be larger for older men. The percentage of biopsies that detect cancer after a positive PSA screening test does not differ a great deal by age.

Assuming that screening is beneficial in reducing mortality, and assuming that the benefit derives from detection of intracapsular tumors that would not have caused symptoms for some years, then older men would tend to benefit less as they are more likely to die of other causes before they would die of prostate cancer. Indeed, given 2 men with prostate cancer, both with a Gleason score of 7 or higher (i.e., more aggressive cancers), the older man is less likely to die of the cancer than the younger man. Finally, we also know that the harms of treatment for prostate cancer are at least as great for older men as younger men. Thus, if there is a benefit from screening, it seems likely that older men would have a smaller net benefit than younger men.

We do not have enough information to make these contrasts for African American men compared with white. We know that the incidence of prostate cancer among African Americans is nearly double that of white, and that mortality for African American men is more than double that for whites.^ 14 ^ But most of the studies in this report primarily (or exclusively) involve white men rather than any other ethnic or racial group. If screening is beneficial, then African American men could have a larger absolute benefit than white men. This may not mean screening at an earlier age (the age-incidence curve is as steep for African Americans as for whites) or screening at a different interval, but the total level of benefit could be higher. The same uncertainties about screening, however, apply to African Americans as they do to whites and other groups. Whether screening would result in benefit, and whether that benefit would outweigh the attendant harms, is unknown.

### Future Research Needs

Successful completion of the PLCO and ERSPC screening trials is the most important research advance needed at this time. In addition, RCTs of various treatments for clinically localized prostate cancer, comparing standard treatments against watchful waiting (as in the Prostatectomy Intervention Versus Observation Trial [PIVOT]) and against each other, would be very useful.

Further research into identifying factors that would allow us to more precisely categorize prostate cancer into prognostic categories, better discriminating between clinically important and clinically unimportant cancers, would assist us to focus our efforts on those cancers that cause death and disability.

Finally, to date research concerning screening for prostate cancer has focused on detecting localized prostate cancer that might be cured by aggressive treatment. Several pieces of indirect evidence in this review suggest a different model for how screening might be able to impact mortality and morbidity from prostate cancer. This evidence includes these facts:

1. prostate cancer mortality declined soon after the widespread introduction of screening (but if screening is contributing to this trend then the lead time must be short);
2. reduction in the incidence of late-stage disease (with a short lead time) has been an impressive characteristic of this decline; and
3. ADT has been shown in several RCTs to improve overall survival in men with locally advanced disease (which may be a subset of cancers with a shorter lead time). RP has been shown to improve prostate cancer-specific mortality for men with clinically detected prostate cancer.

If screening is responsible for at least some of the reduction in prostate cancer mortality, and if the cancers that are being better treated (e.g., by ADT or RP) as a result of screening are locally advanced (rather than localized), or advanced within the localized category (e.g., as shown by being clinically detected), then more research is needed in finding less expensive and more efficient means of detecting cancer at a stage intermediate between those detected by PSA and those that have already metastasized.