# Methods

This chapter documents procedures that the RTI-UNC Evidence-based Practice Center (EPC) staff used to develop this report on screening for prostate cancer. During preparation of the evidence report, we collaborated with 2 current members of the US Preventive Services Task Force (USPSTF) who served as liaisons to the EPC topic team (see Acknowledgements). We first document the analytic framework and key questions developed at the beginning of the review. We then describe the inclusion and exclusion criteria for admissible evidence, our strategy for literature search and synthesis, and our approach to developing the final summary of the evidence.

## Analytic Framework and Key Questions

The analytic framework (Figure 1) describes the relationship between screening and treating patients in a clinical setting and reduced morbidity and/or mortality from prostate cancer. The arrows with superscripts in the analytic framework represent steps in the chain of logic connecting screening with reduced morbidity and/or mortality from prostate cancer; the superscripts refer specifically to 9 key questions that guided our literature searches and synthesis of the evidence. We examined 1 overarching question (Key Question 1, linking screening and ultimate health outcomes) and 8 additional questions pertaining to specific links in the analytic framework.

Figure 1. Analytic framework for screening for prostate cancer NOTE: Superscripts refer tp Key Questions addressed by this review (see Table 2 and text).

Key Question 1: What are the health outcomes (both type and magnitude) of screening a defined population for prostate cancer compared to not screening?

Key Question 2: What is the yield of screening for prostate cancer (i.e., accuracy and reliability of screening tests, prevalence of undetected cancer in various populations)?

Key Question 3: What harms are associated with screening for prostate cancer?

Key Questions 4-7: What are the health outcomes associated with treating clinically localized prostate cancer with radical prostatectomy, external beam radiation therapy or brachytherapy, androgen deprivation, or watchful waiting?

Key Question 8: What harms are associated with treatment of clinically localized prostate cancer with the treatments above?

Key Question 9: What costs are associated with screening for and early treatment of prostate cancer? Have studies modeled the potential benefits of screening? What is the cost-effectiveness of screening for prostate cancer?

## Eligibility Criteria for Admissible Evidence

The authors and Task Force liaisons developed eligibility criteria for selecting the evidence relevant to answer the key questions (Table 2). We first searched for evidence from randomized controlled trials (RCTs) for the efficacy of screening. As we found no well-conducted and well-analyzed RCT of screening, we then examined case-control and ecologic evidence regarding the overarching key question (Key Question 1).

Table 2. Inclusion criteria, search strategy, and results of searches

Key Question | Inclusion Criteria | Search Terms | Number of Articles
Key Question | Inclusion Criteria | Search Terms | Identified for Abstract Review | Retained for Full Review
1. Efficacy of screening in reducing mortality from prostate cancer | RCT or case-control Screening test (PSA or DRE or other) Health outcomes ----- or ----- Surveillance (ecologic) study of PC incidence morbidity or mortality over time Defined population Associate mortality with screening | Prostate neoplasm Mass screening RCT Case-control ------------------------- Prostate neoplasm Incidence Mortality Trends Surveillance | 100 1399 | RCT, 1 Case-control, 2 Ecologic, 15
2. Yield of screening tests | Unselected population without PC Screening test used for all Result of screening test compared with a valid gold standard applied to all | Prostate neoplasm Mass screening DRE, PSA Diagnosis Sensitivity/Specificity Predictive value Reproducibility | 1905 | 35
3. Harms of screening | Unselected population Screened group compared with not screened group Either randomized or adjustment for confounders Reliable measure of adverse effects | Prostate neoplasm Mass screening Adverse effects Anxiety, depression Labeling Quality of Life | 94 | 1
4 - 7. Health outcomes of treatment | RCT or large cohort with control group Follow-up at least 2 years At least 75% of patients followed Health outcomes | Prostate neoplasm Therapeutics Treatment Surgery, prostatectomy Radiation Brachytherapy | 656 | KQ4: 3 KQ5: 0 KQ6: 10 KQ7: 6
8. Harms of treatment | Unselected population with PC Treated group compared with valid comparison group Either randomized or adjustment for confounders Not metastatic cancer Valid measures of harms At least 75% of patients followed At least one year follow-up | Prostate neoplasm Therapeutics Treatment Surgery, prostatectomy Radiation Adverse effects Side effects Impotence Urinary incontinence Quality of life | 923 | 32
9. Costs/cost-effectiveness of screening | Costs of screening Costs of treatment Cost-effectiveness, cost-utility Modeling studies | Prostate neoplasm Costs and cost analysis Cost-benefit Cost-effectiveness | 84 | 2

For Key Question 2, concerning the operating characteristics of screening tests, we examined well-conducted systematic reviews and individual studies that started with a primary care or unselected population without prostate cancer and that compared the findings of 1 or more screening tests with an adequate reference standard. For Key Questions 4 through 7, concerning the effectiveness of various therapies, we required evidence from RCTs with health outcomes. For Key Questions 3 and 8, concerning the harms of screening or treatment, we required either RCTs or well-controlled studies that included patient reports and, for treatment, at least 12 months of follow-up. Finally, for Key Question 9, we searched for evidence of the costs and cost-effectiveness of screening, including models of potential benefits, that considered all appropriate costs and estimates of effectiveness supported by reasonable assumptions based on good evidence.

## Literature Search Strategy and Synthesis

The analytic framework and key questions guided our literature searches. We examined the critical literature described in the review by the USPSTF (published in 1996)^ 2 ^ and searched the reference lists of systematic reviews (including Cochrane Library reviews) published since 1993. We then used our eligibility criteria to develop search terms and searched the MEDLINE database for relevant articles concerning humans in the English language published between January 1, 1994, and September 15, 2002. We especially looked for articles involving patients whose experience is clearly generalizable to a primary care US population.

The search strategy and results are given in Table 2. All searches started with the term "prostate neoplasm" and then proceeded by adding further terms as shown in the table.

The first author reviewed abstracts of all articles found in the searches to determine which met eligibility criteria. Other authors reviewed all abstracts excluded by the first reviewer. We retrieved the full text of all articles not excluded by both reviewers (see next to last column in Table 2).

One reviewer then examined the full text of all retrieved articles against the inclusion/exclusion criteria and discussed all excluded articles with one of the other reviewers. We included any article that either reviewer judged had met inclusion criteria (see last column in Table 2). Three of the authors then divided the articles and abstracted data from them, entering the relevant data into predesigned evidence tables (see Appendix B). The abstracting author also graded the articles using the criteria established by the Methods Work Group of the USPSTF.^ 19 ^ The first author read all articles, checked the grading, and discussed the crucial ones with a second author. The authors also discussed key articles with the Task Force liaisons.

## Development of the Final Systematic Evidence Review

The authors presented an initial work plan including a provisional analytic framework and key questions to the entire Task Force in September 2000; we also presented interim reports on results of the literature search and the early results of the synthesis of information in December 2000, March 2001, and September 2002. This draft Systematic Evidence Review was submitted for broad-based external peer review in May 2001; the peer review involved individual experts in the field, representatives of relevant professional organizations, and representatives of organizations and federal agencies that serve as liaisons to the USPSTF. After we received peer review comments and revised the evidence review accordingly, the Task Force voted on the recommendation at its June, 2001 meeting, and finalized the recommendation at its September, 2002 meeting. Afterward, we revised the report for journal publication and made final revisions to this version for the AHRQ website.