# Introduction

## Background

Prostate cancer is the most common noncutaneous cancer and the second leading cause of cancer death in US men. Although several studies are exploring the potential of primary prevention of this disease, primary care clinical practice is currently dealing with great public interest in screening.

Screening for prostate cancer is a controversial topic. Those in favor of screening point to the lack of symptoms in early stage disease, the higher 5-year relative survival for localized (greater than 99%) compared with distant (less than 40%) cancer, and the fact that screening increases the proportion of cancers detected at an early stage.^ 1 ^ Those opposed point to the lack of strong evidence that earlier treatment produces better health outcomes and the problem of harms arising from the various treatments for prostate cancer.^ 2 ^

Different medical groups make different recommendations about screening for prostate cancer. In 1996, the United States Preventive Services Task Force (USPSTF) recommended against screening for prostate cancer.^ 2 ^ The American College of Physicians-American Society of Internal Medicine (ACP-ASIM) and the American Academy of Family Physicians have both recommended shared decisionmaking.^3,4^ The American Urological Association and the American Cancer Society both have recommended offering screening to every eligible man with a life expectancy of more than 10 years, but have also emphasized the importance of providing adequate information before testing.^5-7^

Since the earlier USPSTF review, investigators have completed new research bearing on the issue of screening for this disease. Among these studies are 2 case-control studies of the effectiveness of digital rectal examination (DRE) in reducing mortality from prostate cancer; analyses of changes in the incidence of and mortality from prostate cancer in various locations; randomized controlled trials (RCTs) of new approaches to its treatment; examinations of the operating characteristics of strategies for prostate cancer screening; and more research on the frequency of harms from treatment of the disease and ways to reduce those harms.

Given the continued controversy over this issue and the new evidence that has appeared since the previous review, the RTI-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) undertook this review for the use of the USPSTF in reconsidering its previous conclusions and recommendation.

## Burden of Suffering

In 2001, the American Cancer Society predicted that 198,100 men would be diagnosed with prostate cancer and that 31,500 men will die from this disease.^ 7 ^ Misattribution of cause of death on death certificates makes an exact counting of men dying as a result of prostate cancer difficult. Some studies show that misattribution of cause of death for this disease may be as high as 20% and that the misclassification may be higher among older men and may vary by aggressiveness of therapy.^ 8 ^ What is clear is that, among cancers, only lung cancer kills more men each year.

As discussed more fully in Chapter III (Results), the incidence of prostate cancer increased slowly from at least the 1970s to 1989, when it increased more dramatically, averaging a gain of 20% per year.^1,9^ After 1992, the incidence of prostate cancer declined at a rate of 10% to 11% per year. These changes have been widely attributed to screening.

Prostate cancer mortality in the United States had been gradually increasing for many years until it began to increase more rapidly in the late 1980s and then to decline in 1991. The age-adjusted mortality rate for all men ages 65 years and older dropped from 243.8 deaths per 100,000 (2.9 per 100,000 among men younger than 65) in 1991 to 206.9 deaths per 100,000 (2.3 per 100,000 for men younger than 65) in 1997, a relative decrease of 15.1% (20.7% for men younger than 65).^1,9^ Observers have attributed this decline in mortality to several different factors, as discussed later in this review.

The burden of prostate cancer falls disproportionately on older men and African-American men. The median age at diagnosis is about 71 years; the median age at death is 78.^ 1 ^ More than 75% of all cases of prostate cancer are diagnosed in men more than 65 years of age, and 90% of deaths due to this disease are in this age group.^1,10^ The average number of life years lost per person dying of prostate cancer is 9.0, compared with 19.3 years for breast cancer and 13.4 years from colorectal cancer.^ 11 ^

African-American men have about a 60% higher incidence rate and a 2-fold higher mortality rate than white men.^ 1 ^ Five-year relative survival is 9% to 15% higher for white men than for African-American men, depending on the date of diagnosis.^ 1 ^

## Epidemiology

### Difference Between Incidence and Mortality

The incidence of prostate cancer in the United States is almost 5 times the mortality rate. This is a larger ratio than any of the other major cancers.^1,12^ This implies that, although prostate cancer is a major cause of cancer death, many more men are diagnosed with this cancer than die from it.

### Risk Factors

The etiology of prostate cancer is unknown. The best-documented risk factors are age, race-ethnicity, and family history. Some studies have also shown statistical associations between prostate cancer and dietary fat, androgen levels, and previous vasectomy, but the results have been neither consistent nor strong enough to recommend taking actions on the basis of these variables to reduce prostate cancer incidence or mortality. Benign prostatic hyperplasia (BPH), a common enlargement of the prostate gland often seen in older men, is not a risk factor for prostate cancer.

The age-specific incidence curve increases more rapidly for prostate cancer than for any other cancer. The incidence rate for men ages 45 to 49 years is 26.6 per 100,000; for men ages 55 to 59 years, 284.4 per 100,000; for men ages 65 to 69 years, 898.7 per 100,000; and for men ages 75 to 79 years, 1,118.5 per 100,000.^13-15^ The lifetime risk of being diagnosed with prostate cancer is about 1 in 6.

Mortality increases with age in a similar fashion (1.0 per 100,000 for men ages 45 to 49; 258.8 per 100,000 for men ages 75 to 79). The lifetime risk of dying of prostate cancer is about 3.4% (about 1 in 29).

Incidence rates for African-Americans are among the highest in the world. Incidence rates for Asian-Americans are approximately one-third to one-half those of US whites. Asian-American and Hispanic men in the United States have rates somewhat lower than those of non-Hispanic white men in this country.^ 10 ^

Men with a first-degree relative with prostate cancer have an approximate 2-fold increase in risk for the disease, and much of this increased risk is expressed in men younger than age 50.^10,16^ Although researchers have made advances in understanding the genetics of this disorder, the evidence is still insufficient to allow screening for specific genetic risk factors.

## Screening Tools

Two basic tools are currently used in the United States to screen for prostate cancer: the DRE test and the blood test for prostate-specific antigen (PSA). With the DRE, the clinician inserts a gloved finger into the rectum to palpate the posterior aspect of the prostate gland for nodules or other abnormalities. The PSA test involves drawing a sample of blood that is tested for a glycoprotein produced primarily by epithelial cells in the prostate gland. Although blood levels of PSA often increase with prostate cancer, other conditions as BPH and prostatitis also may raise PSA levels.

Variations of the PSA test have been developed, primarily to improve the specificity of the test. These include PSA density (the ratio of the PSA level to the volume of the prostate as measured by transrectal ultrasound [TRUS]), PSA velocity (the rate at which the PSA increases over time), the percentage of free PSA (the ratio of the portion of total PSA that is not bound to serum proteins [and thus is "free"] to total PSA), and the amount of PSA that is complexed with proteins.

## Treatment Modalities

Clinicians have used 5 main types of therapies to treat patients with prostate cancer. These include surgery (radical prostatectomy), external beam radiation therapy (EBRT), brachytherapy (the implantation of small radioactive pellets within the prostate), hormonal manipulation (previously with estrogenic drugs or orchiectomy, now primarily with luteinizing hormone-releasing hormone agonists [LHRH agonists] or nonsteroidal antiandrogens, or both), and "watchful waiting" or expectant therapy (involving no treatment until symptoms arise or there is other evidence of progression).

## Staging and Histologic Grading

Two important prognostic factors in prostate cancer are stage and histologic grade. One must understand these factors to appreciate fully the issues involved in screening.

Stage refers to the extent of the disease. Stage can be classified clinically, that is, estimated from clinical tests such as DRE, blood tests, computerized tomography (CT), radionuclide bone scan, or magnetic resonance imaging (MRI), or it can be classified pathologically by using information from histologic examination of the tumor and/or lymph nodes. Two staging systems are in current use - the Whitmore (A-D) approach and the Tumor-Nodes-Metastasis (TNM) approach. Their different stages and substages are defined in Table 1.

Table 1. Staging systems for prostate cancer

Clinical Stage
A-D System | TNM System* | Definition
1. Clinically nonpalpable cancers
A_1_ | T_1a_ | Incidental finding of cancer in < 5% resected (removed) tissue from TURP.
A_2_ | T_1b_ | Incidental cancer finding > 5% resected tissue. Moderately or poorly differentiated grade with < 5% resected tissue from TURP.
B_0_ | T_1c_ | Cancer detected by needle biopsy (e.g., following elevated PSA).
2. Palpable cancers apparently confined within prostate capsule
B_1_ | T_2a_ | Involves one-half of one lobe of the prostate or less.
B_1_ | T_2b_ | Involves more than one-half of one lobe, but not both lobes.
B_2_ | T_2c_ | Involves both lobes of gland but apparently confined (B_2,_ but not T_2c_ cancers can be greater than 1.5 cm but still involve only one lobe.
3. Local extra-capsular penetration
C_1_ | T_3a-3b_ | Penetration of the prostate capsule palpable without evidence of invasion of the seminal vesicles outside the prostate.
C_2_ | T_3c_
| T_4a-4b_ | Palpable invasion of seminal vesicle. Invasion of the bladder neck, external sphincter, rectum, or pelvic muscles.
4. Metastatic Disease
D_1_ | N_x_ | Cannot assess; no apparent nodal involvement
| N_1_ N_2_ N_3_ | Metastasis in a single lymph node 2 cm, metastasis single nodes 2-5 cm, or multiple nodes (all > 5 cm), metastasis in node > 5 cm.
D_2_ | M_1_ | Distant metastasis.
| M_1a_ | Lymph nodes outside the region of the prostate
| M_1b_ | Bone.
| M_1c_ | Other site(s).

* In the TNM system, "T" refers to characteristics of the tumor, "N" refers to the extent cancerous cells are found in lymph nodes, and "M" refers to the extent of metastasis (spread of the cancer).

PSA indicates prostate-specific antigen blood test; TURP, Transurethral resection of the prostate, a procedure for treating benign prostatic hypertrophy (BPH), a noncancerous enlargement of the prostate, by surgically removing parts of the gland.

SOURCE: Office of Technology Assessment, 1995. Based on information presented in M.J. Barry, C.M. Coley, C. Fleming, et.al, "The Safety, Effectiveness, and Cost of Early Detection and Treatment of Prostate Cancer Among Older Men: A Report to the Congressional Office of Technology Assessment.^ 13 ^

An important distinction is whether the cancer is confined within the prostate ("organ-confined" or "localized") or has spread to extracapsular (i.e., outside the prostate capsule) sites. Among neoplasms that have spread outside the capsule, some have spread only to contiguous structures (e.g., periprostatic tissue, seminal vesicles, local lymph nodes) and are termed "locally advanced"; others that have spread to distant structures (e.g., bone) are thus metastatic.

When it is first detected, prostate cancers can be categorized into "clinically localized" or "clinically advanced" disease. Clinically localized refers to the absence of any clinical evidence of spread beyond the prostate itself. If the patient undergoes surgery, the tumor can then be pathologically staged. As discussed later in this review, a number of clinically localized cancers are found at surgery to have spread beyond the capsule.

Histologic grade of the tumor refers to the degree of differentiation of the tumor cells. Pathologists use a standardized scoring system called the "Gleason score" to indicate the degree of differentiation.^ 17 ^ It ranges from 2 to 10, with 2 to 4 indicating well-differentiated tumor cells, 5 to 7 indicating a moderate degree of differentiation, and 8 to 10 indicating poor differentiation.

Although the Gleason score is the standard grading system, studies have found problems with interobserver variability of this score. Aggregating scores into the 3 categories of well, moderate, and poor differentiation improves reliability.^ 17 ^ Another problem is the agreement between Gleason scores based on biopsy specimens and scores based on larger amounts of tumor on surgical pathology specimens. One study found 74% agreement within a Gleason score of ± 1 between prostatectomy and biopsy specimens. The number of specimens overgraded and undergraded was similar.^ 18 ^

## Focus of this Review

The purpose of this review is to update the USPSTF review appearing in the second Guide to Clinical Preventive Services.^ 2 ^ As described more fully in Chapter II, we focus on evidence published since 1994 of the efficacy of screening in reducing mortality from prostate cancer, on the yield of screening tests and the potential harms of screening, on the benefits and harms of treatments for prostate cancer, and finally on the costs and cost-effectiveness of screening.