# References

1 Ortman J, Velkoff V, Hogan H. An Aging Nation: The Older Population in the United States. U.S. Census Bureau; 2014.
2 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. Web-based Injury Statistics Query and Reporting System (WISQARS). http://www.cdc.gov/injury/wisqars/. Accessed: Nov 8, 2017.
3 Bergen G, Stevens M, Burnes E. Falls and Fall Injuries Among Adults Aged ≥65 Years United States, 2014. MMWR Morb Mortal Wkly Rep. 2016;65(37):993-8. PMID: 27656914. https://dx.doi.org/10.15585/mmwr.mm6537a2 27656914
4 Maresh J, Guse C, Layde P. National trends and coding patterns in fall-related mortality among the elderly in the United States. J Public Health Policy. 2012;33(2):202-14. PMID: 22358121. https://doi.org/10.1057/jphp.2012.6 22358121
5 Stevens J, Dellinger A. Motor vehicle and fall related deaths among older Americans 1990-98: sex, race, and ethnic disparities. Inj Prev. 2002;8(4):272-5. PMID: 12460960.12460960
6 Fuller GF. Falls in the elderly. Am Fam Physician. 2000;61(7):2159. PMID: 10779256.10779256
7 Rubenstein LZ, Josephson KR, Robbins AS. Falls in the nursing home. Annals of internal medicine. 1994;121(6):442. PMID: 8053619.8053619
8 Ferrucci L, Guralnik JM, Studenski S, . Designing randomized, controlled trials aimed at preventing or delaying functional decline and disability in frail, older persons: a consensus report. J Am Geriatr Soc. 2004;52(4):625. PMID: 15066083. https://doi.org/10.1111/j.1532-5415.2004.52174.x 15066083
9 Jorstad-Stein EC, Hauer K, Becker C, . Suitability of physical activity questionnaires for older adults in fall-prevention trials: a systematic review. J Aging Phys Act. 2005;13(4):461. PMID: 16301756.16301756
10 Sterling DA, O’Connor JA, Bonadies J. Geriatric falls: injury severity is high and disproportionate to mechanism. J Trauma. 2001;50(1):116. PMID: 11231681.11231681
11 Alexander B, Rivara F, Wolf M. The cost and frequency of hospitalization for fall-related injuries in older adults. Am J Public Health. 1992;82(7):1020-3. PMID: 1609903.1609903
12 Court-Brown CM, Caesar B. Epidemiology of adult fractures: A review. Injury. 2006;37(8):691-7. PMID: 16814787. https://doi.org/10.1016/j.injury.2006.04.130 16814787
13 Court-Brown CM, Clement N. Four score years and ten: an analysis of the epidemiology of fractures in the very elderly. Injury. 2009;40(10):1111-4. PMID: 19596316. https://doi.org/10.1016/j.injury.2009.06.011 19596316
14 Deprey S. Descriptive analysis of fatal falls of older adults in a Midwestern county in the year 2005. J Geriatr Phys Ther. 2009;32(2):67-72. PMID: 20039585.20039585
15 Farahmand B, Michaelsson K, Ahlbom A, . Survival after hip fracture. Osteoporos Int. 2005;16(12):1583-90. PMID: 16217590. https://doi.org/10.1007/s00198-005-2024-z 16217590
16 Bergeron E, Clement J, Lavoie A, . A simple fall in the elderly: not so simple. J Trauma. 2006;60(2):268. PMID: 16508481. https://doi.org/10.1097/01.ta.0000197651.00482.c5 16508481
17 Leibson C, Tosteson A, Gabriel S, . Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. J Am Geriatr Soc. 2002;50(10):1644-50. PMID: 12366617.12366617
18 Burns E, Stevens J, Lee R. The direct costs of fatal and non-fatal falls among older adults - United States. J Safety Res. 2016;58:99-103. PMID: 27620939. http://dx.doi.org/10.1016/j.jsr.2016.05.001 27620939
19 Heinrich S, Rapp K, Rissmann U, . Cost of falls in old age: a systematic review. Osteoporos Int. 2010;21(6):891-902. PMID: 19924496. https://doi.org/10.1007/s00198009-1100-1 19924496
20 Tinetti ME. Clinical practice. Preventing falls in elderly persons. N Engl J Med. 2003;348(1):42. PMID: 12510042. https://doi.org/10.1056/NEJMcp020719 12510042
21 Gill T, Taylor AW, Pengelly A. A population-based survey of factors relating to the prevalence of falls in older people. Gerontology. 2005;51(5):340. PMID: 16110237. https://doi.org/10.1159/000086372 16110237
22 Kannus P, Sievanen H, Palvanen M, . Prevention of falls and consequent injuries in elderly people. Lancet. 2005;366(9500):1885. PMID: 16310556. https://doi.org/10.1016/S0140-6736(05)67604-0 16310556
23 Steinweg KK. The changing approach to falls in the elderly. Am Fam Physician. 1997;56(7):1815-23. PMID: 9371011.9371011
24 Phelan E, Mahoney J, Voit J, . Assessment and management of fall risk in primary care settings. Med Clin North Am. 2015;99(2):281-93. PMID: 25700584. https://doi.org/10.1016/j.mcna.2014.11.004 25700584
25 Ambrose A, Paul G, Hausdorff J. Risk factors for falls among older adults: a review of the literature. Maturitas. 2013;75(1):51-61. PMID: 23523272. https://dx.doi.org/10.1016/j.maturitas.2013.02.009 23523272
26 Ganz D, Bao Y, Shekelle P, . Will My Patient Fall? JAMA. 2007;297(1):77-86. PMID: 17200478 https://doi.org/10.1001/jama.297.1.77 17200478
27 Deandrea S, Lucenteforte E, Bravi F, . Risk factors for falls in community-dwelling older people: a systematic review and meta-analysis. Epidemiology. 2010;21(5):658-68. http://dx.doi.org/10.1097/EDE.0b013e3181e89905 20585256
28 Tinetti ME, Doucette JT, Claus EB. The contribution of predisposing and situational risk factors to serious fall injuries. J Am Geriatr Soc. 1995;43(11):1207. PMID: 7594153.7594153
29 Centers for Disease Control and Prevention. STEADI Materials for Health Care Providers. http://www.cdc.gov/steadi/materials.html. Accessed: Jun 10, 2015.
30 Group Health Guideline Team. Fall Prevention Guideline. Seattle, WA: Group Health Cooperative; 2013.
31 Thomas J, Lane J. A pilot study to explore the predictive validity of 4 measures of falls risk in frail elderly patients. Arch Phys Med Rehabil. 2005;86(8):1636-40. PMID: 16084819. https://doi.org/10.1016/j.apmr.2005.03.004 16084819
32 Arnold C, Faulkner R. The history of falls and the association of the timed up and go test to falls and near-falls in older adults with hip osteoarthritis. BMC Geriatr. 2007;7(17). PMID: 17610735. https://doi.org/10.1186/1471-2318-7-17 17610735
33 Barry E, Galvin R, Keogh C, . Is the Timed Up and Go test a useful predictor of risk of falls in community dwelling older adults: a systematic review and meta-analysis. BMC Geriatr. 2014;14:14. PMID: 24484314. https://doi.org/10.1186/1471-2318-14-14 24484314
34 Ward R, Leveille S, Beauchamp M, . Functional performance as a predictor of injurious falls in older adults. J Am Geriatr Soc. 2015;63(2):315-20. PMID: 25688606. https://doi.org/10.1111/jgs.13203 25688606
35 Lamb SE, Becker C, Gillespie LD, . Reporting of complex interventions in clinical trials: development of a taxonomy to classify and describe fall-prevention interventions. Trials. 2011;12:125. PMID: 21586143. https://doi.org/10.1186/1745-6215-12-125 21586143
36 Fortinsky RH, Iannuzzi-Sucich M, Baker DI, . Fall-risk assessment and management in clinical practice: views from healthcare providers. J Am Geriatr Soc. 2004;52(9):1522-26. PMID: 15341555. https://dx.doi.org/10.1111/j.1532-5415.2004.52416.x 15341555
37 Chou WC, Tinetti ME, King MB, . Perceptions of physicians on the barriers and facilitators to integrating fall risk evaluation and management into practice. J Gen Intern Med. 2006;21(2):117-22. PMID: 16336618. https://dx.doi.org/10.1111/j.15251497.2005.00298.x 16336618
38 Stevens JA, Ballesteros MF, Mack KA, . Gender differences in seeking care for falls in the aged Medicare population. Am J Prev Med. 2012;43(1):59-62. PMID: 22704747. https://dx.doi.org/10.1016/j.amepre.2012.03.008 22704747
39 Moore M, Williams B, Ragsdale S, . Translating a multifactorial fall prevention intervention into practice: a controlled evaluation of a fall prevention clinic. J Am Geriatr Soc. 2010;58(2):357-63. PMID: 20370859. http://dx.doi.org/10.1111/j.15325415.2009.02683.x 20370859
40 Johns Hopkins University, Johns Hopkins Hospital, Johns Hopkins Health System. Falls Prevention Clinic. http://www.hopkinsmedicine.org/physical_medicine_rehabilitation/services/outpatient/falls_prevention_clinic.html. Accessed: Jun 1, 2015.
41 Cleveland Clinic. Falls Prevention Therapy. http://my.clevelandclinic.org/services/rehabilitation-sports-therapy/specialty-therapyservices/falls-prevention-therapy. Accessed: Jun 1, 2015.
42 Vancouver Falls Follow-up Clinic. Falls Preventino Clinic. http://fallclinic.com/information-for-doctors/services-provided. Accessed: Jun 1, 2015.
43 Centers for Medicare & Medicaid Services. The ABCs of the Initial Preventive Physical Examination (IPPE). Baltimore, MD: Department of Health and Human Services, Centers for Medicare & Medicaid Services; 2015.
44 Centers for Medicare & Medicaid Services. Medicare Plan Finder. https://www.medicare.gov/find-a-plan/questions/home.aspx. Accessed: 9/6/2016.
45 Stevens J, Phelan E. Development of STEADI: a fall prevention resource for health care providers. Health Promot Pract. 2013;14(5):706-14. PMID: 23159993. https://doi.org/10.1177/1524839912463576 23159993
46 Wagner E. Chronic disease management: what will it take to improve care for chronic illness? Eff Clin Pract. 1998;1(1):2-4. PMID: 10345255.10345255
47 Prochaska J, Velicer W. The transtheoretical model of health behavior change. Am J Health Promot. 1997;12(1):38-48. PMID: 10170434.10170434
48 Guralnik J, Simonsick E, Ferrucci L, . A short physical performance battery assessing lower extremity function: association with self-reported disability and prediction of mortality and nursing home admission. J Gerontol. 1994;49(2):M85-94. PMID: 8126356.8126356
49 Rikli R, Jones C. Development and validation of a functional fitness test for communityresiding older adults. J Aging Phys Act. 1999;6:127-59. PMID: None.
50 Viccaro L, Perera S, Studenski S. Is timed up and go better than gait speed in predicting health, function, and falls in older adults? J Am Geriatr Soc. 2011;59(5):887-82. PMID: 21410448. https://doi.org/10.1111/j.1532-5415.2011.03336.x 21410448
51 Rubenstein L, Vivrette R, Harker J, . Validating an evidence-based, self-rated fall risk questionnaire (FRQ) for older adults. J Safety Res. 2011;42(6):493-99. PMID: 22152267. https://doi.org/10.1016/j.jsr.2011.08.006 22152267
52 Moyer VA, Force USPST. Prevention of falls in community-dwelling older adults: U.S. Preventive Services Task Force recommendation statement. Annals of internal medicine. 2012;157(3):197-204. PMID: 22868837. https://doi.org/10.7326/0003-4819-157-3201208070-00462 22868837
53 Michael YL, Lin JS, Whitlock EP, . Interventions to Prevent Falls in Older Adults: An Updated Systematic Review. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
54 Kahwati L, Weber R, Pan H, . Vitamin D, Calcium, or Combined Supplementation for the Primary Prevention of Fractures in Community-Dwelling Adults: An Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 160. AHRQ Publication No. 17-05233-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2018.
55 US Preventive Services Task Force. Vitamin D, calcium, or combined supplementation for the primary prevention of fractures in community-dwelling adults: US Preventive Services Task Force recommendation statement. JAMA. 2018;319(15):1-9. doi:10.1001/jama.2018.3185
56 Michael YL, Whitlock EP, Lin JS, . Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Annals of internal medicine. 2010;153(12):815-25. PMID: 21173416. https://doi.org/10.7326/0003-4819-153-12-201012210-00008 21173416
57 Gillespie LD, Robertson MC, Gillespie WJ, . Interventions for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2012;9:CD007146. PMID: 22972103. http://dx.doi.org/10.1002/14651858.CD007146.pub3 22972103
58 Tricco AC, Thomas SM, Veroniki AA, . Comparisons of Interventions for Preventing Falls in Older Adults: A Systematic Review and Meta-analysis. JAMA. 2017;318(17):1687-99. PMID: 29114830. https://doi.org/10.1001/jama.2017.15006 29114830
59 Matchar DB, Duncan PW, Lien CT, . Randomized Controlled Trial of Screening, Risk Modification, and Physical Therapy to Prevent Falls Among the Elderly Recently Discharged From the Emergency Department to the Community: The Steps to Avoid Falls in the Elderly Study. Arch Phys Med Rehabil. 2017;98(6):1086-96. PMID: 28202383. https://doi.org/10.1016/j.apmr.2017.01.014 28202383
60 Chu MM, Fong KN, Lit AC, . An Occupational Therapy Fall Reduction Home Visit Program for Community-Dwelling Older Adults in Hong Kong After an Emergency Department Visit for a Fall. J Am Geriatr Soc. 2017;65(2):364-72. PMID: 27858951. https://doi.org/10.1111/jgs.14527 27858951
61 Wallace BC, Small K, Brodley CE, . Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. New York, NY: ACM; 2012.
62 Schleicher R, Sternberg M, Lacher D, . The vitamin D status of the US population from 1988 to 2010 using standardized serum concentrations of 25-hydroxyvitamin D shows recent modest increases. Am J Clin Nutr. 2016;104(2):454-61. PMID: 27385610. https://dx.doi.org/10.3945/ajcn.115.127985 27385610
63 U.S. Preventive Services Task Force. Procedure Manual. https://www.uspreventiveservicestaskforce.org/Home/GetFile/6/7/proceduremanual_2015/pdf. Accessed: July 2017.
64 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. 2007;28(2):105-14. PMID: 16807131. https://doi.org/10.1016/j.cct.2006.04.004 16807131
65 Altman D, Bland J. How to obtain the confidence interval from a P value. BMJ. 2011;343:d2090. PMID: 21824904.21824904
66 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. PMID: 12111919. https://doi.org/10.1002/sim.1186 12111919
67 Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. Higgins J, Green S, editors: The Cochrane Collaboration; 2011.
68 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. JAMA. 2006;295(6):676-80. PMID: 16467236. https://doi.org/10.1001/jama.295.6.676 16467236
69 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314-49.
70 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. https://doi.org/10.1186/1472-6963-4-38 15615589
71 Ciaschini PM, Straus SE, Dolovich LR, . Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724-30. PMID: 19767629. https://doi.org/10.1093/ageing/afp176 19767629
72 Close J, Ellis M, Hooper R, . Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93-7. PMID: 10023893. https://doi.org/10.1016/S0140-6736(98)06119-4 10023893
73 Cohen MA, Miller J, Xiaomei S, . Prevention Program Lowered The Risk Of Falls And Decreased Claims For Long-Term Services Among Elder Participants. Health Affairs. 2015;34(6):971-7. PMID: 26056202. https://doi.org/10.1377/hlthaff.2014.1172 26056202
74 Conroy S, Kendrick D, Harwood R, . A multicentre randomised controlled trial of day hospital-based falls prevention programme for a screened population of communitydwelling older people at high risk of falls. Age Ageing. 2010;39(6):704-10. PMID: 20823124. http://dx.doi.org/10.1093/ageing/afq096 20823124
75 Davison J, Bond J, Dawson P, . Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162-8. PMID: 15716246. https://doi.org/10.1093/ageing/afi053 15716246
76 de Vries OJ, Peeters GM, Elders PJ, . Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. 2010;170(13):1110-7. PMID: 20625015. http://dx.doi.org/10.1001/archinternmed.2010.169 20625015
77 Elley CR, Robertson MC, Garrett S, . Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383-9. PMID: 18808597. https://doi.org/10.1111/j.15325415.2008.01802.x 18808597
78 Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616-22. PMID: 24381025. http://dx.doi.org/10.1093/ageing/aft204 24381025
79 Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383-93. PMID: 24596458. http://dx.doi.org/10.2147/CIA.S57580 24596458
80 Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390-7. PMID: 18662214. https://doi.org/10.1111/j.1532-5415.2008.01803.x 18662214
81 Hogan DB, MacDonald FA, Betts J, . A randomized controlled trial of a communitybased consultation service to prevent falls. CMAJ. 2001;165(5):537-43. PMID: 11563205.11563205
82 Imhof L, Naef R, Wallhagen MI, . Effects of an advanced practice nurse in-home health consultation program for community-dwelling persons aged 80 and older. J Am Geriatr Soc. 2012;60(12):2223-31. PMID: 23194103. http://dx.doi.org/10.1111/jgs.12026 23194103
83 Lightbody E, Watkins C, Leathley M, . Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203-10. PMID: 12006310.12006310
84 Logan PA, Coupland CA, Gladman JR, . Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. PMID: 20460331. http://dx.doi.org/10.1136/bmj.c2102 20460331
85 Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296-304. PMID: 16078954. https://doi.org/10.1111/j.15325415.2005.53425.x 16078954
86 Moller UO, Kristensson J, Midlov P, . Effects of a one-year home-based case management intervention on falls in older people: a randomized controlled trial. J Aging Phys Act. 2014;22(4):457-64. PMID: 24152667. http://dx.doi.org/10.1123/japa.20130101 24152667
87 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104-7. PMID: 11556409.11556409
88 Palvanen M, Kannus P, Piirtola M, . Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: a randomised controlled trial. Injury. 2014;45(1):265-71. PMID: 23579066. http://dx.doi.org/10.1016/j.injury.2013.03.010 23579066
89 Perula LA, Varas-Fabra F, Rodriguez V, . Effectiveness of a multifactorial intervention program to reduce falls incidence among community-living older adults: a randomized controlled trial. Arch Phys Med Rehabil. 2012;93(10):1677-84. PMID: 22609117. http://dx.doi.org/10.1016/j.apmr.2012.03.035 22609117
90 Russell MA, Hill KD, Day LM, . A randomized controlled trial of a multifactorial falls prevention intervention for older fallers presenting to emergency departments. J Am Geriatr Soc. 2010;58(12):2265-74. PMID: 21143436. http://dx.doi.org/10.1111/j.15325415.2010.03191.x 21143436
91 Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612-19. PMID: 19392952. https://doi.org/10.1111/j.1532-5415.2009.02176.x 19392952
92 Spice CL, Morotti W, George S, . The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33-40. PMID: 18829689. https://doi.org/10.1093/ageing/afn192s 18829689
93 Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821-7. PMID: 8078528. https://doi.org/10.1056/NEJM199409293311301 8078528
94 van Haastregt JC, Diederiks JP, van Rossum E, . Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994-8. PMID: 11039967.11039967
95 Vind AB, Andersen HE, Pedersen KD, . An outpatient multifactorial falls prevention intervention does not reduce falls in high-risk elderly Danes. J Am Geriatr Soc. 2009;57(6):971-7. PMID: 19507291.19507291
96 Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800-6. PMID: 7977921.7977921
97 Peeters GM, de Vries OJ, Elders PJ, . Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. PMID: 17605771. https://doi.org/10.1186/1471-2318-7-15 17605771
98 Cameron ID, Fairhall N, Langron C, . A multifactorial interdisciplinary intervention reduces frailty in older people: randomized trial. BMC Med. 2013;11:65. PMID: 23497404. https://doi.org/10.1186/1741-7015-11-65 23497404
99 Fairhall N, Aggar C, Kurrle SE, . Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. PMID: 18851754. https://doi.org/10.1186/1471-2318-8-27 18851754
100 Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809-13. PMID: 19958918. https://doi.org/10.1016/j.puhe.2009.10.018 19958918
101 Vind AB, Andersen HE, Pedersen KD, . The Effect of a program of Multifactorial Fall Prevention on Health Related Quality of Life, Functional Ability, Fear of Falling and Psychological Well-being. A Randomized Controlled Trial. Aging Clin Exp Res. 2010;22(3):249-54. PMID: 19934621. https://doi.org/10.3275/6628 19934621
102 Peri K, Kerse N, Robinson E, . Does functionally based activity make a difference to health status and mobility? A randomised controlled trial in residential care facilities (The Promoting Independent Living Study; PILS). Age Ageing. 2008;37(1):57-63. PMID: 17965045. https://doi.org/10.1093/ageing/afm135 17965045
103 Dyer CA, Taylor GJ, Reed M, . Falls prevention in residential care homes: a randomised controlled trial. Age Ageing. 2004;33(6):596-602. PMID: 15381507. https://doi.org/10.1093/ageing/afh204 15381507
104 Coleman EA, Grothaus LC, Sandhu N, . Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47(7):775-83. PMID: 10404919.10404919
105 Buchner DM, Cress ME, de Lateur BJ, . The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218-M24. PMID: 9224433.9224433
106 Robertson MC, Devlin N, Gardner MM, . Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322(7288):697-701. PMID: 11264206.11264206
107 Luukinen H, Lehtola S, Jokelainen J, . Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44(3):265-71. PMID: 17174387. https://doi.org/10.1016/j.ypmed.2006.09.011 17174387
108 Logghe IH, Zeeuwe PE, Verhagen AP, . Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57(1):70-5. PMID: 19054193. https://doi.org/10.1111/j.15325415.2008.02064.x 19054193
109 Barnett A, Smith B, Lord SR, . Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32(4):407-14. PMID: 12851185.12851185
110 Campbell AJ, Robertson MC, Gardner MM, . Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315(7115):1065-9. PMID: 9366737.9366737
111 Morgan RO, Virnig BA, Duque M, . Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59(10):1062-7. PMID: 15528779.15528779
112 Voukelatos A, Cumming RG, Lord SR, . A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185-91. PMID: 17661956. https://doi.org/10.1111/j.15325415.2007.01244.x 17661956
113 Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703-11. PMID: 25799402. http://dx.doi.org/10.1001/jamainternmed.2015.0225 25799402
114 Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784-9. PMID: 25990940. http://dx.doi.org/10.1093/ageing/afv064 25990940
115 El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510. http://dx.doi.org/10.1136/bmj.h3830 26201510
116 Voukelatos A, Merom D, Sherrington C, . The impact of a home-based walking programme on falls in older people: the Easy Steps randomised controlled trial. Age Ageing. 2015;44(3):377-83. PMID: 25572426. http://dx.doi.org/10.1093/ageing/afu186 25572426
117 Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702. http://dx.doi.org/10.1371/journal.pone.0104412 25180702
118 Gawler S, Skelton DA, Dinan-Young S, . Reducing falls among older people in general practice: The ProAct65+ exercise intervention trial. Arch Gerontol Geriatr. 2016;67:46-54. PMID: 27420150. https://doi.org/10.1016/j.archger.2016.06.019 27420150
119 Kovacs E, Prokai L, Meszaros L, . Adapted physical activity is beneficial on balance, functional mobility, quality of life and fall risk in community-dwelling older women: a randomized single-blinded controlled trial. Eur J Phys Rehabil Med. 2013;49(3):301-10. PMID: 23486300.23486300
120 Freiberger E, Haberle L, Spirduso WW, . Long-term effects of three multicomponent exercise interventions on physical performance and fall-related psychological outcomes in community-dwelling older adults: a randomized controlled trial. J Am Geriatr Soc. 2012;60(3):437-46. PMID: 22324753. http://dx.doi.org/10.1111/j.15325415.2011.03859.x 22324753
121 Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525-33. PMID: 21098340. http://dx.doi.org/10.1001/archinternmed.2010.446 21098340
122 Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728-33. PMID: 20817936. http://dx.doi.org/10.1093/ageing/afq109 20817936
123 Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634. https://doi.org/10.1016/j.amjmed.2015.06.017 26159634
124 Kamide N, Shiba Y, Shibata H. Effects on balance, falls, and bone mineral density of a home-based exercise program without home visits in community-dwelling elderly women: a randomized controlled trial. J Physiol Anthropol. 2009;28(3):115-22. PMID: 19483372.19483372
125 Gill TM, Pahor M, Guralnik JM, . Effect of structured physical activity on prevention of serious fall injuries in adults aged 70-89: randomized clinical trial (LIFE Study). BMJ. 2016;352:i245. PMID: 26842425. http://dx.doi.org/10.1136/bmj.i245 26842425
126 Buchner DM, Cress ME, Wagner EH, . The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41(3):321-5. PMID: 8440857.8440857
127 Buchner DM, Hornbrook MC, Kutner NG, . Development of the common data base for the FICSIT trials. J Am Geriatr Soc. 1993;41(3):297-308. PMID: 8440854.8440854
128 Dargent-Molina P, El Khoury F, Cassou B. The ‘Ossebo’ intervention for the prevention of injurious falls in elderly women: background and design. Glob Health Promot. 2013;20(2 Suppl):88-93. PMID: 23678502. http://dx.doi.org/10.1177/1757975913483341 23678502
129 Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
130 Fielding RA, Rejeski WJ, Blair S, . The Lifestyle Interventions and Independence for Elders Study: design and methods. J Gerontol A Biol Sci Med Sci. 2011;66(11):1226-37. PMID: 21825283. https://doi.org/10.1093/gerona/glr123 21825283
131 Iliffe S, Kendrick D, Morris R, . Multicentre cluster randomised trial comparing a community group exercise programme and home-based exercise with usual care for people aged 65 years and over in primary care. Health Technol Assess. 2014;18(49):vii-xxvii, 1-105. PMID: 25098959. http://dx.doi.org/10.3310/hta18490 25098959
132 Iliffe S, Kendrick D, Morris R, . Multi-centre cluster randomised trial comparing a community group exercise programme with home based exercise with usual care for people aged 65 and over in primary care: protocol of the ProAct 65+ trial. Trials. 2010;11:6. PMID: 20082696. http://dx.doi.org/10.1186/1745-6215-11-6 20082696
133 Karinkanta S, Nupponen R, Heinonen A, . Effects of exercise on health-related quality of life and fear of falling in home-dwelling older women. J Aging Phys Act. 2012;20(2):198-14. PMID: 22472580.22472580
134 Logghe IH, Verhagen AP, Rademaker AC, . Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357-62. PMID: 20965096. http://dx.doi.org/10.1016/j.archger.2010.05.013 20965096
135 Patil R, Kolu P, Raitanen J, . Cost-effectiveness of vitamin D supplementation and exercise in preventing injurious falls among older home-dwelling women: findings from an RCT. Osteoporos Int. 2015;27(1):193-201. PMID: 26205890. https://doi.org/10.1007/s00198-015-3240-9 26205890
136 Stevens Z, Carpenter H, Gawler S, . Lessons learnt during a complex, multicentre cluster randomised controlled trial: the ProAct65+ trial. Trials. 2013;14:192. PMID: 23815878. http://dx.doi.org/10.1186/1745-6215-14-192 23815878
137 Tinetti ME, Baker DI, Garrett PA, . Yale FICSIT: risk factor abatement strategy for fall prevention. J Am Geriatr Soc. 1993;41(3):315-20. PMID: 8440856.8440856
138 Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872. http://dx.doi.org/10.1186/1471-2318-12-12 22448872
139 Voukelatos A, Merom D, Rissel C, . The effect of walking on falls in older people: the ’Easy Steps to Health’ randomized controlled trial study protocol. BMC Public Health. 2011;11:888. PMID: 22115340. http://dx.doi.org/10.1186/1471-2458-11-888 22115340
140 Ashburn A, Fazakarley L, Ballinger C, . A randomised controlled trial of a home based exercise programme to reduce the risk of falling among people with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 2007;78(7):678-84. PMID: 17119004. https://doi.org/10.1136/jnnp.2006.099333 17119004
141 Campbell AJ, Robertson MC, La Grow SJ, . Randomised controlled trial of prevention of falls in people aged > or =75 with severe visual impairment: the VIP trial. BMJ. 2005;331(7520):817. PMID: 16183652.16183652
142 Green J, Forster A, Bogle S, . Physiotherapy for patients with mobility problems more than 1 year after stroke: a randomised controlled trial. Lancet. 2002;359(9302):199-203. PMID: 11812553. https://doi.org/10.1016/S0140-6736(02)07443-3 11812553
143 Li F, Harmer P, Fisher KJ, . Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60(2):187-94. PMID: 15814861.15814861
144 Kronhed AG, Hallberg I, dkvist L, . Effect of training on health-related quality of life, pain and falls in osteoporotic women. Adv Physiother. 2009;11(3):154-65.
145 Wolf SL, Barnhart HX, Kutner NG, . Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies of Intervention Techniques. J Am Geriatr Soc. 1996;44(5):489-97. PMID: 8617895.8617895
146 Rubenstein LZ, Josephson KR, Trueblood PR, . Effects of a group exercise program on strength, mobility, and falls among fall-prone elderly men. J Gerontol A Biol Sci Med Sci. 2000;55(6):M317-M21. PMID: 10843351.10843351
147 Lord SR, Ward JA, Williams P, . The effect of a 12-month exercise trial on balance, strength, and falls in older women: a randomized controlled trial. J Am Geriatr Soc. 1995;43(11):1198-206. PMID: 7594152.7594152
148 Dukas L, Bischoff HA, Lindpaintner LS, . Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 2004;52(2):230-6. PMID: 14728632.14728632
149 Gallagher JC, Fowler SE, Detter JR, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86(8):3618-28. PMID: 11502787. https://doi.org/10.1210/jcem.86.8.7703 11502787
150 Porthouse J, Cockayne S, King C, . Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330(7498):1003. PMID: 15860827. https://doi.org/10.1136/bmj.330.7498.1003 15860827
151 Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 2006;166(4):424-30. PMID: 16505262. https://doi.org/10.1001/archinte.166.4.424 16505262
152 Glendenning P, Zhu K, Inderjeeth C, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012;27(1):170-6. PMID: 21956713. http://dx.doi.org/10.1002/jbmr.524 21956713
153 Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 2010;303(18):1815-22. PMID: 20460620. http://dx.doi.org/10.1001/jama.2010.594 20460620
154 Dawson-Hughes B, Harris SS, Krall EA, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 1997;337(10):670-6. PMID: 9278463. https://doi.org/10.1056/NEJM199709043371003 9278463
155 Gallagher JC, Rapuri PB, Smith LM. An age-related decrease in creatinine clearance is associated with an increase in number of falls in untreated women but not in women receiving calcitriol treatment. J Clin Endocrinol Metab. 2007;92(1):51-8. PMID: 17032712. https://dx.doi.org/10.1210/jc.2006-1153 17032712
156 Dhesi JK, Jackson SH, Bearne LM, . Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 2004;33(6):589-95. PMID: 15501836. https://doi.org/10.1093/ageing/afh209 15501836
157 Pfeifer M, Begerow B, Minne HW, . Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15(6):1113-8. PMID: 10841179. https://doi.org/10.1359/jbmr.2000.15.6.1113 10841179
158 Pfeifer M, Begerow B, Minne HW, . Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20(2):315-22. PMID: 18629569. https://doi.org/10.1007/s00198-008-0662-7 18629569
159 Prince RL, Austin N, Devine A, . Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008;168(1):103-8. PMID: 18195202. https://doi.org/10.1001/archinternmed.2007.31 18195202
160 Karkkainen MK, Tuppurainen M, Salovaara K, . Does daily vitamin D 800IU and calcium 1000mg supplementation decrease the risk of falling in ambulatory women aged 65-71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010. PMID: 20060665. https://doi.org/10.1016/j.maturitas.2009.12.018 20060665
161 Stevens M, Holman CD, Bennett N, . Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49(11):1448-55. PMID: 11890582.11890582
162 Pighills AC, Torgerson DJ, Sheldon TA, . Environmental assessment and modification to prevent falls in older people.[Erratum appears in J Am Geriatr Soc. 2011 Apr;59(4):776]. J Am Geriatr Soc. 2011;59(1):26-33. PMID: 21226674. http://dx.doi.org/10.1111/j.1532-5415.2010.03221.x 21226674
163 Blalock SJ, Casteel C, Roth MT, . Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother. 2010;8(5):428-40. PMID: 21335296. http://dx.doi.org/10.1016/j.amjopharm.2010.09.002 21335296
164 Mott DA, Martin B, Breslow R, . Impact of a medication therapy management intervention targeting medications associated with falling: Results of a pilot study. J Am Pharm Assoc. 2016;56(1):22-8. PMID: 26802916. http://dx.doi.org/10.1016/j.japh.2015.11.001 26802916
165 Mott D, Martin B, Breslow R, . The development of a community-based, pharmacistprovided falls prevention MTM intervention for older adults: Relationship building, methods, and rationale. Inov Pharm. 2014;5(1):140. PMID: 25309809.25309809
166 Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in communitydwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020-8. PMID: 19793161. https://doi.org/10.1111/j.15325415.2009.02489.x 19793161
167 Dorresteijn TA, Zijlstra GA, Ambergen AW, . Effectiveness of a home-based cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial.[Erratum appears in BMC Geriatr. 2016;16:108; PMID: 27220990. BMC Geriatr. 2016;16:2. PMID: 26739339. http://dx.doi.org/10.1186/s12877-015-0177-y 27220990
168 Dorresteijn TA, Rixt Zijlstra GA, Van Haastregt JC, . Feasibility of a nurse-led inhome cognitive behavioral program to manage concerns about falls in frail older people: a process evaluation. Res Nurs Health. 2013;36(3):257-70. PMID: 23533013. http://dx.doi.org/10.1002/nur.21534 23533013
169 Dorresteijn TA, Zijlstra GA, Delbaere K, . Evaluating an in-home multicomponent cognitive behavioural programme to manage concerns about falls and associated activity avoidance in frail community-dwelling older people: Design of a randomised control trial [NCT01358032]. BMC Health Serv Res. 2011;11:228. PMID: 21933436. http://dx.doi.org/10.1186/1472-6963-11-228 21933436
170 Kempen GI, Oude Wesselink SF, van Haastregt JC, . Long-term effect on mortality of a multicomponent cognitive behavioural group intervention to reduce fear of falling in older adults: a randomised controlled trial. Age Ageing. 2011;40(4):519-23. PMID: 21551460. http://dx.doi.org/10.1093/ageing/afr041 21551460
171 Clemson L, Cumming RG, Kendig H, . The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487-94. PMID: 15341550. https://doi.org/10.1111/j.15325415.2004.52411.x 15341550
172 Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420-27. PMID: 18166695.18166695
173 Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365-72. PMID: 27504699. http://dx.doi.org/10.3238/arztebl.2016.0365 27504699
174 Blank WA, Freiberger E, Siegrist M, . An interdisciplinary intervention to prevent falls in community-dwelling elderly persons: protocol of a cluster-randomized trial [PreFalls]. BMC Geriatr. 2011;11:7. PMID: 21329525. http://dx.doi.org/10.1186/14712318-11-7 21414185
175 Thomas S, Mackintosh S, Halbert J. Does the ’Otago exercise programme’ reduce mortality and falls in older adults?: a systematic review and meta-analysis. Age Ageing. 2010;39(6):681-7. PMID: 20817938. http://dx.doi.org/10.1093/ageing/afq102 20817938
176 Bolland MJ, Grey A, Reid IR. Differences in overlapping meta-analyses of vitamin D supplements and falls. J Clin Endocrinol Metab. 2014;99(11):4265-72. PMID: 25093621. https://doi.org/10.1210/jc.2014-2562 25093621
177 Stubbs B, Brefka S, Denkinger MD. What Works to Prevent Falls in CommunityDwelling Older Adults? Umbrella Review of Meta-analyses of Randomized Controlled Trials. Physical Therapy. 2015;95(8):1095-110. PMID: 25655877. http://dx.doi.org/10.2522/ptj.20140461 25655877
178 Murad MH, Elamin KB, Abu Elnour NO, . Clinical review: The effect of vitamin D on falls: a systematic review and meta-analysis. J Clin Endocrinol Metab. 2011;96(10):2997-3006. PMID: 21795448. http://dx.doi.org/10.1210/jc.2011-1193 21795448
179 Kalyani RR, Stein B, Valiyil R, . Vitamin D treatment for the prevention of falls in older adults: systematic review and meta-analysis. J Am Geriatr Soc. 2010;58(7):1299-310. PMID: 20579169. http://dx.doi.org/10.1111/j.1532-5415.2010.02949.x 20579169
180 Gallagher JC. Vitamin D and falls - the dosage conundrum. Nat Rev Endocrinol. 2016. PMID: 27494391. https://doi.org/10.1038/nrendo.2016.123 27494391
181 Bolland M. Vitamin D supplements do not prevent falls. BMJ. 2016;353:i3005. PMID: None. http://dx.doi.org/10.1136/bmj.i3005
182 Bolland MJ, Grey A, Gamble GD, . Vitamin D supplementation and falls: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014;2(7):573-80. PMID: 24768505. http://dx.doi.org/10.1016/S2213-8587(14)70068-3 24768505
183 El-Khoury F, Cassou B, Charles MA, . The effect of fall prevention exercise programmes on fall induced injuries in community dwelling older adults: systematic review and meta-analysis of randomised controlled trials. BMJ. 2013;347:f6234. PMID: 24169944. http://dx.doi.org/10.1136/bmj.f6234 24169944
184 Choi M, Hector M. Effectiveness of intervention programs in preventing falls: a systematic review of recent 10 years and meta-analysis. J Am Med Dir Assoc. 2012;13(2):188.e13-21. PMID: 21680249. http://dx.doi.org/10.1016/j.jamda.2011.04.022 21680249
185 Petridou E, Manti E, Ntinapogias A, . What works better for community-dwelling older people at risk to fall?: a meta-analysis of multifactorial versus physical exercisealone interventions. J Aging Health. 2009;21(5):713-29. PMID: 19494361.19494361
186 Woo J, Hong A, Lau E, . A randomised controlled trial of Tai Chi and resistance exercise on bone health, muscle strength and balance in community-living elderly people. Age Ageing. 2007;36(3):262-8. PMID: 17356003. https://dx.doi.org/10.1093/ageing/afm005 17356003
187 Huang HC, Liu CY, Huang YT, . Community-based interventions to reduce falls among older adults in Taiwan - long time follow-up randomised controlled study. J Clin Nurs. 2010;19(7-8):959-68. PMID: 20492040. http://dx.doi.org/10.1111/j.13652702.2009.02834.x 20492040
188 Shigematsu R, Okura T, Nakagaichi M, . Square-stepping exercise and fall risk factors in older adults: a single-blind, randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(1):76-82. PMID: 18245764.18245764
189 Lin JS, Whitlock EP, Eckstrom E, . Challenges in Synthesizing and Interpreting the Evidence From a Systematic Review of Multifactorial Interventions to Prevent Functional Decline in Older Adults. Rockville, MD: Agency for Healthcare Research and Quality; 2012.
190 Lin JS, Whitlock EP, Eckstrom E, . Challenges in synthesizing and interpreting the evidence from a systematic review of multifactorial interventions to prevent functional decline in older adults. J Am Geriatr Soc. 2012;60(11):2157-66. PMID: 23072282. https://doi.org/10.1111/j.1532-5415.2012.04214.x 23072282
191 Gates S, Smith L, Fisher J, . Systematic review of accuracy of screening instruments for predicting fall risk among independently living older adults. J Rehabil Res Dev. 2008;45(8):1105-16. PMID: 19235113.19235113
192 Lusardi MM, Fritz S, Middleton A, . Determining Risk of Future Falls in Community-Dwelling Older Adults: A Systematic Review and Meta-analysis Using Posttest Probability. J Geriatr Phys Ther. 2016;17:17. PMID: 27537070. http://dx.doi.org/10.1519/JPT.0000000000000099 27537070
193 Rikli R, Jones C. Development and validation of criterion-referenced clinically relevant fitness standards for maintaining physical independence in later years. Gerontologist. 2013;52(2):255-67. PMID: 22613940.22613940
194 Dawson-Hughes B, Harris SS. High-dose vitamin D supplementation: too much of a good thing? JAMA. 2010;303(18):1861-2. PMID: 20460627. http://dx.doi.org/10.1001/jama.2010.598 20460627
195 Appel L, Johns Hopkins University. Study To Understand Fall Reduction and Vitamin D in You (STURDY). In: ClinicalTrials.gov. https://clinicaltrials.gov/ct2/show/NCT02166333. Accessed: Sep 28, 2016.
196 LeBlanc ES, Zakher B, Daeges M, . Screening for vitamin D deficiency: a systematic review for the U.S. Preventive Services Task Force. Annals of internal medicine. 2015;162(2):109-22. PMID: 25419719. http://dx.doi.org/10.7326/M14-1659 25419719
197 Newberry S, Chung M, Shekelle P, . Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update). Evidence Report/Technology Assessment No. 217. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
198 Fortmann SP, Burda BU, Senger CA, . Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2013.
199 Latham N, Brigham and Women’s Hospital. Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE). In: ClinicalTrials.gov. https://clinicaltrials.gov/ct2/show/NCT02475850. Accessed: Sep 28, 2016.
200 Nyman SR, Victor CR. Older people’s participation in and engagement with falls prevention interventions in community settings: an augment to the Cochrane systematic review. Age Ageing. 2012;41(1):16-23. PMID: 21875865. http://dx.doi.org/10.1093/ageing/afr103 21875865
201 Dickinson A, Horton K, Machen I, . The role of health professionals in promoting the uptake of fall prevention interventions: a qualitative study of older people’s views. Age Ageing. 2011;40(6):724-30. PMID: 22016345. http://dx.doi.org/10.1093/ageing/afr111 22016345
202 Jones TS, Ghosh TS, Horn K, . Primary care physicians perceptions and practices regarding fall prevention in adult’s 65 years and over. Accid Anal Prev. 2011;43(5):1605-9. PMID: 21658485. http://dx.doi.org/10.1016/j.aap.2011.03.013 21658485
203 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. Stay Independent. In: Centers for Disease Control and Prevention 2014.
204 Tinetti M. Performance-oriented assessment of mobility problems in elderly patients. J Am Geriatr Soc. 1986;34(2):119-26. PMID: 3944402.3944402
205 Close J, Lord S. Fall assessment in older people. BMJ. 2011;343(d5153). PMID: 21917828.21917828
206 National Institute for Health and Care Excellence. Falls in older people: assessment after a fall and preventing further falls. Quality standard [QS86]. UK: National Institute for Health and Care Excellence; 2015.
207 Preventive activities in older age. In: Guidelines for preventive activities in general practice, 8th edition. East Melbourne, Australia: Royal Australian College of General Practitioners; 2012.
208 Panel on Prevention of Falls in Older Persons, American Geriatrics Society, British Geriatrics Society. Summary of the Updated American Geriatrics Society/British Geriatrics Society clinical practice guideline for prevention of falls in older persons. J Am Geriatr Soc. 2011;59(1):148-57. PMID: 21226685.21226685
209 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. PMID: 11306229.11418253