# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, and Tracy Wolff, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the Centers for Disease Control and Prevention and the National Institutes of Health for providing federal partner review of the draft report; Elizabeth Eckstrom, MD, MPH, School of Medicine, Oregon Health & Science University, J. Christopher Gallagher, MD, Division of Endocrinology, Creighton University School of Medicine, David Ganz, MD, PhD, U.S. Department of Veterans Affairs Greater Los Angeles Healthcare System, Geriatric Research, Education, and Clinical Center and David Geffen School of Medicine, University of California, Los Angeles, Thomas Gill, MD, Yale School of Medicine, Adler Geriatric Center, Elizabeth Phelan, MD, MS, Division of Gerontology and Geriatric Medicine, Department of Medicine, University of Washington, and David Reuben, MD, David Geffen School of Medicine, University of California, Los Angeles, who provided expert review of the draft report; Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.