# 4 Discussion

## Overall Summary of the Evidence

In this review, we identified 62 trials (n=35,058) examining seven types of multifactorial, single, or multiple interventions designed to reduce falls, people experiencing a fall, and/or fall-related injuries in average and high-risk older adults. We analyzed 11 fall-related outcomes; the most commonly reported outcomes were falls and people experiencing a fall. Thirty-one of the trials were powered to detect clinically meaningful differences in falls or people experiencing a fall. The largest bodies of literature within this review evaluated multifactorial and exercise interventions with 26 and 21 trials, respectively. Our findings suggest that there is a fall-related benefit (i.e., reduction in falls and/or people experiencing a fall) associated with both multifactorial and exercise interventions, but evidence is most consistent across multiple fall-related outcomes for the exercise trials. For all other interventions, we were unable to make firm conclusions about their effects on included outcomes due to insufficient data or mixed results. A summary of each intervention type appears below and in Tables 56 and 57. An evidence map provides a visual synopsis of our main findings (Figure 22).

Figure 22 Evidence Map of the Largest Intervention Types and Main Outcomes

Note: Circle size corresponds to number of participants analyzed

Abbreviations: En = environment; Ex = exercise; MF = multifactorial; Vit = vitamin D

Figure 22 displays an evidence map of four intervention types: multifactorial, exercise, vitamin D, and environment. A beneficial intervention effect is indicated for multifactorial and for exercise interventions on falls and for exercise on fallers, injurious falls, and injurious fallers. An unclear intervention effect is indicated for vitamin D and environment on falls; for multifactorial, vitamin D, and environment on fallers and injurious fallers; and multifactorial interventions on injurious fallers.

Table 56 Total Number of Included Studies and Participants Analyzed by Intervention Type and Outcome

Intervention Type | Falls | People Experiencing a Fall | Injurious Falls | People Experiencing an Injurious Fall | Mortality | ADL | IADL | QOL | People Hospitalized | People Transitioning to Institutional Care | Harms
Multifactorial k=26 | k=17 n=9,737 | k=24 n=12,490 | k=9 n=4,306 | k=16 n=9,445 | k=23 n=9,721 | k=7 n=2,106 | k=4 n=1,102 | k=4 n=1,104 | k=4 n=2,134 | k=7 n=2,143 | k=4 n=1,466
Exercise k=21 | k=14 n=4,663 | k=15 n=4,926 | k=10 n=4,622 | k=5 n=2,776 | k=11 n=4,263 | k=0 n=0 | k=3 n=363 | k=3 n=1,179 | k=1 n=98 | k=2 n=206 | k=8 n=4,107
Vitamin D k=7 | k=5 n=3,496 | k=6 n=6,519 | k=2 n=2,460 | k=0 n=0 | k=6 n=7,084 | k=0 n=0 | k=0 n=0 | k=1 n=3,314 | k=0 n=0 | k=0 n=0 | k=5 n=3,955
Environment k=3 | k=3 n=2,175 | k=2 n=438 | k=1 n=273 | k=0 n=0 | k=0 n=0 | k=1 n=165 | k=0 n=0 | k=1 n=165 | k=0 n=0 | k=0 n=0 | k=0 n=0
Medication Management k=2 | k=1 n=186 | k=2 n=266 | k=1 n=186 | k=0 n=0 | k=1 n=186 | k=0 n=0 | k=0 n=0 | k=0 n=0 | k=0 n=0 | k=0 n=0 | k=0 n=0
Psychological k=2 | k=2 n=886 | k=2 n=886 | k=2 n=886 | k=0 n=0 | k=2 n=886 | k=0 n=0 | k=1 n=540 | k=0 n=0 | k=0 n=0 | k=0 n=0 | k=1 n=540
Multiple k=6 | k=6 n=1,770 | k=4 n=1,413 | k=5 n=1,460 | k=1 n=378 | k=3 n=1,035 | k=0 n=0 | k=0 n=0 | k=1 n=258 | k=0 n=0 | k=0 n=0 | k=3 n=810

Abbreviations: ADL = activities of daily living; IADL = instrumental activities of daily living; k=number of studies; n=number of participants; QOL = quality of living

Table 57 Summary of Evidence

Intervention Type No. of studies (k), no. of participants randomized (n) | Outcome | No. of RCTs (k), no. of obs. (n) | Summ ary of Findings by Outcome | Consistency/Precision | Reporting Bias | EPC Assessment of Strength of Evidence | Study Quality | Body of Evidence Limitations | Applicability
KQ1
Multifactorial k=26 (11 new studies), n=15,506 | Falls | k=17, n=9,737 | Pooled reduction in falls (IRR, 0.79 [95% CI, 0.68 to 0.91]; I^2^=87.2%) with substantial heterogeneity. Exploratory analysis suggests that trials recruiting from emergency setting report greater benefit (than trials recruiting from clinic or a combination of clinic and emergency setting) | Inconsistent, imprecise | Undetected | Low | Good: 7 Fair: 19 | Heterogeneous populations as reflected by large variation in CG fall rate and percent fallers. Heterogeneous group of interventions. Cannot make conclusions about which components associated with greater falls-related benefit. Most studies report and designed to be powered for either falls or fallers outcomes.. | Applicable to community-dwelling older adults. ¾ of trials in ’high risk’ older adults where high risk is variably defined but often includes history of fall Difficult to identify set of effective components for implementation purposes
Multifactorial k=26 (11 new studies), n=15,506 | People experiencing a fall | k=24, n=12,490 | No pooled effect (RR, 0.95 [95% CI, 0.89 to 1.01]; I^2^=56.4%) | Reasonably consistent, imprecise | Undetected | Moderate | Good: 7 Fair: 19
Multifactorial k=26 (11 new studies), n=15,506 | Injuries | Injurious falls k=9, n=4,306 People experiencing an injurious fall: k=16 n=9,445 | No statistically significant difference seen in nearly all studies for number of injurious falls. Pooled estimate of people experiencing an injurious fall shows no effect (RR, 0.94 [95% CI, 0.85 to 1.03]; I^2^=34.3%) | Reasonably consistent, imprecise | Undetected | Low | Good: 7 Fair: 19
Multifactorial k=26 (11 new studies), n=15,506 | Mortality | k=23, n=9,721 | No statistically significant pooled effect (RR, 0.96 [95% CI, 0.79 to 1.17];I^2^=0%) | Inconsistent, imprecise | Undetected | Low | Good: 7 Fair: 19
Exercise k=21 (12 new) n=7,297 | Falls | k=14 n=4, 663 | Nonsignificant reduction in falls (IRR, 0.87 [95% CI, 0.75 to 1.00]; I^2^=57.3%) | Inconsistent, imprecise | Undetected | Low | Good: 5 Fair: 16 | Relatively small trials and less than half powered for falls or fallers; heterogeneous interventions; small to moderate potential for reporting bias | Community-dwelling older adults Average to high risk for falling (55% of RCTs recruited “high risk”, often includes history of falls or physical impairment) Difficult to identify set of effective components fo implementation purposes
Exercise k=21 (12 new) n=7,297 | People experiencing a fall | k=15, n=4,926 | Pooled reduction in people experiencing a fall (RR, 0.89 [95% CI, 0.81 to 0.97]; I^2^=43.9%) | Reasonably consistent, imprecise | Undetected | Low to Moderate | Good: 5 Fair: 16 | Relatively small trials and less than half powered for falls or fallers; heterogeneous interventions; small to moderate potential for reporting bias
Exercise k=21 (12 new) n=7,297 | Injuries | Injurious falls: k=10, n=4,622 People experiencing an injurious fall: k=5 n=2,776 | Pooled reduction in injurious falls (IRR, 0.81 [95% CI, 0.73 to 0.90] I^2^=0.0%). Trend towards reduction in people experiencing an injurious fall in individual trials with IRR ranging from 0.61 to 0.90 but not statistically significant. | Reasonably consistent, imprecise | Undetected | Low to Moderate | Good: 5 Fair: 16 | Relatively small trials and less than half powered for falls or fallers; heterogeneous interventions; small to moderate potential for reporting bias
Exercise k=21 (12 new) n=7,297 | Mortality | k=11 n=4,263 | No statistically significant pooled effect (RR, 0.93 [95% CI, 0.71 to 1.22]; I^2^=0%) | Inconsistent, imprecise | Undetected | Low | Good: 5 Fair: 16 | Relatively small trials and less than half powered for falls or fallers; heterogeneous interventions; small to moderate potential for reporting bias
Vitamin D K= 7 (3 new) n=7,531 | Falls | k=5, n=3,529 | Mxed results: 1 trial of calcitriol showed stat sig reduction in falls (IRR, 0.63 [95% CI, 0.47 to 0.84]) and 1 trial of 1-hydroxycholecalciferol showed non stat sig reduction in falls (0.87 [0.59-1.30]). The high dose cholecalciferol (500,000 IU annually) showed increase in falls in vitamin D group at 36 months (IRR 1.16 [1.03-1.31]) while 2 other trials of cholecalciferol 700IU and 800IU daily showed nonstat sig point estimates just above 1 (IRRs 1.08 and 1.12). Pooled results show overall no effect on falls (IRR, 0.97 [95% CI, 0.79 to 1.20]; I^2^=75.8%) | Inconsistent, imprecise | Undetected | Low | Fair: 3 Good: 4 | Heterogeneity in formulations, dosing schedules, control group fall rates (reflecting heterogeneous baseline risk) | Applicable to unselected older populations of US community-dwelling adults
Vitamin D K= 7 (3 new) n=7,531 | People experiencing a fall | k=6, n=6,519 | Mxed results: 1 trial calcitriol showed stat sig reduction in fallers (RR 0.77 [0.61-0.98]) while 1 trial of 1-hydroxycholecalciferol showed nonstat sig reduction (0.84 [0.58-1.22]). 2 trials of cholecalciferol 800IU daily and 150,000IU every 3 months with RRs near 1 (1.01 and 1.08). The high dose vitamin D 500,000IU annually showed stat sig increase in fallers (RR 1.08 [1.03-1.14]). Pooled analysis shows no effect on people experiencing a fall (RR, 0.97 [95% CI, 0.88 to 1.08]; I^2^= 60.3%) | Inconsistent, imprecise | Undetected | Low | Fair: 3 Good: 4 | Heterogeneity in formulations, dosing schedules, control group fall rates (reflecting heterogeneous baseline risk) | Applicable to unselected older populations of US community-dwelling adults
Vitamin D K= 7 (3 new) n=7,531 | Injuries | Injurious falls: k=2, n=2,460 People experiencing an injurious fall: k=0 | Mxed results: The annual high dose (500,000 IU) vitamin D showed increase in injurious falls in vitamin D group at 36 months (IRR, 1.15 [95% CI, 1.02 to 1.29]) while another trial (800IU daily) showed no difference at 24 months (IRR, 0.84 [95% CI, 0.45 to 1.57]). | Inconsistent, imprecise | Undetected | Low | Fair: 3 Good: 4 | Heterogeneity in formulations, dosing schedules, control group fall rates (reflecting heterogeneous baseline risk) | Applicable to unselected older populations of US community-dwelling adults
Vitamin D K= 7 (3 new) n=7,531 | Mortality | k=6, n=7,084 | No statistically significant difference in mortality (RR, 1.08 [95% CI, 0.83 to 1.40]; I2=0%) | Inconsistent, imprecise | Undetecte d | Low | Fair: 3 Good: 4 | Heterogeneity in formulations, dosing schedules, control group fall rates (reflecting heterogeneous baseline risk) | Applicable to unselected older populations of US community-dwelling adults
Environment K=3 (2 new) N=2,175 | Falls | k=3, n=2,175 | Mxed results: One trial reported a significant reduction in falls for the IG versus CG (IRR, 0.54 [95% CI, 0.36 to 0.83]). The other two trials showed no effect (IRRs 0.98 and 1.02). | Inconsistent and imprecise | Undetected | Low | Good: 1 Fair: 2 | Small group of studies showing no consistent effect on falls or fallers. | Conducted outside the US; one trial had a social services program conduct repairs that would likely not be available in the US
Environment K=3 (2 new) N=2,175 | People experiencing a fall | k=2, n=438 | No statistically significant difference in fallers in any trial at 12 and 18 months (RR/OR ranging from 0.83-0.93) | Reasonably consistent but only 2 trials and imprecise | Undetected | Low | Good: 1 Fair: 2 | Small group of studies showing no consistent effect on falls or fallers. | Conducted outside the US; one trial had a social services program conduct repairs that would likely not be available in the US
Environment K=3 (2 new) N=2,175 | Injuries | k=1, n=273 | No difference between IG and CG | NA | NA | Insufficient | Good: 1 Fair: 2 | Small group of studies showing no consistent effect on falls or fallers. | Conducted outside the US; one trial had a social services program conduct repairs that would likely not be available in the US
Environment K=3 (2 new) N=2,175 | Mortality | k=0 | NA | NA | NA | Insufficient | Good: 1 Fair: 2 | Small group of studies showing no consistent effect on falls or fallers. | Conducted outside the US; one trial had a social services program conduct repairs that would likely not be available in the US
KQ2
Multifactorial | Harms | k=4, n=1,466 | Harms were generally minor, rare musculoskeletal complaints related to the exercise component of the MF intervention. | Reasonably consistent, imprecise | Suspected | Low | Good: 2 Fair: 2 | Conclusions are limited by few studies and incomplete adverse event reporting | Studies of high-risk older adults
Exercise | Harms | k=8, n=4,107 | No difference in serious injuries observed in two studies with CG comparison; several studies reported minor pain and/or bruising associated with exercise. One of these trials reported low rate of serious injurious falls during exercise sessions (2.6/100,000 sessions). | Reasonably consistent, imprecise | Suspected | Low | Good: 3 Fair: 5 | 75% did not report harms for CG | Community-dwelling; Average to high risk for falling
Vitamin D | Harms | k=5, n=3,955 | As noted above, there may be an increase in falls, people experiencing a fall, and injuries associated with the highest annual dose of vitamin D. No difference between the IG and CG in other adverse events attributable to treatment. | Inconsistent, imprecise | Suspected | Low | Good: 3 Fair: 2 | Conclusions limited by rare events and incomplete reporting | Most studies of average risk older adults
Environment | Harms | k=0 | NA | NA | NA | Insufficient | NA | NA | NA

Abbreviations: CG = control group; CI = confidence interval; EPC = Evidence-based Practice Center; IG = intervention group; IRR = incidence rate ratio; IU = international unit(s); k = number of studies; n = number of participants; NA = not applicable; NR = not reported; RCT = randomized controlled trial; RR = relative risk; sig = significant; stat = statistically; US = United States

Other intervention types included in this review:

Medication management: Two fair quality trials (n=266) of participants at high risk for falls showed no difference in falls, people experiencing a fall, injuries or mortality (insufficient)

Psychological: Two fair quality trials (n=886) showed nonstatistically significant reductions in falls and people experiencing a fall. Trial results on injurious falls was mixed, and there was no difference in mortality. (Insufficient)

Multiple: Six fair to good quality individual trials each studying different combination of intervention types: Exercise + Environment + Vision (n=272), Exercise + Psychological (k=2, n=531), Exercise + Knowledge + Fall risk assessment (n=453), Exercise + Vitamin D (n=204), Knowledge + Environment (n=310). Trials show mixed results on falls, fallers, injuries with the only the exercise+environonment+vision trial showing a statistically significant reduction in both falls and fallers. (Insufficient)

### Multifactorial Interventions

Our meta-analyses, which examined 26 multifactorial trials, showed a 21 percent reduction in the incidence rate of falls with substantial heterogeneity (k=17; n=9,737; IRR, 0.79 [95% CI, 0.68 to 0.91]; p=0.001; I^2^=87.2%) but showed no effect on people experiencing a fall (k=24; n=12,490; RR, 0.95 [0.89 to 1.01]; p=0.000; I^2^=56.4%), people experiencing an injurious fall (k=16; n=9,445; RR, 0.94 [95% CI, 0.85 to 1.03]; I^2^=34.3%), or mortality (k=23; n=9,721; RR, 0.96 [95% CI, 0.79 to 1.17]; p=0.659; I^2^=0%). In addition to the clinical heterogeneity inherent in the nature of the customized multifactorial interventions, some of the statistical heterogeneity may also be related to differences in recruitment setting (i.e., patients recruited after a fall from emergency settings may realize greater fall reductions from multifactorial interventions than those recruited from other settings). For all other fall-related outcomes, an insufficient number of studies was available for pooling (e.g., the outcome was reported in <50% of the 26 trials). For outcomes including injurious falls, fracture, persons with a fracture, ADL, IADL, QOL, people hospitalized, and people transitioning to institutional care, the existing studies were underpowered and revealed no statistically significant effect of the multifactorial intervention.

### Exercise

Our meta-analyses examining 21 exercise trials revealed a nonsignificant 13 percent reduction in falls (k=14; n=4,663; IRR, 0.87 [95% CI, 0.75 to 1.00]; I^2^=57.3%), an 11 percent reduction in people experiencing a fall (k=15; n=4,926; RR, 0.89 [95% CI, 0.81 to 0.97]; I^2^=43.9%), a 19 percent reduction in injurious falls (k=10, n=4,622; IRR, 0.81 [95% CI, 0.73 to 0.90]; I^2^=0.0%), and a reduction in people experiencing an injurious fall, with individual estimates ranging from 0.61 to 0.90 (k=5, n=2,776). We observed no effect on mortality (k=11; n=4,263; RR, 0.93 [95% CI, 0.71 to 1.22]; I^2^=0%). Unlike the multifactorial intervention results, which only showed statistically significant reductions in incidence of falls, the exercise intervention evidence base showed a more consistent pattern of effectiveness across multiple fall-related outcomes (falls, people experiencing a fall, injurious falls, and people experiencing an injurious fall) despite fewer trials and fewer total participants. For the remaining outcomes (e.g., hospitalization, institutionalization, QOL, IADL), there was an insufficient number of exercise trials to pool (1–3 trials for each outcome), and none of the underpowered trials had an effect on these outcomes.

### Vitamin D

Seven heterogeneous studies of different vitamin D formulations, dosing schedules, and varying baseline risk in community-dwelling older adults (not selected for vitamin D insufficiency or deficiency) reported mixed results for falls (k=5; n=3,496), people experiencing a fall (k=6; n=6,519), and mortality (k=6; n=7,084). While we presented vitamin D meta-analyses showing no overall effect on these outcomes, we are aware that the number of trials available is at the lower end of what would be considered a sufficient number of trials for pooling, and the wide variation in the formulation and dosages may contribute to the statistical heterogeneity obscuring important differences related to formulation or dosage. A single study showed no difference in QOL at 12 months. No studies reported on hospitalizations, institutionalizations, ADLs, or IADLs. Sensitivity analyses performed removing the high-dose vitamin D trial showed no statistically significant difference in falls or people experiencing a fall. Our main analysis excluded trials solely recruiting vitamin D insufficient/deficient populations because our clinical question was whether or not universal supplementation of unselected primary care older populations would influence fall-related outcomes. However, adding trials specifically recruiting participants with insufficient or deficient vitamin D levels in a sensitivity analysis showed a nonstatistically significant reduction in people experiencing a fall with the upper confidence interval including 1 (RR, 0.88 [95% CI, 0.78 to 1.00]).

### Environment

Three environment trials (n=540) showed mixed results. One small trial showed a 46 percent reduction in falls; the other two trials showed no difference in falls. Three trials showed no difference in people experiencing a fall. One trial showed no difference in injurious falls,^122^ and another showed no difference in QOL or ADL outcomes.^162^

### Medication Management

Evidence is limited to two underpowered RCTs (n=266). There was no difference in falls, people experiencing a fall, injuries or mortality seen in high-risk older adults receiving medication management interventions.

### Psychological

Two trials (n=2,886) of psychological interventions showed nonstatistically significant reductions in falls and people experiencing a fall. Trial results on injurious falls were mixed, and there was no difference in mortality.

### Multiple Interventions

Six trials that provided more than one intervention component to all participants used a variety of combinations of components. Five trials used exercise plus one or more other interventions. Overall, the studies did not provide sufficient evidence to allow us to conclude whether there was a benefit from combining individual intervention types.

### Heterogeneity

For the exercise and multifactorial intervention trials, we explored heterogeneity by the setting of the trial recruitment, study quality, duration, and country; the duration of the intervention, total hours, and time per week; and mean age of participant, participant’s risk status, and rate of the control group for falls or people experiencing a fall. For the multifactorial trials, we found no patterns that suggested that any of these variables altered the effectiveness of treatment, with the exception of the recruitment setting. For the recruitment setting, trials that recruited participants after a fall from an emergency setting had a greater reduction in the fall rate (but not the number of people experiencing a fall) and meta-regression showed that both clinic (p=0.030) and multiple (p=0.023) recruitment settings were statistically different than the emergency setting (Appendix C). Notably, while there was no linear correlation seen between control group fall rates and intervention effectiveness, this association between recruitment setting and effect size may reflect the fact that trials recruiting from emergency settings have generally higher-risk populations. For exercise interventions, our initial exploratory analysis, which should be interpreted with caution, suggested that group-based exercise compared to individual-based exercise, multiple exercise components versus single exercise component, and interventions including strength or resistance exercises compared to those without those components were more likely to be associated with a greater reduction in both falls and people experiencing a fall.^175^

### Harms

Theoretically, increasing physical activity could lead to more frequent falls and injuries, but the trial literature is too limited to confirm this idea. Some of the exercise intervention trials and multifactorial interventions with exercise components have reported largely minor adverse effects associated with exercise, including muscle soreness; injurious falls occurring during exercise sessions were rare. The vitamin D trial with the highest dosage (500,000 IU annually of cholecalciferol) was associated with a statistically significant increase in falls, people experiencing a fall, and injurious falls as well as a nonstatistically significant increase in fractures, but this trial has not been replicated.^153^ Other dosing regimens do not appear to be consistently associated with increased harms.

## Comparison With Other Systematic Reviews (Michael 2010 and Gillespie 2012)

### Michael 2010 Review (USPSTF)

Our review represents an update to the 2010 systematic review for the USPSTF by Michael et al.^53,56^ Major differences between this review and that one include the use of studies published since the earlier review’s end search date of February 2010 and the addition of number of falls and injurious falls as outcomes (we calculated IRRs for trials based on the number of falls and followup time when IRRs were not reported by the study authors). Another major difference was our exclusion of trials that solely recruited populations with specific medical diagnoses (e.g., exclusion of vitamin D trials that recruited participants with vitamin D deficiency or insufficiency). Moreover, we excluded certain types of interventions we considered to be most applicable to the frailest older adults in institutional settings (e.g., hip protectors, nutritional interventions) or interventions that could be implemented for reasons other than preventing falls (e.g., treatment of visual defects).

Despite the differences between our review and the prior review, our conclusions regarding the effect of interventions on preventing falls are similar, with the exception of vitamin D, where excluding populations that had vitamin D deficiency or insufficiency resulted in fewer included trials and the results indicated a more mixed picture with meta-analyses showing no overall effect. On the basis of the results of our findings and in terms of the vitamin D literature, it is unclear if the use of this vitamin by the general population of older adults plays a role in reducing falls. Other researchers have reported conflicting results regarding vitamin D’s effect on falls.^176,^ ^177^ Some systematic reviews that included trials that recruited institutionalized participants and those with vitamin D deficiency or insufficiency reported a pooled reduction in falls, but the dose and target population remain uncertain.^177-180^ Still others have concluded from the broader literature on vitamin D (including vitamin D-deficient or -insufficient populations) that no benefit is achieved with vitamin D, with or without calcium, in reducing falls among older adults^181^ and that new studies are unlikely to change this conclusion.^182^

### Gillespie 2012 Review (Cochrane)

Our review methods differ in several ways from the oft-cited 2012 Cochrane review by Gillespie et al.^57^ Our criteria excluded cataract surgery, comparative effectiveness trials, trials with less than 6 months of followup, and trials that recruited participants who were not representative of general, unselected primary care populations (e.g., participants with osteoporosis, vitamin D deficiency or insufficiency, visual impairment.) In addition, the minimum age we selected was 65 years, while Gillespie selected 60 years for the minimum age; this did not make a substantive difference in our included studies. Finally, we included fall-related injuries as an outcome (Gillespie reported only fall-related fracture). Despite differences in the inclusion criteria, statistical methods, and intervention categorizations for meta-analysis, our conclusions regarding the effectiveness of exercise, multifactorial, and vitamin D interventions on falls and/or people experiencing a fall are similar to those of Gillespie et al^57^ and others.^177,^ ^183-185^ Subanalyses by Gillespie et al demonstrated that vitamin D was effective in reducing falls or people experiencing a fall in four trials (n=804) of populations selected for lower vitamin D levels.^57^ Gillespie et al demonstrated that tai chi-based exercise interventions were effective in reducing falls (n=1,563, k=5) and the number of people experiencing falls (n=1,625, k=6). We saw no difference in effectiveness for tai chi-based exercise interventions in the current review. Gillespie included five tai chi exercise trials that were not included in our current review; these interventions were excluded because of study aim,^186^ follow-up of less than 6 months,^145,^ ^187^ quality,^187^ or comparative effectiveness.^143,^ ^188^ In general, the five tai chi exercise studies included in Gillespie and excluded from our current review had large positive effects, and a couple were statistically significant.

## Fall and Injury Outcomes

As mentioned above, most trials provided data on either falls or people experiencing a fall. We calculated fall rates for many of the trials for inclusion in our meta-analyses; the remaining outcomes were less commonly reported in the trials. While it remains uncertain whether falls or people experiencing a fall represent a more clinically meaningful outcome, we present both in this review because the number of trials and participants was similar for these outcomes (falls: k=52, n=26,319; people experiencing a fall: k=54, n=26,560). Since each fall could result in injury, an intervention that reduces the number of falls could provide an important public health benefit by reducing the number of injuries and thus overall morbidity. On the other hand, reducing the number of people experiencing a fall may represent an important outcome to individuals seeking to prevent any fall and subsequent injury, activity limitation, and functional decline. Our qualitative within-trial comparisons between falls and people experiencing a fall showed no apparent association between statistically significant reductions in one of these outcomes (falls) and the other (people experiencing a fall). Nor was there an association between the rate of falls or percentage of people experiencing a fall in the control group and the effect of interventions on falls and people experiencing a fall.

For effective interventions, trials would ideally show that interventions lead to fewer falls and fewer people experiencing a fall as well as fall-induced injuries. We attempted to increase our power to analyze the effect of interventions on injuries by creating a composite category of “injurious falls” (defined as a trial-reported injurious fall, fall-induced injury, or fall with injury resulting in medical attention), although we recognized that the severity of injuries may vary widely even among falls that lead to visits to an emergency department. With the exception of exercise interventions, for which we found a reduction in injurious falls in the pooled analysis and a reduction in people experiencing an injurious fall based on our qualitative analysis and consistent with the findings of another review,^183^ the available evidence on injurious falls or persons with injurious falls for the remaining interventions is either too limited to make conclusions or the available evidence suggests no effect. Concluding that interventions other than exercise have no effect on injuries would be premature given that so few of the trials were designed to have adequate power for preventing injury (or fracture).^88,^ ^90,^ ^115,^ ^150,^ ^153^ The uncertainty of the effect of all nonexercise interventions on injuries remains.

A fracture may represent a serious injury that can be diagnosed more objectively than a fall or person experiencing a fall can (hence, fracture reporting in other systematic reviews^53,^ ^56,^ ^57^ instead of the general category of injury). Preventing mortality associated specifically with hip fractures remains a clinically important goal for interventions in preventing falls. Only one-fourth of the trials included in our review (14 of 58) reported fracture outcomes (9 multifactorial trials,^71,^ ^75,^ ^78,^ ^88-92,^ ^95^ 2 vitamin D trials,^150,^ ^153^ and 3 exercise trials^114,^ ^117,^ ^125^ reported fracture events or people with fracture). Even fewer (4 trials) reported hip fractures (1 exercise,^125^ 1 vitamin D,^150^ and 2 multifactorial trials)^75,^ ^95^ reported hip fracture or persons with hip fracture). Other systematic reviewers who have pooled fractures in exercise trials have shown an approximately 60 percent reduction in fracture with exercise interventions (Gillespie et al^57^: k=6, RR, 0.34 [95% CI, 0.18 to 0.63], el-Khoury et al^183^: k=6, RR, 0.39 [95% CI, 0.22 to 0.66]). We did not pool the trials reporting fractures; the few available trials showed inconsistent and imprecise results (Figure 4; Figure 7), so we have low certainty of fall-prevention intervention effects on fractures.

The effect of interventions to prevent falls on functional status or QOL remains uncertain. The few trials reporting QOL, ADL, or IADL showed no benefit, but these studies used different scales, and few trials were powered for these outcomes. Larger trials might be able to explore interventions to prevent falls associated with QOL, but it is unlikely that measures of ADL or IADL would have sufficient specificity in this population for measuring functional status. The issues with ADL and IADL scales include floor and ceiling effects, insensitivity to change, and a lack of evidence that supports a minimal clinically important difference among community-dwelling older adults.^189,^ ^190^ The most severe outcome of mortality would not be expected to be affected by these interventions to reduce falls in older adults because competing causes of mortality are more common than falls. In addition, these relatively short-term studies (most trials lasted 12 months) of older adults had relatively few mortality events, so null findings on mortality were expected.

## Implementation Issues

### Selection of High-Risk Patients for Interventions to Prevent Falls

While a number of primary care tools are available for use in assessing the risk of falls among older adults, the efficacy of these tools is uncertain. The literature on fall-risk assessment tools is both complex and limited: few prospective or retrospective studies use different cut points for any given tool, LRs are inconsistent for a given tool across the available studies, and rarely is there a consistent LR high enough to move the post-test probability to a clinically important threshold. Systematic reviews of the TUG test and other clinical screening tests for the risk of falls suggest that evidence of the adequacy of these screening instruments for predicting falls is insufficient.^33,^ ^191^ A 2016 systematic review of fall-risk assessment tools concluded that no single test or measure included in the review (56 measures including history questions, self-report measures, and performance-based measures) was an accurate diagnostic tool.^192^ Given the multifactorial etiology of falls, there may be value in combining measures to accurately predict future falls; however, such combinations have not been validated in large studies. In addition, the interventions included in this review rarely used these tools to assess participants’ eligibility or inclusion into a study. We did not find any evidence that interventions targeted to populations at high risk of falls (other than recruitment from emergency settings in the multifactorial studies) were more successful than interventions targeted at populations at average risk of falls. Thus, within our included literature, we were not able to evaluate evidence addressing feasible approaches for clinicians to identify older adults who would most benefit from exercise or multifactorial interventions.

The CDC STEADI toolkit includes an algorithm for annual fall-risk assessment beginning with three questions (history of falls, unsteadiness, and worries about falling); in those with a positive response to any of these questions, the algorithm suggests a TUG test (with an optional 30-Second Chair Stand^193^ and Four-Stage Balance Test).^29^ However, systematic reviews of the TUG test and other clinical screening tests for the risk of falls suggest that evidence of the adequacy of these screening instruments for predicting falls is insufficient.^33,^ ^191^

In the included studies, 65 percent of the RCTs were conducted in populations at high risk of falls (40 of 62 RCTs). Medication management and psychological interventions selected only high-risk populations. More than half of the multifactorial (73%, 19 of 26), multiple (67%, 4 of 6), and exercise (57%, 12 of 21) trials selected high-risk populations. Vitamin D and environment interventions were more likely to include populations at average risk of falls. Only one of the included studies adopted the CDC recommendations for risk assessment to identify a population at high risk for falling.^173^ The most common approach taken in the included studies to identify a person at high risk of falls was to collect the patient’s history of falls (k=16).^72,^ ^75-77,^ ^80,^ ^81,^ ^83,^ ^84,^ ^90-92,^ ^95,^ ^113,^ ^120,^ ^162,^ ^164,^ ^171^ The remaining RCTs conducted with high-risk populations evaluated two or more risk factors (e.g., history of a fall, difficulty with mobility, use of health care) and included participants with any of these risk factors.

### Implementation of Effective Interventions

There are some important considerations in applying our findings to the U.S. health care system for the multifactorial and exercise interventions. The interventions offered in the included exercise trials are different from typical physical therapy referrals available in the U.S. clinical setting in their design (the majority were not customized based on individual risk assessment and diagnoses) and delivery (exercises delivered by exercise instructor or other health professional and group based) but similar in their focus on common components (balance, gait, strength). Most of these exercise programs are similar to what may be available in the community, rather than clinical, setting. In the multifactorial trials, the individual treatment interventions including physician specialty referrals, physical therapy/exercise, and environment interventions are largely reflective of what patients could receive piecemeal, although rarely in such a comprehensive fashion in the current U.S. health care delivery system. The exercise/PT interventions included in the multifactorial trials are similar to what patients receive in the U.S. clinical setting in their design (physical therapist designed and individually developed program based on functional assessment and diagnoses), delivery (physical therapist delivered most of the interventions—some individually and some group), and components (balance, gait, strength).

## Limitations of the Literature

Although we used the ProFaNE taxonomy to systematically categorize intervention types, components, personnel, participants, settings, and outcomes, the heterogeneity in the designs and implementation strategies within even a single intervention type was marked. Meta-analysis reporting a single point estimate may present false precision in a field where the complexity of the causes of falls, patient functional status and comorbidities, and environmental influences would be expected to lead to subgroup differences. Exercise showed the most consistent benefits across multiple fall-related outcomes (i.e., falls, people experiencing a fall, injurious falls, people experiencing an injurious fall), even though the exercise trials varied widely by the type and number of exercise components, the setting, and the intensity and duration. Among multifactorial interventions, which were designed to customize interventions to patients dealing with the complexity of falls, the protocols were rarely described in enough detail for replication. Nonetheless, clinicians and guideline developers need a best-evidence approach to preventing falls on the basis of available trial data. Aside from an annual dose of 500,000 IU of vitamin D, which may be associated with harms related to falls, uncertainty remains about the role of vitamin D in preventing falls. Different target populations, formulations, and dosages may have different effects on falls.^194^ One ongoing trial, the Study To Understand Fall Reduction and Vitamin D in You (STURDY), will randomly allocate 1,200 patients to one of four doses of vitamin D (200, 1,000, 2,000, or 4,000 IU per day) as a means to prevent falls among adults aged 70 and older who are at high risk of falls.^195^ The literature examining multiple interventions included only one or two trials of any given combination of interventions. The literature of other single interventions (i.e., environment, psychology, medication management) was similarly limited.

## Limitations of Our Approach

We excluded trials that specifically recruited participants with neurologic diagnoses (e.g., dementia, Parkinson’s disease, stroke) because those populations may require specialized approaches to preventing falls. We also excluded other specific diagnoses, such as vitamin D insufficiency and osteoporosis, so our conclusions may not be applicable to those populations. Our inclusion criteria more generally represented unselected community-dwelling older adults seen in primary care. We included trials only when the primary or secondary aim was to prevent falls among older adults, both to select interventions with biologic plausibility of reducing falls and for pragmatic purposes. We limited our search to English-language literature following USPSTF methodology.^63^ We excluded comparative effectiveness trials and as such, for the exercise trials, we excluded those with active exercise controls (e.g., stretching, walking). We conservatively pooled trials that represented at least 50 percent of the studies for a given intervention so did not perform meta-analysis for many outcomes. Our protocol prioritized hard health outcomes consistent with the USPSTF methodology and therefore did not include functional outcomes, such as changes in balance, endurance, or walking speed. While we recognize that falls efficacy scales and fear of falling are commonly reported in trials, we excluded these outcomes in favor of those focused on falls, people experiencing a fall, and injuries due to a fall. We also did not examine other non-fall-related outcomes that may be associated with these interventions (e.g., the effect of exercise on cardiovascular outcomes or vitamin D on other health outcomes). For vitamin D, this review captures a small fraction of the large body of evidence of vitamin D’s effect on numerous outcomes including cardiovascular and cancer outcomes in populations with and without vitamin D deficiency.^196-198^

## Future Research

Large-scale RCTs are needed that replicate the multifactorial and exercise trials with detailed published protocols. Ideally, these trials would use recommended clinical risk-assessment tools (e.g., STEADI screening protocol) to target interventions to high-risk patients. One such trial, the Strategies to Reduce Injuries and Develop Confidence in Elders (STRIDE) study (jointly funded by the Patient-Centered Outcome Research Institute and the National Institute on Aging of the National Institutes of Health) is a large-scale (n=6,000), pragmatic cluster-randomized trial of a multifactorial intervention in community-dwelling older adults at risk of falls who are being recruited from 86 U.S. primary care practices. This trial will report falls, fall-related injuries, and physical function. The scheduled completion date is July 2019.^199^ Other ongoing research trials are listed in Appendix D Table 1.

Only fifty percent of community-dwelling older adults adhere to fall-prevention interventions at 1 year.^200^ Thus, exploring barriers to the implementation of effective exercise interventions would be critical to increasing exercise among elderly adults.^201,^ ^202^ Likewise, in considering how to implement effective exercise interventions, it remains uncertain whether altering personnel, components, and/or intensity of exercise may influence outcomes. Additionally, while our review did not address comparative effectiveness, it would be helpful to focus future research on whether the addition of another intervention to an effective intervention (e.g., exercise) is more beneficial. Finally, to provide adequate evidence on potential harms, all research needs to more consistently monitor adverse effects in both the control and intervention groups.

## Conclusion

The largest bodies of literature evaluated multifactorial and exercise interventions, with 26 and 21 trials, respectively. Our findings suggest that there is a fall-related benefit associated with both multifactorial and exercise interventions, but evidence is most consistent across multiple fall-related outcomes for the exercise trials. The current fall-prevention evidence base demonstrates that exercise is associated with fewer falls, people experiencing a fall, injurious falls, and people experiencing an injurious fall in average and high-risk community-dwelling older adults. Multifactorial interventions, which include risk-based, customized referrals and treatments, appear to reduce falls but not people experiencing a fall or injuries, and while there are numerous multifactorial trials designed with somewhat similar strategies, the studies are clinically and statistically heterogeneous. No specific effective exercise or multifactorial protocol has been replicated in larger population trials. Vitamin D, environment, and medication management interventions have either single trials showing no statistically significant effect or a few trials reporting mixed results. Single trials of cognitive behavioral, knowledge+environment, and exercise+environment+vision interventions showed moderate effectiveness in reducing falls, people experiencing a fall, or both.