# 1 Introduction

## Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2012 recommendation on preventing falls in older adults.

## Condition Background

### Condition Definition

A fall is “an unexpected event in which the participant comes to rest on the ground, floor, or lower level.” A severe fall is defined as a fall leading to medical care, fracture, injury (including serious injury or death), or hospital admission. The operationalization of these definitions varies considerably across studies, and in some studies no explicit definition is used at all. Ascertainment of a fall may be documented via retrospective reporting systems, such as a telephone interview, face-to-face interview, or postal questionnaire; prospective reporting systems using postcards, calendars, and diaries; or routine surveillance systems, including health care records.

### Prevalence and Burden

People aged 65 years and older constitute the fastest-growing segment of the U.S. population. The U.S. Census Bureau projects that the number of people 65 years and older will be 83.7 million in 2050, almost double the estimated population of 43.1 million in 2012.^1^ The number of people greater than 85 years old will increase from 5.9 million in 2012 to 8.9 million in 2030.^1^ In 2050, this oldest age group is projected to account for 4.5 percent of the U.S. population.^1^

Falls are the leading cause of injury-related morbidity and mortality among older adults.^2^ Nearly one-third (28.7%) of community-dwelling people aged 65 years or older fall at least once each year.^2,^ ^3^ The risk of falling increases with increasing age: 26.7 percent of those 65-74 years old report falling, while 36.5 percent of those 85 years and older report falling.^3^ In 2014, an estimated 2.8 million nonfatal falls among this population were treated in emergency departments and approximately 800,000 of people experiencing a fall were hospitalized.^2,^ ^3^ In the same year, over 27,000 older adults died from unintentional injuries from a fall.^2^ A recent study of coding patterns in fall-related mortality among the elderly in the United States found that current data on mortality due to a fall may underestimate the actual rate of these falls: states using coroners to investigate deaths due to injury from a fall reported 14 percent fewer incidences than did states in which a medical examiner completed the investigation.^4^

Disparities in falls exist by sex and race/ethnicity. Women are more likely to experience falls and fall-related injuries than men (30.3% of women versus 26.5% of men report a fall; 12.6% of women versus 8.3% men experience a fall-related injury). Whites are more likely to experience a fall than blacks (29.6% v 23.1%).^3^ After adjustment for age, men have a 40 percent higher rate of fall-related deaths than women.^2^ Older whites are 2.7 times more likely to have a fatal fall than their black counterparts,^2^ and older non-Hispanics have higher fatal fall rates than Hispanics.^5^

Falls predict quality of life, disability, admission to long-term care facilities, and death.^6-9^ Between 20 and 30 percent of those who fall incur moderate to severe injuries, such as fractures, lacerations, and head trauma (including traumatic brain injury), that result in decreased mobility and potentially reduced independence.^10,^ ^11^ In an analysis conducted in the United Kingdom of almost 2,000 fractures in adults over the age of 65, the most common fractures occurred in the hip (32%), wrist (24%), shoulder (10%), and ankle (6%).^12^ Among the very elderly (90 years or older), 56 percent of fractures occurred in the hip, but the prevalence was high for all femoral fractures.^13^ Over 50 percent of deaths due to falls are a result of complications following a hip fracture,^14^ and the highest mortality risks are observed in the first 6 months post-fracture.^15^ For those people who are admitted to a hospital after a fall, the length of stay is longer and referral to long-term care facilities is significantly higher among older adults than younger people.^16^ An estimated one-third of adults who lived independently before their hip fracture remain in a nursing home for 1 year or longer.^17^

Falls represent a significant burden on the U.S. health care system. In 2015, the direct medical cost was estimated to total $637.5 million for fatal falls and more than $31 billion for medically treated, nonfatal fall-related injuries.^18^ A 2010 systematic review found the mean costs per person who fell in the United States ranged from $2,044 to $25,955, depending on severity of the fall (based on 18 studies).^19^ Costs per fall ranged from $1,596 to $10,913, while costs per fall-related hospitalization ranged from $10,052 to $42,840.^19^

### Etiology and Natural History

Falls are caused by complex interactions among multiple risk factors, including long-term or short-term predisposing factors. Interactions between these factors may be modified by age, disease, and factors in the person’s environment.^20^ A single fall may have multiple causes or contributors, and repeated falls may have different etiologies.^6,21-23^

### Risk Factors

Risk factors for falls can be classified as intrinsic (within an individual) or extrinsic (external to an individual). Intrinsic (i.e., patient-related) risk factors include age, cognitive, and sensory deficits; gait, strength, and balance deficits; acute and chronic conditions; and behaviors.^24,^ ^25^ Extrinsic factors include environmental hazards or hazardous activities, such as medications, footwear, assistive devices, home or neighborhood features, alcohol and drugs, and physical support provided by caregivers.^24^ Certain risk factors may be modifiable through interventions: gait, strength, balance, and sensory deficits; behaviors; medications; footwear; assistive devices; home environment; alcohol or drug use; and physical support provided by caregivers.^24,^ ^25^

A person’s functional capacity may decrease as he or she ages because of physical and mental alterations that lead to impairments in balance, gait, and strength. A 2007 systematic review by Ganz et al concluded that those with a history of falls are likely to fall again (likelihood ratio [LR], 2.3 to 2.8), and the most consistent predictor of future falls was a clinically detected gait or balance abnormality (LR, 1.7 to 2.4)^26^ Other, more recent systematic and narrative reviews have likewise concluded that gait and balance abnormalities are the risk factors most consistently associated with falls;^25,^ ^27^ several other risk factors have also been associated with increased falls, including lower extremity weakness (OR, 1.76 [95% CI, 1.31 to 2.37]), cognitive impairment (OR, 2.13 [1.56 to 2.90]), psychoactive medications (e.g., benzodiazepines, antipsychotics, antidepressants) (OR range, 1.36 to 1.41), and a host of other medications and medical conditions.^25^

As people age, they may also develop more than one risk factor. Appreciating the interaction and probable synergism among multiple risk factors is important in making a clinical assessment.^7^ The risk for injuries that results from falling increases dramatically as the number of risk factors increases.^28^

### Risk Assessment Tools Feasible for Primary Care

Several options exist for assessing risk and customizing fall-prevention interventions in primary care. One common approach is to administer a one- to three-item fall-risk questionnaire (history of falls, feeling unsteady, and/or worry about falling) followed by a brief physical function assessment of strength, gait, and balance in those with positive screening questionnaires.^29,^ ^30^ Older adults with abnormal physical function on testing would then be referred for a single fall-prevention intervention or multiple interventions, as needed. Alternatively, both a questionnaire and an assessment of physical function could be administered to all older adults; results indicating a risk of falls would trigger a referral to intervention.

A number of risk assessment tools is available for use in primary care settings to identify an adult’s risk of falling (Table 1). Several physical function tests feasible for use in primary care focus on assessing lower extremity strength, endurance, balance, and/or mobility. These tests vary in their ability to predict future falls, and many were originally intended for research purposes rather than primary care practice.

Table 1 Examples of Fall-Risk Assessment Tools Feasible for Primary Care

| Measure | Description
Questionnaires | CDC STEADI three initial screening questions | A fall in the past year; feeling of unsteadiness when standing or walking; worry about falling.
Questionnaires | Patient administered: Stay Independent^203^ | Patient-administered questionnaire and scored questions on risk factors for falling (e.g., fall in previous 6 months, trouble stepping onto a curb, lost feeling in feet, depression).
Physical Function Measures | Timed Up and Go | The time it takes for a subject to rise from an arm chair, walk 3 meters, and return to the chair and sit.
Physical Function Measures | Gait speed | Speed used to walk a pre-specified distance in the clinic.
Physical Function Measures | Short Physical Performance Battery | Summary measure that incorporates time to complete 5 chair stands, balance testing, and time to walk 8 feet.
Physical Function Measures | 30-Second Chair Stand | Number of times a patient can stand from a chair without using their arms in 30 second215s.
Physical Function Measures | 4-Stage Balance Test | Four standing positions (feet side by side; feet with the instep of one foot touching the toe of the other; one foot in front of the other; one foot) that should be held for at least 10 seconds.
Physical Function Measures | Performance Oriented Mobility Assessment (POMA)^204^ | Task-oriented test measuring patient gait and balance abilities. Balance tests measure nine maneuvers from sitting position. Gait tests include seven measures that time and observe the patient’s abilities.
Combination | QuickScreen^205^ | Assessment of previous falls, drug use, vision, peripheral sensation, lower limb strength, balance, and coordination.

The Timed Up and Go (TUG) test is a risk assessment tool routinely used by clinicians to identify patients at risk for falls.^31-33^ A recent systematic review and meta-analysis of the overall predictive value of TUG in community-dwelling older adults found that the test has limited ability to predict falls in this population (OR, 1.01 [95% CI, 1.00 to 1.02], p=0.05) and should be used in conjunction with other tools to identify older adults at high risk of falls.^33^ Reviewers also found that TUG was more useful at ruling in—rather than ruling out—risk for falls in older adults and had a higher pooled specificity (0.74, 95% CI, 0.52 to 0.88) than sensitivity (0.31, 95% CI, 0.13 to 0.57).^33^

A recent study of another risk assessment tool, the Short Physical Performance Battery (SPPB), which includes measures of balance, gait speed, and repeated chair stands, found that the chair stand test alone may be sufficient to predict injurious falls.^34^ The poorest performance (≥16.7 seconds) was associated with a greater hazard of falling than all other time thresholds groups (hazard ratio, 1.96 [95% CI, 1.18 to 3.26] for ≥16.7 vs. 13.7–16.6 seconds, 1.65 [95% CI, 1.07 to 2.55] for ≥16.7 vs. 11.2–13.6 seconds, 1.60 [95% CI, 1.03 to 2.48] for ≥16.7 vs. <11.2 seconds).^34^

### Interventions

Interventions to prevent falls in older adults are varied and complex, with multiple components involving multidisciplinary teams in different implementation settings.^35^ For this reason, researchers from the Prevention of Falls Network Europe (ProFaNE) developed a taxonomy with the aim of improving the design and reporting of clinical trials on fall-prevention interventions and to classify existing intervention trials for analysis. The ProFaNE taxonomy groups interventions by type (i.e., descriptors), including the subdomains of exercise, medication (including pharmacotherapy [e.g., vitamin D] and medication management), surgery, management of urinary incontinence, fluid or nutrition therapy, psychological, environment/assistive technology, social environment, and interventions to increase knowledge.^35^ Interventions are further categorized by their combination of intervention types: single, multiple, or multifactorial. Multiple and multifactorial interventions both require two or more types of interventions (or subdomains) to be provided to the study participants. For multifactorial interventions, the intervention types provided to each patient are linked to his or her risk profile (usually part of a formal assessment); not all participants receive the same combination of interventions. For multiple interventions, all participants receive the same intervention types.^35^ For the purposes of this systematic review, we include interventions in accordance with a priori inclusion and exclusion criteria (Appendix B Table 1).

### Current Clinical Practice in the United States and Recent Recommendations

There are many reported barriers to implementation of fall-prevention interventions in current U.S. clinical practice, including competing demands, clinician education, and logistical issues (limitations in patient transportation, mobility).^36,^ ^37^ Furthermore, one study reported that less than half of older adults who fall discuss their falls with their physician.^38^ Nonetheless, there are several potential models for the implementation of fall-prevention interventions.

After an initial risk assessment in the context of a primary care visit or an annual prevention or wellness examination, primary care clinicians may elect to refer all patients identified as being at high risk of falls to individual or multiple services for further risk assessment and tailored intervention or interventions (e.g., home health, physical therapy, occupational therapy). Alternatively, where available, clinicians can refer a patient at high risk of falls to a “falls clinic.” These clinics are not widely available in the United States and vary substantially in personnel staffing, content of the visit, and duration of the intervention. A falls clinic may have a single or multiple specialties staffed by advanced registered-nurse practitioners, physical therapists, occupational therapists, and/or a variety of physician specialists (e.g., geriatrician, physical medicine and rehabilitation physician, ophthalmologist, otolaryngologist, neurologist, orthopedist). The clinic can provide multicomponent risk assessments in a patient encounter lasting between 30 minutes to 3 hours and generate tailored referrals. It may also provide ongoing interventions to prevent falls.^39-42^

The Centers for Medicare and Medicaid Services (CMS) sponsors the Annual Wellness Visit and the Initial Preventive Physical Examination (IPPE, known as the “Welcome to Medicare Preventive Visit”), a one-time benefit for all new Medicare beneficiaries within the first 12 months of their first Medicare Part B coverage period.^43^ As part of these visits, health care providers collect the plan member’s medical history, including risk factors for depression and other mood disorders, and review the beneficiary’s functional ability and level of safety. Appropriate screening questions and standardized questionnaires are used to review functional elements, including the risk of falls, hearing impairment, activities of daily living, and home safety.^43^ To help incentivize primary care physicians to perform fall-risk assessment and intervention, CMS also provides a five-star quality rating to insurance plans that measure the percentage of plan members with a risk of falling who discussed this risk with their physicians and received a fall-prevention intervention.^44^

Health care providers can also use the CDC Stopping Elderly Accidents, Deaths, and Injuries (STEADI) toolkit, which was designed to help providers incorporate fall risk assessments and individualized fall interventions into current clinical practice.^45^ Based on American and British Geriatrics Societies’ guidelines, conceptual chronic disease management,^46,^ ^47^ literature reviews on provider knowledge and clinical practices regarding older adult falls, and qualitative research, this toolkit provides resources for risk assessment, including standardized and validated gait, strength, and balance assessments (i.e., Timed Up and Go [TUG] test,^48^ 30-Second Chair Stand,^49^ Four-Stage Balance Test^50^), as well as educational materials for patients (e.g., a validated clinical assessment brochure).^45,^ ^51^

Recent recommendations from professional societies or organizations are listed in Appendix A. While all endorse interventions to prevent falls among older adults, the recommended interventions vary.

### Previous USPSTF Recommendation

In 2012, the USPSTF recommended “exercise or physical therapy and vitamin D supplementation to prevent falls in community-dwelling adults aged 65 years or older who are at increased risk for falls” (Grade B recommendation).^52^ The Task Force did not recommend routinely “performing an in-depth multifactorial risk assessment in conjunction with comprehensive management of identified risks to prevent falls in community-dwelling adults aged 65 years or older because the likelihood of benefit is small” (Grade C recommendation). Instead, the Task Force recommended that in determining whether this service is appropriate in individual cases, the patient and clinician should together consider the balance of the benefits and harms on the basis of the circumstances of prior falls, comorbid medical conditions, and the patient’s values.^52^