# Appendix D Ongoing Studies

Trial Identifier | Study Name | Location | Estimated N | Aim | Reported relevant Outcomes | 2017 Status
NCT01698580 | Multifactorial Falls Prevention Program-Brazil | Brazil | 612 | Clinical trial designed to evaluate the effectiveness of a multifactorial fall-prevention program in reducing the rate of falls. A multifactorial fall-prevention program consisting of an individualized medical management of the modifiable risk factors, a progressive on-site body balance exercise plus a home-based exercise program, an educational/behavioral intervention and a fall-prevention booklet will reduce the number of falls and fall rates when compared with usual care | Falls | Active Est. Completion Date: Jul 2018
NCT02665169 | Kuopio Fall Prevention Study. (KFPS) | Finland | 1078 | Evaluates the 6-month exercise intervention (Taiji and gym course) combined with free use of communal recreation facilities in fall prevention. Morbidity, use of social services and health outcomes of aging women in province of Kuopio, Finland are also monitored. The study combines 6 months of supervised exercise, followed by six months free, but unsupervised, use of recreational facilities and observational period of second year into total of 2 year follow up duration. | Falls; Physical function; QOL | Recruiting Est. Completion Date: Oct 2019
NCT02634736 | Cluster RCT of Falls Prevention Exergames for Older Adults (Profexs) | UK | 108 | Investigate the effectiveness of strength/balance Exergames (exercise and computer games that use body movements as controls) developed to improve balance, function, prevent falls and increase exercise adherence for older people in the home setting. | Fear of falling | Recruiting Est. Completion Date: Sep 2017
NCT02732366 | Living in Fitness Together (LIFT): Testing an Innovative Fall Prevention Program | USA | 48 | To test the feasibility and preliminary efficacy of a group-based fall-prevention program for older adults. | Falls; Fall-related injuries | Recruiting Est. Completion Date: Jan 2018
NCT02475850 | Strategies to Reduce Injuries and Develop Confidence in Eders (STRIDE) | USA | 6000 | The aim of this pragmatic cluster-randomized trial is to determine the effectiveness of an evidence-based, patient-centered multifactorial fall injury prevention strategy in community-dwelling older adults at risk of falls recruited from 86 primary care practices around the U.S. | Falls; Fall-related injuries; Physical function | Active Est. Completion Date: Nov 2019
NCT02631330 | Effect on Falls Reduction of a Multimodal Intervention in Frail and Pre-frail Ederly Community-dwelling People (FAREMAVA) | Spain & Portugal | 466 | To determine the efficacy of a comprehensive program to prevent falls in the community. | Falls; Fall-related medical care | Recruiting Est. Completion Date: Jul 2017 No results published as of Aug 2017
NCT02617303 | Prevention of Falls and Its Consequences in Elderly People (PRECIOSA) | Spain | 402 | This is a randomized clinical trial carried out in primary care. The study’s scope of activity will include four urban primary care centers. All selected patients with inclusion criteria will receive a geriatric assessment and other required medical treatment. Next, they will be allocated either to an intervention group or control group. The intervention group will be trained for 3 months according to the OTAGO exercise program (training phase). Followed by a loyalty phase during which they will be monitored quarterly for a year by their assessment team. The control group will be receiving normal medical treatment. Falls and fractures will be monitored quarterly in both groups during 15 months. | Falls; Fall-related fractures | Active Est. Completion Date: Jun 2017 No results published as of Aug 2017
NCT02847871 | Ederly Patient at Risk of Loss of Mobility, Exercise - Primary Care, Prevention, Care Pathways (PRISME-3P) | France | 300 | PRISME-3P program aims to develop and evaluate a dedicated care pathway, in primary care, based on a personalized multimodal intervention: screening, support combining physician, teaching exercises by a specialized Monitor in Adapted Physical Activities (MAPA) and nutritional counseling. | Falls; QOL | Recruiting Est. Completion Date: Jan 2020
NCT02166333 | Study To Understand Fall Reduction and Vitamin D in You (STURDY) | USA | 1200 | The proposed study is a clinical trial that will determine the effects of Four doses of vitamin D (200 International Units [IU]/day, 1000 IU/day, 2000 IU/day and 4000 IU/day) as a means to prevent falls in high-risk adults, ages 70 and older. | Falls | Recruiting Est. Completion Date: Dec 2019
NCT02828826 | Impact of Telephone Coaching on Physical Performance in a Physical Exercise Maintenance Program for Fallers Ederly Patients Living at Home (STEP-PA) | France | 180 | The recent OSSEBO study (intervention for the prevention of injurious falls in elderly women: background and design) recalled the interest to propose a program of physical exercise to reduce trauma and falls in the elderly. It also shows the possibility to implement an effective program on a long-term and large scale in France. The study allowed patients to participate in collective sessions of physical exercises, within the framework of an association. Patients were invited to continue their home exercises they had learned. | Falls | Not Yet Recruiting Est. Completion Date: Oct 2019
NCT02570178 (Protocol (https://www.ncbi.nlm.nih.gov/pubmed/26796956?dopt=Abstract)) | Effectiveness of an Intervention to Improve Balance and Decrease Falls in the Ederly (EWii) (EWii) | Spain | 760 | The objectives of this study are to evaluate the usefulness of an intervention utilizing the NintendoTM Wii console in order to improve balance, thereby decreasing both the fear of falling as well as the number of falls, and to evaluate the correlation between balance as determined by the console and the value obtained in the Tinetti tests and the one-foot stationary test. | Falls | Completed Protocol published Jan 2016; No results published as of Aug 2017
NCT02392013 | Home Hazard Removal Program to Reduce Falls (HARP) | USA | 300 | This study evaluates the effectiveness and implementation of a home-hazard removal program to reduce falls in older adults through a community program delivered through the aging services network. The investigators will conduct a hybrid effectiveness/implementation trial of 300 older adults at risk for a fall who will be randomized to a home-hazard removal program or usual care and then followed for 12 months. | Falls | Active Est. Completion Date: Nov 2017
NCT02714257 | Seniors Avoiding Falls Through Exercise Study (SAFE) | USA | 2280 | A 36-month multi-center randomized effectiveness trial to compare the impact of an Enhanced Usual Care (Control) intervention, with Exercise Coaching (Exercise), on Fragility Fractures and Serious Fall-Related Injuries (FF/SFRI) in patients with a previous fragility fracture (FF) | Falls; Fall-related injuries | Not Yet Recruiting Est. Completion Date: Aug 2020
NCT02374307 | Falls-prevention in Older People Receiving Home-help Services | Norw ay | 150 | Investigate the effect of a fall-prevention program on quality of life, fear of falling, falls and physical function in older people receiving home-help services. The participants in the intervention group will perform conduct the Otago exercise programme. The participants in the control group will continue with their usual activities. | Falls; QOL | Recruiting Est. Completion Date: Jan 2018
ISRCTN22202133 | Occupational Therapist Home Assessment and Modification for Prevention of Falls | UK | 1329 | A small study found that people in the community who had not been admitted to hospital because of a fall also had fewer falls when visited by an occupational therapist. To be more confident of these results, we wish to conduct a larger study to find out if people in the community would have fewer falls if they have a home hazard assessment by an occupational therapist. | Falls; QOL | Active Est. Completion Date: Nov 2018
ISRCTN 71002650 (Protocol (https://www.ncbi.nlm.nih.gov/pubmed/?term=ISRCTN+71002650)) | Prevention of Falls Injury Trial (PreFIT) | UK | 9000 | A three-arm, pragmatic, cluster randomised controlled trial, conducted within primary care in England, UK. Sixty-three general practices will be randomised to deliver one of three falls prevention interventions: (1) advice only; (2) advice with exercise; or (3) advice with multifactorial falls prevention (MFFP). | Falls, Fall-related injuries; QOL | Complete Protocol published Jan 2016; No results available as of Aug 2017
NCT01745263 | Do-HEALTH | Europe (7 cities) | 2152 | A randomized 2x2x2 factorial design trial of a simple home exercise program and/or vitamin D, and/or omega-3 fatty acids, over a 3-year period. The specific aim is to establish whether vitamin D, omega-3 fatty acids, and a simple home exercise program will prevent disease at older age. | Falls | Active Est. Completion Date: Nov 2017

Abbreviations: Aug = Oct = October; QOL = August; Dec = December; Est = estimated; Feb = February; FU = international units; Jan = January; Jun = June; Jul = July; N = number; Nov = November; quality of life; UK = United Kingdom; USA = United States of America