# Appendix C Multifactorial Forest Plots by Setting

Appendix C Figure 1 Pooled Analysis of Multifactorial Intervention Randomized, Controlled Trials for Falls at Longest Followup (6–12 Months), Stratified by Recruitment Setting

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio

Appendix C Figure 2 Pooled Analysis of Multifactorial Intervention Randomized, Controlled Trials for People Experiencing a Fall at Longest Followup (6-12 Months), Stratified by Recruitment Setting

Abbreviations: CG= control group; CI = confidence interval; IG - intervention group; RR = relative risk