# Appendix B Detailed Methods

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Trials with the primary or secondary aim of reducing falls or falls-related injuries | Comparative effectiveness trials of fall interventions
Population | Community-dwelling adults age ≤65 years (including those residing in independent living facilities). Includes older adults who are at average and high risk for falls; participants may be recruited from settings both within and outside of the community or primary care (e.g., community-dwelling adults recruited from emergency department visits for falls-related injuries). | - Trials conducted exclusively in populations living in special settings outside of the community (e.g., hospitals, nursing or care homes, rehabilitation centers, or other long-term care facilities); - Trials conducted exclusively in special populations (e.g., adults with neurocognitive disorders, such as moderate to severe dementia or Parkinson’s disease; persons who are nonambulatory) in which interventions may be considered disease management; - Trials conducted in adults age ≤65 years or with a mean study age of ≤65 years
Interventions | KQ 1:; - Interventions that are primary care feasible or referable; - Studies with a minimum followup of 6 months; Categories of included interventions^*^:; - Exercise (supervised or unsupervised, individual or group); - Medications (e.g., medical management, supplements [vitamin D, calcium]); - Psychological (individual or group); - Environmental/assistive technology (e.g., home hazard assessment and modification); - Knowledge (e.g., educational materials); - Social environment (e.g., caregiver training); Interventions may be delivered alone (single) or in combination (multifactorial, multiple). Multifactorial assessment and management is an included intervention. | KQs 1, 2:; - Community interventions that are not generally accessible (e.g., senior residence program); - Social marketing (e.g., media campaign); - Policy (e.g., local and State public or health policy); - Institutional methods (e.g., use of restraints); - Surgery (e.g., cataract extraction, pacemaker placement, podiatry surgery); - Fluid or nutrition therapyb; - Management of urinary incontinence; - Optical aids, hearing aids, and body-worn protective aids (e.g., hip protectors); - Interventions designed solely for persons with neurocognitive disorders; - Interventions designed solely for persons who are nonambulatory
Comparators | KQ 1:Pacebo, minimal control (i.e., provision of education via written materials, video, lecture), usual care
Outcomes | KQ 1:; - Falls; - Mortality (all-cause and falls-related); - Falls-related morbidity, defined as:; ○ Falls-related fracture injuries; ○ Disability (activities of daily life and/or instrumental activities of daily life); ○ Quality of life (as measured on the 12-, 20-, or 36-item Short-form Health Survey; EuroQol; Sickness Impact Profile; Health Utilities Index; Dartmouth COOP Charts; Nottingham Health Profile); ○ Hospitalizations for falls-related injuries; ○ Emergency department visits for falls-related injuries; ○ Institutionalizations (e.g., transition from community dwelling to nursing or care homes, or other long-term care facilities); KQ 2: Harm outcomes as reported in studies, including psychological outcomes | KQ 1:; - Falls-related injuries other than fractures that do not lead to an emergency department visit or hospitalization; - Quality of life measures not listed in the inclusion criteria; - Disability measures other than activities of daily life and/or instrumental activities of daily life; - Falls Efficacy Scale; - Function measures (e.g., Performance-Oriented Mobility Assessment, Timed Get Up & Go Test, 6-meter timed walk, Functional Reach Test, and Berg Balance Scale); KQ 2: Minor adverse events that are reported using nonvalidated, nongeneralizable measures
Study Designs | KQ 1: Randomized, controlled trials KQ 2 (vitamin D): Systematic evidence reviews; randomized, controlled trials identified from KQ 1 KQ 2 (all other interventions): Randomized, controlled trials identified from KQ1 | All KQs: Editorials, letters, nonsystematic reviews, opinions, comparative effectiveness trials KQ 1: Clinical controlled trials, case-control studies, cohort studies KQ 2: Convenience surveys, qualitative studies
Setting | Interventions conducted in primary care or that are referable from primary care | Interventions conducted in or recruited from settings that are not generalizable to primary care (e.g., worksites, university classrooms, institutional settings), in a population with pre-existing social ties (e.g., from the same worksite or church), in a setting with a population not comparable to a community-dwelling, primary care population (e.g., hospital, rehabilitation center, long-term care facility, emergency department), or in a setting where the intervention could not be reproduced in primary care or within a broader health system.
Country | Countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Countries not categorized as “Very High” on the 2014 Human Development Index
Language | English only | Non-English language publications
Quality | Fair or good, according to design-specific criteria | Poor, according to design-specific criteria

* Based on ProFaNE intervention descriptors (Lamb SE, Becker C, Gillespie LD, et al. Reporting of complex interventions in clinical trials: development of a taxonomy to classify and describe fall-prevention interventions. Trials. 2011;12:125).

† Included countries: all countries listed as “very high” or equivalent on human development on the 2014 Human Development Index (http://hdr.undp.org/en/statistics/): Andorra, Argentina, Australia, Austria, Bahrain, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cuba, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, Taiwan, United Arab Emirates, United Kingdom, United States

Abbreviations: ADL = activities of daily living; ED = emergency department; HDI = Human Development Index; IADL = instrumental activities of daily living

Appendix B Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria^*^
Randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^209^ | Valid random assignment? Was allocation concealed? Was eligibility criteria specified? Were groups similar at baseline? Was there a difference in attrition between groups? Were outcome assessors blinded? Were measurements equal, valid and reliable? Was there intervention fidelity? Was there risk of contamination? Was there adequate adherence to the intervention? Were the statistical methods acceptable? Was the handling of missing data appropriate? Was there acceptable followup? Was there evidence of selective reporting of outcomes? Was there a clear definition of the intervention?

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer

## Literature Search Strategies for Primary Literature

### Central

#1 “accidental falls”:kw
#2 falling:kw
#3 fall:ti
#4 falling:ti
#5 falls:ti
#6 (faller or fallers):ti,ab
#7 ^52-#6^Publication Year from 2010 to 2015, in Trials

### Cinahl

S55 S11 OR S54
S54 S7 AND S52 (Limiters - Published Date: 20100101-20151231; English Language)
S53 S7 AND S52
S52 S48 OR S51
S51 S4 AND S49 AND S50
S50 TI injur* OR AB injur* OR MW injur*
S49 S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29
S48 S43 AND S47
S47 S44 OR S45 OR S46
S46 TI “falls efficacy” OR AB “falls efficacy”
S45 TI “fear of falling” OR AB “fear of falling”
S44 TI adverse* OR AB adverse* OR MW adverse* OR TI harm* OR AB harm* OR MW harm*
S43 S41 OR S42
S42 MH “accidental falls” AND MW “prevention and control”
S41 S4 AND S40
S40 (S12 OR S13 OR S14 OR S15 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24
OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39)
S39 TI “recurrent faller*” OR AB “recurrent faller*” OR TI “recurrent falls” OR AB “recurrent falls”
S38 TI ( medication N3 (cessat* OR remov* OR stop OR withdraw*) ) OR AB ( medication N3 (cessat* OR remov* OR stop OR withdraw*) )
S37 TI ( medication N3 (modification or adjustment* or optim*)) OR AB ( medication N3 (modification or adjustment* or optim*) )
S36 TI (medication N2 review) OR AB (medication N2 review)
S35 TI “medical management” OR AB “medical management”
S34 TI “medication management” OR AB “medication management”
S33 TI ( multivitamin* OR multimineral* ) OR AB ( multivitamin* OR multimineral* )
S32 TI ( (vitamin* or mineral*) N5 (dietary or supplement*) ) OR AB ( (vitamin* or mineral*) N5 (dietary or supplement*) )
S31 MH “Vitamins” OR MH “Minerals”
S30 MH “Calcium, Dietary” OR TI (dietary N3 calcium) OR AB (dietary N3 calcium) OR TI “calcium supplement*” OR AB “calcium supplement*”
S29 MH “muscle strengthening” OR TI “muscle strengthening” OR AB “muscle strengthening”
S28 TI “mobility training” OR AB “mobility training”
S27 TI “balance training” OR AB “balance training”
S26 MH “gait training” OR TI “gait training” OR AB “gait training”
S25 MH “tai chi” OR TI “tai chi” OR AB “tai chi”
S24 TI “exercise therapy” OR AB “exercise therapy” OR TI “physical therapy” OR AB “physical therapy”
S23 MH exercise OR MH “therapeutic exercise”
S22 ( TI “hazard reduction” OR AB “hazard reduction” ) AND home
S21 ( TI “home hazard*” OR TI “home safety” OR AB “home hazard*” OR AB “home safety” ) AND (
TI modification* OR AB modification* OR TI program* OR AB program*)
S20 MH “home visits” OR TI “home visit*” OR AB “home visit*” S19 MH counseling OR (TI counsel* OR AB counsel*) OR MH “cognitive therapy”
S18 S16 AND S17
S17 TI ( assessment* or intervention* ) OR AB ( assessment* or intervention* )
S16 TI ( multifactorial or multifaceted or multidimensional ) OR AB ( multifactorial or multifaceted or multidimensional )
S15 TI ( “patient education” or “health education” ) OR AB ( “patient education” or “health education” )
S14 mh “patient education” or mh “health education”
S13 TI ( “geriatric assessment” or “geriatric functional assessment” ) OR AB ( “geriatric assessment” or “geriatric functional assessment” )
S12 mh “geriatric assessment” or mh “geriatric functional assessment”
S11 S8 AND S9 (Limiters - Published Date: 20100101-20151231; Language: English)
S10 S8 AND S9
- (MH “Meta Analysis”) OR (MH “Control Group”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR (MH “Randomized Controlled
S9 Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (AB clinical n1 trial*) OR (AB controlled n1 trial*) OR (TI clinical n1 trial*) OR (TI controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial)
S8 (S4 AND S7)
S7 S5 OR S6
S6 TI ( geriatric* or older or senior* or elder* or aged ) OR AB ( geriatric* or older or senior* or elder* or aged )
S5 (MH “Frail Elderly”) OR (MH “Aged”) OR (MH “Aged, 80 and Over”)
S4 S1 OR S2 OR S3
S3 TI (fall or falling)
S2 TI ( (falls or faller or fallers) ) OR AB ( (falls or faller or fallers) )
S1 mh “accidental falls”

### Ovid MEDLINE, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

#### KQ1

1. Accidental Falls/
2. (falls or faller or fallers).ti,ab.
3. (fall or falling).ti.
4. 1 or 2 or 3
5. aged/ or “aged, 80 and over”/ or frail elderly/
6. Geriatric Assessment/
7. Geriatrics/
8. Health Services for the Aged/
9. geriatric$.ti,ab.
10. older.ti,ab.
11. senior$.ti,ab.
12. elder$.ti,ab.
13. aged.ti,ab.
14. 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. 4 and 14
16. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
17. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
18. Random$.ti,ab.
19. control groups/ or double-blind method/ or single-blind method/
20. clinical trial$.ti,ab.
21. controlled trial$.ti,ab.
22. meta analy$.ti,ab.
23. 16 or 17 or 18 or 19 or 20 or 21 or 22
24. 15 and 23
25. limit 24 to english language
26. limit 25 to yr=“2010 -Current”
27. remove duplicates from 26

#### KQ2

1. Accidental Falls/
2. (falls or faller or fallers).ti,ab.
3. (fall or falling).ti.
4. 1 or 2 or 3
5. Geriatric Assessment/
6. (multifactorial or multifaceted or multidimensional).ti,ab. and (assessment$ or intervention$).ti,ab,hw.
7. geriatric assessment$.ti,ab.
8. Patient Education as Topic/
9. Patient education.ti,ab.
10. Health Education/
11. Health Education.ti,ab.
12. education$ intervention$.ti,ab.
13. Counseling/
14. Directive Counseling/
15. counsel$. ti,ab.
16. Cognitive Therapy/
17. House Calls/
18. home visit$.ti,ab.
19. ((home hazard$ or home safety) and (modification$ or program$)).ti,ab.
20. hazard reduction.ti,ab. and home.ti,ab,hw.
21. Exercise/
22. Exercise Therapy/
23. exercise therapy.ti,ab.
24. Physical Therapy.ti,ab.
25. Physical Therapy Modalities/
26. Exercise Movement Techniques/
27. exercise training.ti,ab.
28. tai chi,ti,ab.
29. Tai Ji/
30. gait training.ti,ab.
31. balance training,ti,ab.
32. mobility training.ti,ab.
33. muscle strengthening.ti,ab.
34. Calcium, dietary/
35. (diet$ adj3 calcium).ti,ab.
36. calcium supplement$.ti,ab.
37. Vitamins/
38. Minerals/
39. ((vitamin$ or mineral$) adj5 (dietary or supplement$)).ti,ab.
40. (multivitamin$ or multimineral$).ti,ab.
41. medication management.ti,ab.
42. medical management,ti,ab.
43. (medication adj2 review).ti,ab.
44. (medication adj3 (modification or adjustment$ or optim$)).ti,ab.
45. (medication adj3 (cessat$ or remov$ or stop$ or withdraw$)).ti,ab.
46. recurrent faller$.ti,ab.
47. recurrent falls.ti,ab,
48. or/5-47
49. 1(4 and 48) or Accidental Falls/pc
50. adverse effects.fs.
51. adverse$.ti,ab.
52. harm$.ti,ab.
53. psychology.fs.
54. fear of falling.ti,ab.
55. falls efficacy.ti,ab.
56. or/50-55
57. 49 and 56
58. or/21-33
59. injuries.fs.
60. injur$.ti.ab.
61. 59 or 60
62. 4 and 58 and 61
63. 57 or 62
64. aged/ or “aged, 80 and over”/ or frail elderly/
65. geriatric$.ti,ab.
66. older.ti,ab.
67. senior$.ti,ab,
68. er$.ti,ab.
69. aged.ti,ab,
70. or/64-69
71. 63 and 70
72. limit 71 to english language
73. limit 72 to yr=“2010 -Current”
74. remove duplicates from 73

PUBMED, publisher-supplied records

#11 #10 AND publisher[sb] AND (“2010”[Date - Publication]: “3000”[Date - Publication]) AND English[Language]
#10 #4 OR #9
#9 #1 AND #2 AND #8
#8 #5 OR #6 OR #7
#7 “falls efficacy”[tiab]
#6 “fear of falling”[tiab]
#5 adverse*[tiab] OR harm*[tiab]
#4 #1 AND #2 AND #3
#3 trial*[tiab] OR random*[tiab]
#2 geriatric*[tiab] OR older[tiab] OR senior*[tiab] OR elder*[tiab] OR aged[tiab]
#1 falls[tiab] or faller[tiab] or fallers[tiab] or fall[ti] OR falling[ti]

Figure 1 Literature Flow Diagram

* Trials may appear in more than one intervention type

Appendix B Figure 1 displays the literature search results and article flow for the review. A total of 3353 articles were identified through database searching, 21 through selected systematic evidence reviews and other sources, and 67 from the previous USPSTF review. 3441 articles were screened and 418 full-text articles were assessed for eligibility. 88 publications (62 trials) were included for KQs 1 and 2.

## List of Included Studies

### Multifactorial Interventions

Ciaschini PM, Straus SE, Dolovich LR, . Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724-30. PMID: 19767629.19767629
Close J, Ellis M, Hooper R, . Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93-7. PMID: 10023893.10023893
Cohen MA, Miller J, Xiaomei S, . Prevention Program Lowered The Risk Of Falls And Decreased Claims For Long-Term Services Among Elder Participants. Health Affairs. 2015;34(6):971-7. PMID: 26056202.26056202
Conroy S, Kendrick D, Harwood R, . A multicentre randomised controlled trial of day hospital-based falls prevention programme for a screened population of community-dwelling older people at high risk of falls. Age Ageing. 2010;39(6):704-10. PMID: 20823124.20823124
Davison J, Bond J, Dawson P, . Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162-8. PMID: 15716246.15716246
de Vries OJ, Peeters GM, Elders PJ, . Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. 2010;170(13):1110-7. PMID: 20625015.20625015
Peeters GM, de Vries OJ, Elders PJ, . Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. PMID: 17605771.17605771
Elley CR, Robertson MC, Garrett S, . Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383-9. PMID: 18808597.18808597
Fairhall N, Sherrington C, Lord SR, . Effect of a multifactorial, interdisciplinary intervention on risk factors for falls and fall rate in frail older people: a randomised controlled trial. Age Ageing. 2014;43(5):616-22. PMID: 24381025.24381025
Cameron ID, Fairhall N, Langron C, . A multifactorial interdisciplinary intervention reduces frailty in older people: randomized trial. BMC Med. 2013;11:65. PMID: 23497404.23497404
Fairhall N, Aggar C, Kurrle SE, . Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. PMID: 18851754.18851754
Ferrer A, Formiga F, Sanz H, . Multifactorial assessment and targeted intervention to reduce falls among the oldest-old: a randomized controlled trial. Clin Interv Aging. 2014;9:383-93. PMID: 24596458.24596458
Hendriks MR, Bleijlevens MH, van Haastregt JC, . Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390-7. PMID: 18662214.18662214
Hogan DB, MacDonald FA, Betts J, . A randomized controlled trial of a communitybased consultation service to prevent falls. CMAJ. 2001;165(5):537-43. PMID: 11563205.11563205
Imhof L, Naef R, Wallhagen MI, . Effects of an advanced practice nurse in-home health consultation program for community-dwelling persons aged 80 and older. J Am Geriatr Soc. 2012;60(12):2223-31. PMID: 23194103.23194103
Lightbody E, Watkins C, Leathley M, . Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203-10. PMID: 12006310.12006310
Logan PA, Coupland CA, Gladman JR, . Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. PMID: 20460331.20460331
Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296-304. PMID: 16078954.16078954
Moller UO, Kristensson J, Midlov P, . Effects of a one-year home-based case management intervention on falls in older people: a randomized controlled trial. J Aging Phys Act. 2014;22(4):457-64. PMID: 24152667.24152667
Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104-7. PMID: 11556409.11556409
Palvanen M, Kannus P, Piirtola M, . Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: a randomised controlled trial. Injury. 2014;45(1):265-71. PMID: 23579066.23579066
Perula LA, Varas-Fabra F, Rodriguez V, . Effectiveness of a multifactorial intervention program to reduce falls incidence among community-living older adults: a randomized controlled trial. Arch Phys Med Rehabil. 2012;93(10):1677-84. PMID: 22609117.22609117
Russell MA, Hill KD, Day LM, . A randomized controlled trial of a multifactorial falls prevention intervention for older fallers presenting to emergency departments. J Am Geriatr Soc. 2010;58(12):2265-74. PMID: 21143436.21143436
Salminen MJ, Vahlberg TJ, Salonoja MT, . Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612-9. PMID: 19392952.19392952
Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809-13. PMID: 19958918.19958918
Spice CL, Morotti W, George S, . The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33-40. PMID: 18829689.18829689
Tinetti ME, Baker DI, McAvay G, . A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821-7. PMID: 8078528.8078528
van Haastregt JC, Diederiks JP, van Rossum E, . Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994-8. PMID: 11039967.11039967
Vind AB, Andersen HE, Pedersen KD, . An outpatient multifactorial falls prevention intervention does not reduce falls in high-risk elderly Danes. J Am Geriatr Soc. 2009;57(6):971-7. PMID: 19507291.19507291
Vind AB, Andersen HE, Pedersen KD, . The Effect of a program of Multifactorial Fall Prevention on Health Related Quality of Life, Functional Ability, Fear of Falling and Psychological Well-being: A Randomized Controlled Trial. Aging Clin Exp Res. 2009. PMID: 19934621.19934621
Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800-6. PMID: 7977921.7977921

### Exercise Interventions

Barnett A, Smith B, Lord SR, . Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32(4):407-14. PMID: 12851185.12851185
Buchner DM, Cress ME, de Lateur BJ, . The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218-M24. PMID: 9224433.9224433
Buchner DM, Cress ME, Wagner EH, . The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41(3):321-5. PMID: 8440857.8440857
Buchner DM, Hornbrook MC, Kutner NG, . Development of the common data base for the FICSIT trials. J Am Geriatr Soc. 1993;41(3):297-308. PMID: 8440854.8440854
Tinetti ME, Baker DI, Garrett PA, . Yale FICSIT: risk factor abatement strategy for fall prevention. J Am Geriatr Soc. 1993;41(3):315-20. PMID: 8440856.8440856
Campbell AJ, Robertson MC, Gardner MM, . Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315(7115):1065-9. PMID: 9366737.9366737
El-Khoury F, Cassou B, Latouche A, . Effectiveness of two year balance training programme on prevention of fall induced injuries in at risk women aged 75-85 living in community: Ossebo randomised controlled trial. BMJ. 2015;351:h3830. PMID: 26201510.26201510
Dargent-Molina P, El Khoury F, Cassou B. The ‘Ossebo’ intervention for the prevention of injurious falls in elderly women: background and design. Glob Health Promot. 2013;20(2 Suppl):88-93. PMID: 23678502.23678502
Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728-33. PMID: 20817936.20817936
Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
Freiberger E, Haberle L, Spirduso WW, . Long-term effects of three multicomponent exercise interventions on physical performance and fall-related psychological outcomes in community-dwelling older adults: a randomized controlled trial. J Am Geriatr Soc. 2012;60(3):437-46. PMID: 22324753.22324753
Gawler S, Skelton DA, Dinan-Young S, . Reducing falls among older people in general practice: The ProAct65+ exercise intervention trial. Arch Gerontol Geriatr. 2016;67:46-54. PMID: 27420150.27420150
Stevens Z, Carpenter H, Gawler S, . Lessons learnt during a complex, multicentre cluster randomised controlled trial: the ProAct65+ trial. Trials. 2013;14:192. PMID: 23815878.23815878
Iliffe S, Kendrick D, Morris R, . Multi-centre cluster randomised trial comparing a community group exercise programme with home based exercise with usual care for people aged 65 and over in primary care: protocol of the ProAct 65+ trial. Trials. 2010;11:6. PMID: 20082696.20082696
Iliffe S, Kendrick D, Morris R, . Multicentre cluster randomised trial comparing a community group exercise programme and home-based exercise with usual care for people aged 65 years and over in primary care. Health Technol Assess. 2014;18(49):vii-xxvii, 1-105. PMID: 25098959.25098959
Gill TM, Pahor M, Guralnik JM, . Effect of structured physical activity on prevention of serious fall injuries in adults aged 70-89: randomized clinical trial (LIFE Study). BMJ. 2016;352:i245. PMID: 26842425.26842425
Fielding RA, Rejeski WJ, Blair S, . The Lifestyle Interventions and Independence for Elders Study: design and methods. J Gerontol A Biol Sci Med Sci. 2011;66(11):1226-37. PMID: 21825283.21825283
Kamide N, Shiba Y, Shibata H. Effects on balance, falls, and bone mineral density of a home-based exercise program without home visits in community-dwelling elderly women: a randomized controlled trial. J Physiol Anthropol. 2009;28(3):115-22. PMID: 19483372.19483372
Karinkanta S, Kannus P, Uusi-Rasi K, . Combined resistance and balance-jumping exercise reduces older women’s injurious falls and fractures: 5-year follow-up study. Age Ageing. 2015;44(5):784-9. PMID: 25990940.25990940
Karinkanta S, Nupponen R, Heinonen A, . Effects of exercise on health-related quality of life and fear of falling in home-dwelling older women. J Aging Phys Act. 2012;20(2):198-214. PMID: 22472580.22472580
Kovacs E, Prokai L, Meszaros L, . Adapted physical activity is beneficial on balance, functional mobility, quality of life and fall risk in community-dwelling older women: a randomized single-blinded controlled trial. Eur J Phys Rehabil Med. 2013;49(3):301-10. PMID: 23486300.23486300
Logghe IH, Zeeuwe PE, Verhagen AP, . Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57(1):70-5. PMID: 19054193.19054193
Logghe IH, Verhagen AP, Rademaker AC, . Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357-62. PMID: 20965096.20965096
Luukinen H, Lehtola S, Jokelainen J, . Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44(3):265-71. PMID: 17174387.17174387
Morgan RO, Virnig BA, Duque M, . Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59(10):1062-7. PMID: 15528779.15528779
Ng TP, Feng L, Nyunt MS, . Nutritional, Physical, Cognitive, and Combination Interventions and Frailty Reversal Among Older Adults: A Randomized Controlled Trial. Am J Med. 2015. PMID: 26159634.26159634
Robertson MC, Devlin N, Gardner MM, . Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322(7288):697-701. PMID: 11264206.11264206
Sherrington C, Lord SR, Vogler CM, . A post-hospital home exercise program improved mobility but increased falls in older people: a randomised controlled trial. PLoS ONE. 2014;9(9):e104412. PMID: 25180702.25180702
Trombetti A, Hars M, Herrmann FR, . Effect of music-based multitask training on gait, balance, and fall risk in elderly people: a randomized controlled trial. Arch Intern Med. 2011;171(6):525-33. PMID: 21098340.21098340
Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703-11. PMID: 25799402.25799402
Patil R, Kolu P, Raitanen J, . Cost-effectiveness of vitamin D supplementation and exercise in preventing injurious falls among older home-dwelling women: findings from an RCT. Osteoporos Int. 2015;27(1):193-201. PMID: 26205890.26205890
Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872.22448872
Voukelatos A, Cumming RG, Lord SR, . A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185-91. PMID: 17661956.17661956
Voukelatos A, Merom D, Sherrington C, . The impact of a home-based walking programme on falls in older people: the Easy Steps randomised controlled trial. Age Ageing. 2015;44(3):377-83. PMID: 25572426.25572426
Voukelatos A, Merom D, Rissel C, . The effect of walking on falls in older people: the ’Easy Steps to Health’ randomized controlled trial study protocol. BMC Public Health. 2011;11:888. PMID: 22115340.22115340

### Vitamin D Interventions

Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 2006;166(4):424-30. PMID: 16505262.16505262
Dawson-Hughes B, Harris SS, Krall EA, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 1997;337(10):670-6. PMID: 9278463.9278463
Dukas L, Bischoff HA, Lindpaintner LS, . Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 2004;52(2):230-6. PMID: 14728632.14728632
Gallagher JC, Fowler SE, Detter JR, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86(8):3618-28. PMID: 11502787.11502787
Gallagher JC, Rapuri PB, Smith LM. An age-related decrease in creatinine clearance is associated with an increase in number of falls in untreated women but not in women receiving calcitriol treatment. J Clin Endocrinol Metab. 2007;92(1):51-8. PMID: 17032712.17032712
Glendenning P, Zhu K, Inderjeeth C, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012;27(1):170-6. PMID: 21956713.21956713
Porthouse J, Cockayne S, King C, . Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330(7498):1003. PMID: 15860827.15860827
Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial.[Erratum appears in JAMA. 2010 Jun 16;303(23):2357]. JAMA. 2010;303(18):1815-22. PMID: 20460620.20460620
Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703-11. PMID: 25799402.25799402
Patil R, Kolu P, Raitanen J, . Cost-effectiveness of vitamin D supplementation and exercise in preventing injurious falls among older home-dwelling women: findings from an RCT. Osteoporos Int. 2015. PMID: 26205890.26205890
Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872.22448872

### Environment Interventions

Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728-33. PMID: 20817936.20817936
Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
Pighills AC, Torgerson DJ, Sheldon TA, . Environmental assessment and modification to prevent falls in older people.[Erratum appears in J Am Geriatr Soc. 2011 Apr;59(4):776]. J Am Geriatr Soc. 2011;59(1):26-33. PMID: 21226674.21226674
Stevens M, Holman CD, Bennett N, . Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49(11):1448-55. PMID: 11890582.11890582

### Medication Management Interventions

Blalock SJ, Casteel C, Roth MT, . Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother. 2010;8(5):428-40. PMID: 21335296.21335296
Mott DA, Martin B, Breslow R, . Impact of a medication therapy management intervention targeting medications associated with falling: Results of a pilot study. J Am Pharm Assoc. 2016;56(1):22-8. PMID: 26802916.26802916
Mott D, Martin B, Breslow R, . The development of a community-based, pharmacistprovided falls prevention MTM intervention for older adults: Relationship building, methods, and rationale. Inov Pharm. 2014;5(1):140. PMID: 25309809.25309809

### Psychological Interventions

Dorresteijn TA, Zijlstra GA, Ambergen AW, . Effectiveness of a home-based cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial.[Erratum appears in BMC Geriatr. 2016;16:108; PMID: 27220990]. BMC Geriatr. 2016;16:2. PMID: 26739339.27220990
Dorresteijn TA, Rixt Zijlstra GA, Van Haastregt JC, . Feasibility of a nurse-led in-home cognitive behavioral program to manage concerns about falls in frail older people: a process evaluation. Research in Nursing & Health. 2013;36(3):257-70. PMID: 23533013.23533013
Dorresteijn TA, Zijlstra GA, Delbaere K, . Evaluating an in-home multicomponent cognitive behavioural programme to manage concerns about falls and associated activity avoidance in frail community-dwelling older people: Design of a randomised control trial [NCT01358032]. BMC Health Serv Res. 2011;11:228. PMID: 21933436.21933436
Zijlstra GA, van Haastregt JC, Ambergen T, . Effects of a multicomponent cognitive behavioral group intervention on fear of falling and activity avoidance in communitydwelling older adults: results of a randomized controlled trial. J Am Geriatr Soc. 2009;57(11):2020-8. PMID: 19793161.19793161
Kempen GI, Oude Wesselink SF, van Haastregt JC, . Long-term effect on mortality of a multicomponent cognitive behavioural group intervention to reduce fear of falling in older adults: a randomised controlled trial. Age Ageing. 2011;40(4):519-23. PMID: 21551460.21551460

### Multiple Interventions

Clemson L, Cumming RG, Kendig H, . The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487-94. PMID: 15341550.15341550
Fitzharris MP, Day L, Lord SR, . The Whitehorse NoFalls trial: effects on fall rates and injurious fall rates. Age Ageing. 2010;39(6):728-33. PMID: 20817936.20817936
Day L, Fildes B, Gordon I, . Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. PMID: 12130606.12130606
Freiberger E, Haberle L, Spirduso WW, . Long-term effects of three multicomponent exercise interventions on physical performance and fall-related psychological outcomes in community-dwelling older adults: a randomized controlled trial. J Am Geriatr Soc. 2012;60(3):437-46. PMID: 22324753.22324753
Shumway-Cook A, Silver I, Mary L, . Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420-7. PMID: 18166695.18166695
Siegrist M, Freiberger E, Geilhof B, . Fall Prevention in a Primary Care Setting. Dtsch. 2016;113(21):365-72. PMID: 27504699.27504699
Blank WA, Freiberger E, Siegrist M, . An interdisciplinary intervention to prevent falls in community-dwelling elderly persons: protocol of a clusterrandomized trial [PreFalls]. BMC Geriatr. 2011;11:7. PMID: 21329525.21329525
Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703-11. PMID: 25799402.25799402
Patil R, Kolu P, Raitanen J, . Cost-effectiveness of vitamin D supplementation and exercise in preventing injurious falls among older home-dwelling women: findings from an RCT. Osteoporos Int. 2015. PMID: 26205890.26205890
Uusi-Rasi K, Kannus P, Karinkanta S, . Study protocol for prevention of falls: a randomized controlled trial of effects of vitamin D and exercise on falls prevention. BMC Geriatr. 2012;12:12. PMID: 22448872.22448872

### Study relevance

Drug news. Geriatrics: annual vitamin D dose increases fall risk. Nursing. 2010;40(8):18-. PMID: None.20234270
Wenger NS, Roth CP, Hall WJ, . Practice redesign to improve care for falls and urinary incontinence: primary care intervention for older patients. Arch Intern Med. 2010;170(19):1765-72. PMID: 20975026.20975026
Woo J, Hong A, Lau E, . A randomised controlled trial of Tai Chi and resistance exercise on bone health, muscle strength and balance in community-living elderly people. Age Ageing. 2007;36(3):262-8. PMID: 17356003.17356003

### Study design, not RCT

Evidence-based medicine. Single high dose vitamin D3 annually increases risk of falls and fractures in elderly women. Clinical Advisor. 2010;13(7):74-. PMID: None.
Reducing the risk of patient falls in home care. Joint Commission Perspectives on Patient Safety. 2011;11(2):6-8. PMID: None.
Exercise prevents serious injuries in women who fall. Harv Womens Health Watch. 2015;23(1):8-. PMID: 26685357.26685357
Anonymous. Raising daily dose of vitamin D can reduce fall risk in older adults. Mayo Clin Womens Healthsource. 2010;14(3):3. PMID: 20110862.20110862
Anonymous. Exercise lowers falls risk and improves life for older people. Nurs Older People. 2015;27(7):15. PMID: 26310226.
Binns E, Taylor D. The effect of the Otago Exercise Programme on strength and balance in community dwelling older women. New Zealand Journal of Physiotherapy. 2011;39(2):63-8. PMID: None.
Bischoff-Ferrari H. Health effects of vitamin D. Dermatol Ther. 2010;23(1):23-30. PMID: 20136906.20136906
Bischoff-Ferrari HA, Shao A, Dawson-Hughes B, . Benefit-risk assessment of vitamin D supplementation. Osteoporos Int. 2010;21(7):1121-32. PMID: 19957164.19957164
Bolland MJ, Bacon CJ, Horne AM, . Vitamin D insufficiency and health outcomes over 5 y in older women. Am J Clin Nutr. 2010;91(1):82-9. PMID: 19906799.19906799
Brown L, de Bruin N. A music-based multitask exercise programme is a promising intervention for improving gait, balance and fall risk in older adults... [corrected] [published erratum appears in EVID BASED NURS 2013 Apr;16(2):68]. Evid Based Nurs. 2011;14(4):108-9. PMID: 21937633.21937633
Brown S. Incidence of falls among older women in Finland unaffected by vitamin D or exercise. Post Reprod Health. 2015;21(2):47. PMID: 26269804.26269804
Callisaya ML, Blizzard L, McGinley JL, . Risk of falls in older people during fastwalking--the TASCOG study. Gait Posture. 2012;36(3):510-5. PMID: 22682610.22682610
Campbell AJ, Borrie MJ, Spears GF. Risk factors for falls in a community-based prospective study of people 70 years and older. J Gerontol. 1989;44(4):M112-M7. PMID: 2738307.2738307
Campbell AJ, Robertson MC. Fall prevention: single or multiple interventions? Single interventions for fall prevention. J Am Geriatr Soc. 2013;61(2):281-4; discussion 6-7. PMID: 23405917.23405917
Comans TA, Currin ML, Brauer SG, . Factors associated with quality of life and caregiver strain amongst frail older adults referred to a community rehabilitation service: implications for service delivery. Disabil Rehabil. 2011;33(13-14):1215-21. PMID: 20977392.20977392
Cummings SR. A single, annual, high dose of oral vitamin D increased falls and fractures in older women. ACP J Club. 2010;153(3):JC3-. PMID: None.
Dattilo J, Martire L, Gottschall J, . A Pilot Study of an Intervention Designed to Promote Walking, Balance, and Self-Efficacy in Older Adults with Fear of Falling. Educ Gerontol. 2014;40(1):26-39. PMID: None.
Davis JC, Marra CA, Liu-Ambrose TY. Falls-related self-efficacy is independently associated with quality-adjusted life years in older women. Age Ageing. 2011;40(3):340-6. PMID: 21436152.21436152
Dawson-Hughes B, Harris SS. High-dose vitamin D supplementation: too much of a good thing? JAMA. 2010;303(18):1861-2. PMID: 20460627.20460627
Elkins M. A balance retraining program reduces injurious falls and improves physical function in older women at risk of falling [synopsis]. J Physiother. 2016;62(1):48. PMID: 26701162.26701162
Figueiro MG, Gras LZ, Rea MS, . Lighting for improving balance in older adults with and without risk for falls. Age Ageing. 2012;41(3):392-5. PMID: 22166683.22166683
Fischer BL, Gleason CE, Gangnon RE, . Declining cognition and falls: role of risky performance of everyday mobility activities. Phys Ther. 2014;94(3):355-62. PMID: 24231226.24231226
Flicker L, MacInnis RJ, Stein MS, . Erratum: Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial (Journal of the American Geriatrics Society (2005) 53 (1881-1888)). J Am Geriatr Soc. 2012;60(8):1599. PMID: None.
Franco MR, Ferreira ML, Howard K, . How big does the effect of an intervention have to be? Application of two novel methods to determine the smallest worthwhile effect of a fall prevention programme: a study protocol. BMJ Open. 2013;3(2). PMID: 23388197.23388197
Franco MR, Pereira LS, Ferreira PH. Exercise interventions for preventing falls in older people living in the community. BJSM online. 2014;48(10):867-8. PMID: 23314888.23314888
Gallieni M. High-dose oral vitamin D supplementation and risk of falls in older women. JAMA. 2010;304(8):855; author reply 6-7. PMID: 20736466.20736466
Geraedts HA, Zijlstra W, Zhang W, . Adherence to and effectiveness of an individually tailored home-based exercise program for frail older adults, driven by mobility monitoring: design of a prospective cohort study. BMC Public Health. 2014;14:570. PMID: 24908049.24908049
Geusens PP. Effect of high-dose once-yearly bolus of oral vitamin D on falls and fractures in older women. Curr Osteoporos Rep. 2010;8(3):115-7. PMID: 20556672.20556672
Glade MJ. A 21st century evaluation of the safety of oral vitamin D. Nutrition. 2012;28(4):344-56. PMID: 22414585.22414585
Glade MJ. A 21st century evaluation of the safety of oral vitamin D. Nutrition. 2012;28(4):344-56. PMID: 22414585.22414585
Grabiner MD. Exercise-based fall prevention programmes decrease fall-related injuries. Evid Based Nurs. 2014;17(4):125. PMID: 24520132.24520132
Griffin M, McCormick D, Taylor MJ, . Using the Nintendo Wii as an intervention in a falls prevention group. J Am Geriatr Soc. 2012;60(2):385-7. PMID: 22332691.22332691
Halfon M, Phan O, Teta D. Vitamin D: a review on its effects on muscle strength, the risk of fall, and frailty. BioMed research international. 2015;2015:953241. PMID: 26000306.26000306
Halvarsson A, Dohrn IM, Stahle A. Taking balance training for older adults one step further: the rationale for and a description of a proven balance training programme. Clin Rehabil. 2015;29(5):417-25. PMID: 25200877.25200877
Hars M, Herrmann FR, Fielding RA, . Long-term exercise in older adults: 4-year outcomes of music-based multitask training. Calcif Tissue Int. 2014;95(5):393-404. PMID: 25148876.25148876
Hellstrom LM, Bondesson A, Hoglund P, . Impact of the Lund Integrated Medicines Management (LIMM) model on medication appropriateness and drug-related hospital revisits. Eur J Clin Pharmacol. 2011;67(7):741-52. PMID: 21318595.21318595
Hempel S, Taylor SL, Solloway MR, . VA Evidence-based Synthesis Program Reports. Evidence Map of Tai Chi. Washington (DC): Department of Veterans Affairs (US); 2014.
Hill K, Womer M, Russell M, . Fear of falling in older fallers presenting at emergency departments. J Adv Nurs. 2010;66(8):1769-79. PMID: 20557379.20557379
Hirsch C. ACP Journal Club: a balance retraining exercise program reduced injurious falls in at-risk older community-dwelling women. Annals of internal medicine. 2015;163(10):JC2. PMID: 26571256.26571256
Hong-lin C, Kun L, Qin-Sheng Y. Attention should be paid to preventing knee injury in tai chi exercise. Inj Prev. 2011;17(4):286-7. PMID: 21788230.21788230
Hung W. High-dose Vitamin D supplementation may lead to increased risk of falls. J Clin Outcomes Manag. 2016;23(2):64-5. PMID: None.
Jones G. Compared to a general wellness programme, an 18-month exercise programme for older women improves bone mineral density and fall risk but has similar improvements in predicted coronary heart disease risk. Evid Based Nurs. 2010;13(3):87-8. PMID: 20584836.20584836
Karinkanta S, Piirtola M, Sievanen H, . Physical therapy approaches to reduce fall and fracture risk among older adults. Nat Rev Endocrinol. 2010;6(7):396-407. PMID: 20517287.20517287
Kelly DM, Frick EM, Hale LS. How the medication review can help to reduce risk of falls in older patients. Jaapa. 2011;24(4):30-4, 55. PMID: 21534380.21534380
Kendrick D, Kumar A, Carpenter H, . Exercise for reducing fear of falling in older people living in the community. Cochrane Database Syst Rev. 2014;11:CD009848. PMID: 25432016.25432016
Kiel DP. Review: Exercise/physical therapy and vitamin D each reduce risk for falls in older community-dwelling adults. ACP J Club. 2011;154(4):4-. PMID: None.
Kim H, Yoshida H, Suzuki T. Falls and fractures in participants and excluded nonparticipants of a fall prevention exercise program for elderly women with a history of falls: 1-year follow-up study. Geriatr Gerontol Int. 2014;14(2):285-92. PMID: 23682858.23682858
Kristoff K. Aquatic therapy gains steam. Provider. 2011;37(12):35, 7. PMID: 22184856.22184856
Lamb SE. The case for stepped-wedge studies: a trial of falls prevention. Lancet. 2015;385(9987):2556-7. PMID: 25865866.25865866
LoPiccolo MC, Lim HW. Vitamin D in health and disease. Photodermatol Photoimmunol Photomed. 2010;26(5):224-9. PMID: 20831695.20831695
Mak JC. High-dose oral vitamin D supplementation and risk of falls in older women. JAMA. 2010;304(8):854; author reply 6-7. PMID: 20736464.20736464
Malgarini RB, Pimpinella G. High-dose oral vitamin D supplementation and risk of falls in older women. JAMA. 2010;304(8):855-6; author reply 6-7. PMID: 20736465.20736465
Milne AC, Avenell A, Potter J. Meta-analysis: protein and energy supplementation in older people. Annals of internal medicine. 2006;144(1):37-48. PMID: 16389253.16389253
Morris RL, Brand CA, Hill KD, . RESPOND: a patient-centred programme to prevent secondary falls in older people presenting to the emergency department with a fall-protocol for a mixed methods programme evaluation. Inj Prev. 2014;22(2):153-60. PMID: 25392367.25392367
Olsson Moller U, Jakobsson U. Predictive validity and cut-off scores in four diagnostic tests for falls-a study in frail older people at home. Eur Geriatr Med. 2012;3:S49. PMID: None.
Phillips CN. Modern technology and an aging population: Can the use of the Wii Fit gaming system improve functional balance in community dwelling seniors?: Utah State University; 2013.
Prieto-Alhambra D, Judge A, Pazianas M. High-dose oral vitamin D supplementation and risk of falls in older women. JAMA. 2010;304(8):854-5; author reply 6-7. PMID: 20736463.20736463
Ramsay E, Sherrington C, Close J, . A home-based exercise intervention designed to prevent falls in older people recently discharged from hospital: Overview, safety and adherence. Physiotherapy. 2011;97:eS1034. PMID: None.
Ray C, Melton F, Ramirez R, . The Effects of a 15-Week Exercise Intervention on Fitness and Postural Control in Older Adults. Act Adapt Aging. 2012;36(3):227-41. PMID: None.
Robbins J. Review: High-dose oral vitamin D supplements and active vitamin D prevent falls in older persons. ACP J Club. 2010;152(1):3p. PMID: None.
Robien K, Oppeneer SJ, Kelly JA, . Drug-vitamin D interactions: a systematic review of the literature. Nutr Clin Pract. 2013;28(2):194-208. PMID: 23307906.23307906
Rosen CJ. Vitamin D and falls--are intermittent, high doses better? Nat Rev Endocrinol. 2011;7(12):695-6. PMID: 22045105.22045105
Salonoja M, Salminen M, Vahlberg T, . Withdrawal of psychotropic drugs decreases the risk of falls requiring treatment. Arch Gerontol Geriatr. 2012;54(1):160-7. PMID: 21420744.21420744
Schacht E, Ringe JD. Alfacalcidol improves muscle power, muscle function and balance in elderly patients with reduced bone mass. Rheumatol Int. 2012;32(1):207-15. PMID: 20827552.20827552
Sengul Aycicek G, Arik G, Canbaz B, . Effect of Multimodal Exercise Program on Physical Function, Falls, and Injuries in Older Women. Journal of the American Geriatrics Society. 2016;64(2):458. PMID: 26889865.26889865
Smith ML, Jiang L, Ory MG. Falls efficacy among older adults enrolled in an evidencebased program to reduce fall-related risk: sustainability of individual benefits over time. Fam Community Health. 2012;35(3):256-63. PMID: 22617416.22617416
Smith ST, Davies TA, Lennox J. Step Training System: an ICT solution to measure and reduce fall risk in older adults. Conf Proc IEEE Eng Med Biol Soc. 2013;2013:7033-5. PMID: 24111364.24111364
Speechley M, Belfry S, Borrie MJ, . Risk factors for falling among community-dwelling veterans and their caregivers. Can J Aging. 2005;24(3):261-74. PMID: 16421850.16421850
Tiedemann A. A balance retraining program reduces injurious falls and improves physical function in older women at risk of falling [commentary]. Journal of Physiotherapy. 2016;62(1):48. PMID: 26687950.26687950
Tinetti ME. Performance-oriented assessment of mobility problems in elderly patients. J Am Geriatr Soc. 1986;34(2):119-26. PMID: 3944402.3944402
Tricco AC, Cogo E, Holroyd-Leduc J, . Efficacy of falls prevention interventions: protocol for a systematic review and network meta-analysis. Syst Rev. 2013;2:38. PMID: 23738619.23738619
Underwood MR, Parsons S, Eldridge SM, . Asking older people about fear of falling did not have a negative effect. J Clin Epidemiol. 2006;59(6):629-34. PMID: 16713526.16713526
Vaapio S, Salminen M, Vahlberg T, . Increased muscle strength improves managing in activities of daily living in fall-prone community-dwelling older women. Aging Clin Exp Res. 2011;23(1):42-8. PMID: 20154505.20154505
van Hateren KJ, Kamper AM, Bilo HJ. Lack of evaluation of the effects of single preventive measures for falling. Arch Intern Med. 2011;171(2):181-2. PMID: 21263113.21263113
Vind AB, Andersen HE, Pedersen KD, . Baseline and follow-up characteristics of participants and nonparticipants in a randomized clinical trial of multifactorial fall prevention in Denmark. J Am Geriatr Soc. 2009;57(10):1844-9. PMID: 19682128.19682128
Waldron N, Dey I, Nagree Y, . A multi-faceted intervention to implement guideline care and improve quality of care for older people who present to the emergency department with falls. BMC Geriatrics. 2011;11(6). PMID: 21281473.21281473
Yamada M, Arai H, Uemura K, . Effect of resistance training on physical performance and fear of falling in elderly with different levels of physical well-being. Age Ageing. 2011;40(5):637-41. PMID: 21729926.21729926
Yeung PY, Chan W, Woo J. A community-based Falls Management Exercise Programme (FaME) improves balance, walking speed and reduced fear of falling. Prim Health Care Res Dev. 2015;16(2):138-46. PMID: 24480023.24480023
Yount J. Strength in Numbers: A Community Education Program to Prevent Falls in Older Adults. Home healthc. 2016;34(7):369-75. PMID: 27348030.27348030
Zanetos JM, Lux KM, Richardson LC. Testing the effects of a pharmaceutical program on fall rates in older adults. J Nurses Prof Dev. 2014;30(3):143-8. PMID: 24845093.24845093

### Falls not primary or secondary aim

Bea JW, Zhao Q, Cauley JA, . Effect of hormone therapy on lean body mass, falls, and fractures: 6-year results from the Women’s Health Initiative hormone trials. Menopause. 2011;18(1):44-52. PMID: 20689466.20689466
Bird ML, Hill KD, Fell JW. A randomized controlled study investigating static and dynamic balance in older adults after training with Pilates. Arch Phys Med Rehabil. 2012;93(1):43-9. PMID: 21975148.21975148
Dangour AD, Albala C, Allen E, . Effect of a nutrition supplement and physical activity program on pneumonia and walking capacity in Chilean older people: a factorial cluster randomized trial. PLoS Med. 2011;8(4):e1001023. PMID: 21526229.21526229
DiGuiseppi CG, Thoreson SR, Clark L, . Church-based social marketing to motivate older adults to take balance classes for fall prevention: cluster randomized controlled trial. Prev Med. 2014;67:75-81. PMID: 25025522.25025522
Duckham RL, Masud T, Taylor R, . Randomised controlled trial of the effectiveness of community group and home-based falls prevention exercise programmes on bone health in older people: the ProAct65+ bone study. Age Ageing. 2015;44(4):573-9. PMID: 25906791.25906791
Gallagher J, Sai A, Templin T, . Dose response to vitamin D supplementation in postmenopausal women a randomized trial. Annals of internal medicine. 2012;156(6):425-37. PMID: 22431675.22431675
Granacher U, Muehlbauer T, Bridenbaugh SA, . Effects of a salsa dance training on balance and strength performance in older adults. Gerontology. 2012;58(4):305-12. PMID: 22236951.22236951
Halvarsson A, Oddsson L, Olsson E, . Effects of new, individually adjusted, progressive balance group training for elderly people with fear of falling and tend to fall: a randomized controlled trial.[Erratum appears in Clin Rehabil. 2012 Nov;26(11):1055 Note: Oddsson, Lars [added]]. Clin Rehabil. 2011;25(11):1021-31. PMID: 21849377.21849377
Kim SB, O’Sullivan D M. Effects of Aqua Aerobic Therapy Exercise for Older Adults on Muscular Strength, Agility and Balance to Prevent Falling during Gait. J Phys Ther Sci. 2013;25(8):923-7. PMID: 24259886.24259886
Kloubec JA, Rozga M, Block M. Balance Improvements in Independent-Living Elderly Adults Following a 12-Week Structured Exercise Program. Act Adapt Aging. 2012;36(2):167-78. PMID: None.
Lagari VS, Gomez-Marin O, Levis S. Study design and baseline characteristics of participants in the Vitamin D in Vulnerable Adults at the VA (the VIVA Study). Contemp Clin Trials. 2014;39(1):66-73. PMID: 25093912.25093912
Lee IH, Park SY. Balance improvement by strength training for the elderly. J Phys Ther Sci. 2013;25(12):1591-3. PMID: 24409027.24409027
Maciaszek J, Osinski W. Effect of Tai Chi on Body Balance:: Randomized Controlled Trial in Elderly Men with Dizziness. Am J Chin Med. 2012;40(2):245-53. PMID: 22419420.22419420
Manor B, Lough M, Gagnon MM, . Functional benefits of tai chi training in senior housing facilities. J Am Geriatr Soc. 2014;62(8):1484-9. PMID: 25116984.25116984
Manson JE, Bassuk SS, Lee IM, . The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012;33(1):159-71. PMID: 21986389.21986389
McMurdo ME, Sugden J, Argo I, . Do pedometers increase physical activity in sedentary older women? A randomized controlled trial. J Am Geriatr Soc. 2010;58(11):2099-106. PMID: 21054290.21054290
Mendoza-Ruvalcaba NM, Arias-Merino ED. “I am active”: effects of a program to promote active aging. Clin Interv Aging. 2015;10:829-37. PMID: 26005337.26005337
Metzelthin SF, Rossum E, Witte LP, . Effectiveness of interdisciplinary primary care approach to reduce disability in community dwelling frail older people: Cluster randomised controlled trial. BMJ. 2013;347:f5264. PMID: 24022033.24022033
Oh DH, Park JE, Lee ES, . Intensive exercise reduces the fear of additional falls in elderly people: findings from the Korea falls prevention study. Korean J Intern Med. 2012;27(4):417-25. PMID: 23269883.23269883
Pekkarinen T, Loyttyniemi E, Valimaki M. Hip fracture prevention with a multifactorial educational program in elderly community-dwelling Finnish women. Osteoporos Int. 2013;24(12):2983-92. PMID: 23652464.23652464
Scheffer AC, Scholte op Reimer WJ, van Dijk N, . Effect of a mobile safety alarm on going outside, feeling safe, fear of falling, and quality of life in community-living older persons: a randomized controlled trial. J Am Geriatr Soc. 2012;60(5):987-9. PMID: 22587862.22587862
Smith-Ray RL, Makowski-Woidan B, Hughes SL. A randomized trial to measure the impact of a community-based cognitive training intervention on balance and gait in cognitively intact Black older adults. Health Educ Behav. 2014;41(1 Suppl):62S-9S. PMID: 25274713.25274713
Szanton SL, Thorpe RJ, Boyd C, . Community aging in place, advancing better living for elders: a bio-behavioral-environmental intervention to improve function and health-related quality of life in disabled older adults. J Am Geriatr Soc. 2011;59(12):2314-20. PMID: 22091738.22091738
Tamblyn R, Eguale T, Buckeridge DL, . The effectiveness of a new generation of computerized drug alerts in reducing the risk of injury from drug side effects: a cluster randomized trial. J Am Med Inform Assoc. 2012;19(4):635-43. PMID: 22246963.22246963
Tiedemann A, O’Rourke S, Sesto R, . A 12-week Iyengar yoga program improved balance and mobility in older community-dwelling people: a pilot randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2013;68(9):1068-75. PMID: 23825035.23825035
Uzor S, Baillie L, Skelton DA, . Falls prevention advice and visual feedback to those at risk of falling: study protocol for a pilot randomized controlled trial. Trials. 2013;14:79. PMID: 23510162.23510162
Vogler CM, Menant JC, Sherrington C, . Evidence of detraining after 12-week homebased exercise programs designed to reduce fall-risk factors in older people recently discharged from hospital. Arch Phys Med Rehabil. 2012;93(10):1685-91. PMID: 22504154.22504154
Wayne PM, Kiel DP, Buring JE, . Impact of Tai Chi exercise on multiple fracture-related risk factors in post-menopausal osteopenic women: a pilot pragmatic, randomized trial. BMC Complement Altern Med. 2012;12:7. PMID: 22289280.22289280
Yamada M, Aoyama T, Hikita Y, . Effects of a DVD-based seated dual-task stepping exercise on the fall risk factors among community-dwelling elderly adults. Telemed J E Health. 2011;17(10):768-72. PMID: 22011054.22011054
Yang XJ, Hill K, Moore K, . Effectiveness of a targeted exercise intervention in reversing older people’s mild balance dysfunction: a randomized controlled trial. Phys Ther. 2012;92(1):24-37. PMID: 21979272.21979272
Ziden L, Haggblom-Kronlof G, Gustafsson S, . Physical function and fear of falling 2 years after the health-promoting randomized controlled trial: elderly persons in the risk zone. Gerontologist. 2014;54(3):387-97. PMID: 23906550.23906550

### Not a very high HDI country

Almeida TL, Alexander NB, Nyquist LV, . Minimally supervised multimodal exercise to reduce falls risk in economically and educationally disadvantaged older adults. J Aging Phys Act. 2013;21(3):241-59. PMID: 22952201.22952201
Ansai JH, Aurichio TR, Goncalves R, . Effects of two physical exercise protocols on physical performance related to falls in the oldest old: A randomized controlled trial. Geriatr Gerontol Int. 2015;16(4):492-9. PMID: 25868484.25868484
Asmidawati A, Hamid TA, Hussain RM, . Home based exercise to improve turning and mobility performance among community dwelling older adults: protocol for a randomized controlled trial. BMC Geriatr. 2014;14:100. PMID: 25196930.25196930
Avelar NC, Bastone AC, Alcantara MA, . Effectiveness of aquatic and non-aquatic lower limb muscle endurance training in the static and dynamic balance of elderly people. Rev Bras Fisioter. 2010;14(3):229-36. PMID: 20730368.20730368
Cangussu L, Nahas-Neto J, Omodei M, . Effect of vitamin d supplementation on the rate of falls and the postural balance in postmenopausal women: Randomized double-blind placebo controlled trial. Climacteric. 2014;17:103. PMID: None.24571033
Kuptniratsaikul V, Praditsuwan R, Assantachai P, . Effectiveness of simple balancing training program in elderly patients with history of frequent falls. Clin Interv Aging. 2011;6:111-7. PMID: 21594001.21594001
Li Z, Changshui W, Yao H. Effects of different interventions on falls and falls-related functional factors in veteran elderly: A pilot randomized controlled trial. Ann Rehabil Med. 2014;57:e153. PMID: None.
Moreira L, Fronza FC, dos Santos RN, . High-intensity aquatic exercises (HydrOS) improve physical function and reduce falls among postmenopausal women. Menopause. 2013;20(10):1012-9. PMID: 23531689.23531689
Sakalli H, Arslan D, Yucel AE. The effect of oral and parenteral vitamin D supplementation in the elderly: a prospective, double-blinded, randomized, placebo-controlled study. Rheumatol Int. 2012;32(8):2279-83. PMID: 21556746.21556746
Teixeira LE, Silva KN, Imoto AM, . Progressive load training for the quadriceps muscle associated with proprioception exercises for the prevention of falls in postmenopausal women with osteoporosis: a randomized controlled trial. Osteoporos Int. 2010;21(4):589-96. PMID: 19562243.19562243
Wu HY, Tu JH, Hsu CH, . Effects of Low-Impact Dance on Blood Biochemistry, Bone Mineral Density, the Joint Range of Motion of Lower Extremities, Knee Extension Torque, and Fall in Females. Journal of Aging & Physical Activity. 2016;24(1):1-7. PMID: 25642949.25642949
Xiao CM. Effects of long-term tai chi ball practice on balance performance in older adults. J Am Geriatr Soc. 2014;62(5):984-5. PMID: 24828932.24828932
Yadegaripour M, Sadeghi H, Shojaedin SS, . Effects of a combined aquatic-nonaquatic training program on static and dynamic balance in elderly men. J Am Geriatr Soc. 2013;61(8):1417-9. PMID: 23937494.23937494

### Setting: not primary care referable/feasible

Babine RL, Farrington S, Wierman HR. HELP© prevent falls by preventing delirium. Nursing. 2013;43(5):18-21. PMID: 23598631.23598631
Dyer CA, Taylor GJ, Reed M, . Falls prevention in residential care homes: a randomised controlled trial. Age Ageing. 2004;33(6):596-602. PMID: 15381507.15381507
Guse CE, Peterson DJ, Christiansen AL, . Translating a Fall Prevention Intervention Into Practice: A Randomized Community Trial. Am J Public Health. 2015;105(7):1475-81. PMID: 25602891.25602891
Loffler C, Drewelow E, Paschka SD, . Optimizing polypharmacy among elderly hospital patients with chronic diseases--study protocol of the cluster randomized controlled POLITERCT trial. Implement Sci. 2014;9:151. PMID: 25287853.25287853
Saravanakumar P, Higgins IJ, van der Riet PJ, . The influence of tai chi and yoga on balance and falls in a residential care setting: A randomised controlled trial. Contemp Nurse. 2014;48(1):76-87. PMID: 25410198.25410198
Saravanakumar P, Higgins IJ, Van Der Riet PJ, . The influence of tai chi and yoga on balance and falls in a residential care setting: a randomised controlled trial. Contemp Nurse. 2014:5231-55. PMID: 25055894.25055894
Teut M, Schnabel K, Baur R, . Effects and feasibility of an Integrative Medicine program for geriatric patients- A cluster-randomized pilot study. Clin Interv Aging. 2013;8:953-61. PMID: 23901266.23901266

### Adults <65 years

Keall MD, Pierse N, Howden-Chapman P, . Home modifications to reduce injuries from falls in the home injury prevention intervention (HIPI) study: a cluster-randomised controlled trial. Lancet. 2015;385(9964):231-8. PMID: 25255696.25255696
Wood AD, Secombes KR, Thies F, . A parallel group double-blind RCT of vitamin D3 assessing physical function: is the biochemical response to treatment affected by overweight and obesity? Osteoporos Int. 2014;25(1):305-15. PMID: 23982800.23982800

### Population not trepresentative of general primary care population

Ashburn A, Fazakarley L, Ballinger C, . A randomised controlled trial of a home based exercise programme to reduce the risk of falling among people with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 2007;78(7):678-84. PMID: 17119004.17119004
Avenell A, Mak Jenson CS, O’Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database Syst Rev. 2014(4):CD000227. PMID: 24729336.24729336
Bjelakovic G, Gluud Lise L, Nikolova D, . Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2014(1):CD007470. PMID: 24414552.24414552
Bosner S, Keller H, Wohner A, . Prevention of falls by outdoor-walking in elderly persons at risk (‘power’) - A pilot study. Eur Geriatr Med. 2012;3(1):28-32. PMID: None.
Campbell AJ, Robertson MC, La Grow SJ, . Randomised controlled trial of prevention of falls in people aged > or =75 with severe visual impairment: the VIP trial. BMJ. 2005;331(7520):817. PMID: 16183652.16183652
Cranney A, Horsley T, O’Donnell S, . Effectiveness and safety of vitamin D in relation to bone health. Evid Rep Technol Assess. 2007(158):1-235. PMID: 18088161.18088161
Dhesi JK, Jackson SH, Bearne LM, . Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 2004;33(6):589-95. PMID: 15501836.15501836
Faes MC, Reelick MF, Melis RJ, . Multifactorial fall prevention for pairs of frail community-dwelling older fallers and their informal caregivers: a dead end for complex interventions in the frailest fallers. J Am Med Dir Assoc. 2011;12(6):451-8. PMID: 21450224.21450224
Gaboury I, Corriveau H, Boire G, . Partnership for fragility bone fracture care provision and prevention program (P4Bones): study protocol for a secondary fracture prevention pragmatic controlled trial. Implement Sci. 2013;8:10. PMID: 23343392.23343392
Green J, Forster A, Bogle S, . Physiotherapy for patients with mobility problems more than 1 year after stroke: a randomised controlled trial. Lancet. 2002;359(9302):199-203. PMID: 11812553.11812553
Hansen KE, Johnson RE, Chambers KR, . Treatment of Vitamin D Insufficiency in Postmenopausal Women: A Randomized Clinical Trial. JAMA Intern Med. 2015;175(10):1612-21. PMID: 26237520.26237520
Juola AL, Bjorkman MP, Pylkkanen S, . Nurse Education to Reduce Harmful Medication Use in Assisted Living Facilities: Effects of a Randomized Controlled Trial on Falls and Cognition. Drugs Aging. 2015;32(11):947-55. PMID: 26446153.26446153
Korpelainen R, Keinanen-Kiukaanniemi S, Nieminen P, . Long-term outcomes of exercise: follow-up of a randomized trial in older women with osteopenia. Arch Intern Med. 2010;170(17):1548-56. PMID: 20876406.20876406
Kronhed AG, Hallberg I, dkvist L, . Effect of training on health-related quality of life, pain and falls in osteoporotic women. Adv Physiother. 2009;11(3):154-65. PMID: None.
Lark SD, Wadsworth DP. Physiological, psychological and functional changes with Whole Body Vibration Exercise in the Elderly: FEVER methodology and protocols. Contemp Clin Trials. 2015. PMID: 26275340.26275340
LeBlanc E, Chou R, Zakher B, . Screening for Vitamin D Deficiency: Systematic Review for the U.S. Preventive Services Task Force Recommendation. Rockville MD2014. PMID: 25521000.25521000
LeBlanc ES, Zakher B, Daeges M, . Screening for vitamin D deficiency: a systematic review for the U.S. Preventive Services Task Force. Annals of internal medicine. 2015;162(2):109-22. PMID: 25419719.25419719
Lee HC, Chang KC, Tsauo JY, . Effects of a multifactorial fall prevention program on fall incidence and physical function in community-dwelling older adults with risk of falls. Arch Phys Med Rehabil. 2013;94(4):606-15, 15.e1. PMID: 23220343.23220343
Menz HB, Spink MJ, Landorf KB, . Older people’s perceptions of a multifaceted podiatric medical intervention to prevent falls. J Am Podiatr Med Assoc. 2013;103(6):457-64. PMID: 24297981.24297981
Peri K, Kerse N, Robinson E, . Does functionally based activity make a difference to health status and mobility? A randomised controlled trial in residential care facilities (The Promoting Independent Living Study; PILS). Age Ageing. 2008;37(1):57-63. PMID: 17965045.17965045
Pfeifer M, Begerow B, Minne HW, . Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15(6):1113-8. PMID: 10841179.10841179
Pfeifer M, Begerow B, Minne HW, . Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20(2):315-22. PMID: 18629569.18629569
Potter K, Flicker L, Page A, . Deprescribing in Frail Older People: A Randomised Controlled Trial. PLoS One. 2016;11(3):e0149984. PMID: 26942907.26942907
Prince RL, Austin N, Devine A, . Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008;168(1):103-8. PMID: 18195202.18195202
Sakamoto K, Endo N, Harada A, . Why not use your own body weight to prevent falls? A randomized, controlled trial of balance therapy to prevent falls and fractures for elderly people who can stand on one leg for <15 s.[Erratum appears in J Orthop Sci. 2014 Mar;19(2):373-4]. J Orthop Sci. 2013;18(1):110-20. PMID: 23138409.23138409
Sambrook PN, Cameron ID, Chen JS, . Does increased sunlight exposure work as a strategy to improve vitamin D status in the elderly: a cluster randomised controlled trial. Osteoporos Int. 2012;23(2):615-24. PMID: 21369788.21369788
Smulders E, Weerdesteyn V, Groen BE, . Efficacy of a short multidisciplinary falls prevention program for elderly persons with osteoporosis and a fall history: a randomized controlled trial. Arch Phys Med Rehabil. 2010;91(11):1705-11. PMID: 21044715.21044715
van Wijngaarden JP, Dhonukshe-Rutten RA, van Schoor NM, . Rationale and design of the B-PROOF study, a randomized controlled trial on the effect of supplemental intake of vitamin B12 and folic acid on fracture incidence. BMC Geriatr. 2011;11:80. PMID: 22136481.22136481
Yokoi K, Yoshimasu K, Takemura S, . Short stick exercises for fall prevention among older adults: a cluster randomized trial. Disabil Rehabil. 2015;37(14):1268-76. PMID: 25243769.25243769

### No relevant outcomes

Barker AL, Cameron PA, Hill KD, . RESPOND--A patient-centred programme to prevent secondary falls in older people presenting to the emergency department with a fall: protocol for a multicentre randomised controlled trial. Inj Prev. 2015;21(1):e1. PMID: 24958769.24958769
Barker AL, McNeil JJ, Seeman E, . A randomised controlled trial of low-dose aspirin for the prevention of fractures in healthy older people: protocol for the ASPREE-Fracture substudy. Inj Prev. 2015;22(4):297-301. PMID: 26002770.26002770
Bergman GJ, Fan T, McFetridge JT, . Efficacy of vitamin D3 supplementation in preventing fractures in elderly women: a meta-analysis. Curr Med Res Opin. 2010;26(5):1193-201. PMID: 20302551.20302551
Bolland MJ, Grey A, Gamble GD, . Vitamin D supplementation and falls: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014;2(7):573-80. PMID: 24768505.24768505
Bruce J, Lall R, Withers EJ, . A cluster randomised controlled trial of advice, exercise or multifactorial assessment to prevent falls and fractures in community-dwelling older adults: protocol for the prevention of falls injury trial (PreFIT). BMJ Open. 2016;6(1):e009362. PMID: 26781504.26781504
Clarke R, Newman C, Tomson J, . Estimation of the optimum dose of vitamin D for disease prevention in older people: rationale, design and baseline characteristics of the BEST-D trial. Maturitas. 2015;80(4):426-31. PMID: 25721698.25721698
Cockayne S, Adamson J, Corbacho Martin B, . The REFORM study protocol: a cohort randomised controlled trial of a multifaceted podiatry intervention for the prevention of falls in older people. BMJ Open. 2014;4(12):e006977. PMID: 25518875.25518875
Daly RM, Duckham RL, Tait JL, . Effectiveness of dual-task functional power training for preventing falls in older people: study protocol for a cluster randomised controlled trial. Trials. 2015;16:120. PMID: 25872612.25872612
Delbaere K, Valenzuela T, Woodbury A, . Evaluating the effectiveness of a home-based exercise programme delivered through a tablet computer for preventing falls in older community-dwelling people over 2 years: study protocol for the Standing Tall randomised controlled trial. BMJ Open. 2015;5(10):e009173. PMID: 26493461.26493461
Fairhall N, Kurrle SE, Sherrington C, . Effectiveness of a multifactorial intervention on preventing development of frailty in pre-frail older people: Study protocol for a randomised controlled trial. BMJ Open. 2015;5(2). PMID: 25667151.25667151
Farag I, Howard K, Hayes AJ, . Cost-effectiveness of a Home-Exercise Program Among Older People After Hospitalization. J Am Med Dir Assoc. 2015;16(6):490-6. PMID: 25703448.25703448
Freiberger E, Monika S. Fall prevention in the general practitioners setting: A cluster randomized controlled study-PreFall (NCT01032252). Eur Geriatr Med. 2013;4:S10. PMID: None.
Grimmer K, Luker J, Beaton K, . TRialing individualized interventions to prevent functional decline in at-risk older adults (TRIIFL): study protocol for a randomized controlled trial nested in a longitudinal observational study. Trials. 2013;14:266. PMID: 23962259.23962259
Gustafson DH, Sr., McTavish F, Gustafson DH, Jr., . The effect of an information and communication technology (ICT) on older adults’ quality of life: study protocol for a randomized control trial. Trials. 2015;16:191. PMID: 25909465.25909465
Hars M, Herrmann FR, Gold G, . Effect of music-based multitask training on cognition and mood in older adults. Age Ageing. 2014;43(2):196-200. PMID: 24212920.24212920
Hartholt KA, Boye ND, Van der Velde N, . [Cost] effectiveness of withdrawal of fallrisk increasing drugs versus conservative treatment in older fallers: design of a multicenter randomized controlled trial (IMPROveFALL-study). BMC Geriatr. 2011;11:48. PMID: 21854643.21854643
Heiden E, Lajoie Y. Games-based biofeedback training and the attentional demands of balance in older adults. Aging Clin Exp Res. 2010;22(5/6):367-73. PMID: 20009499.20009499
Kalyani RR, Stein B, Valiyil R, . Vitamin D treatment for the prevention of falls in older adults: systematic review and meta-analysis. J Am Geriatr Soc. 2010;58(7):1299-310. PMID: 20579169.20579169
Liu-Ambrose T, Davis JC, Hsu CL, . Action seniors! - secondary falls prevention in community-dwelling senior fallers: study protocol for a randomized controlled trial. Trials. 2015;16:144. PMID: 25873254.25873254
Lopez-Torres Hidalgo J, Group A. Prevention of falls and fractures in old people by administration of calcium and vitamin D, randomized clinical trial. BMC Public Health. 2011;11:910. PMID: 22151975.22151975
McTavish F, Gustafson DH, Mahoney JE, . The effect of an information and communication technology (ICT) on older adults’ quality of life: Study protocol for a randomized control trial. Trials. 2015;16:191. PMID: 25909465.25909465
Merom D, Cumming R, Mathieu E, . Can social dancing prevent falls in older adults? a protocol of the Dance, Aging, Cognition, Economics (DAnCE) fall prevention randomised controlled trial. BMC Public Health. 2013;13:477. PMID: 23675705.23675705
Mikolaizak AS, Simpson PM, Tiedemann A, . Intervention to prevent further falls in older people who call an ambulance as a result of a fall: a protocol for the iPREFER randomised controlled trial. BMC Health Serv Res. 2013;13:360. PMID: 24070456.24070456
Montero-Alia P, Munoz-Ortiz L, Jimenez-Gonzalez M, . Study protocol of a randomized clinical trial evaluating the effectiveness of a primary care intervention using the NintendoTM Wii console to improve balance and decrease falls in the elderly. BMC Geriatr. 2016;16:8. PMID: 26796956.26796956
Muir SW, Montero-Odasso M. Effect of Vitamin D Supplementation on Muscle Strength, Gait and Balance in Older Adults: A Systematic Review and Meta-Analysis. J Am Geriatr Soc. 2011;59(12):2291-300. PMID: 22188076.22188076
Murad MH, Elamin KB, Abu Elnour NO, . Clinical review: The effect of vitamin D on falls: a systematic review and meta-analysis. J Clin Endocrinol Metab. 2011;96(10):2997-3006. PMID: 21795448.21795448
Romera L, Orfila F, Segura JM, . Effectiveness of a primary care based multifactorial intervention to improve frailty parameters in the elderly: a randomised clinical trial: rationale and study design. BMC Geriatr. 2014;14:125. PMID: 25427568.25427568
Sales MP, Polman R, Hill KD, . A novel dynamic exercise initiative for older people to improve health and well-being: study protocol for a randomised controlled trial. BMC Geriatr. 2015;15:68. PMID: 26104031.26104031
Sanders K, Stuart AL, Williamson EJ, . The efficacy of high-dose oral vitamin D3 administered once a year: A randomised, double-blind, placebo-controlled trial (vital D study) for falls and fractures in older women. J Bone Miner Res. 2010;25:S50. PMID: None.
Scheffer A, Scholte op Reimer W, van Dijk N, . Safety for older persons; effectiveness of a mobile safety alarm... Fourth European Nursing Congress. J Clin Nurs. 2010;19:38-. PMID: None.
Scragg R, Waayer D, Stewart AW, . The Vitamin DAssessment (ViDA) Study: design of a randomized controlled trial of vitamin D supplementation for the prevention of cardiovascular disease, acute respiratory infection, falls and non-vertebral fractures. J Steroid Biochem Mol Biol. 2015. PMID: 26365555.26365555
Sherrington C, Fairhall N, Kirkham C, . Exercise and fall prevention self-management to reduce mobility-related disability and falls after fall-related lower limb fracture in older people: protocol for the RESTORE (Recovery Exercises and STepping On afteR fracturE) randomised controlled trial. BMC Geriatrics. 2016;16:34. PMID: 26838998.26838998
Skelton DA, Bailey C, Howel D, . Visually Impaired OLder people’s Exercise programme for falls prevenTion (VIOLET): a feasibility study protocol. BMJ Open. 2016;6(8):e011996. PMID: 27486124.27486124
Soto-Varela A, Gayoso-Diz P, Rossi-Izquierdo M, . Reduction of falls in older people by improving balance with vestibular rehabilitation (ReFOVeRe study): design and methods. Aging Clin Exp Res. 2015;27(6):841-8. PMID: 25911608.25911608
Stevens JA, Mahoney JE, Ehrenreich H. Circumstances and outcomes of falls among high risk community-dwelling older adults. Injury epidemiology. 2014;1(5). PMID: 26744637.26744637
Stineman MG, Strumpf N, Kurichi JE, . Attempts to reach the oldest and frailest: recruitment, adherence, and retention of urban elderly persons to a falls reduction exercise program. Gerontologist. 2011;51 Suppl 1:S59-72. PMID: 21565820.21565820
Theodoratou E, Tzoulaki I, Zgaga L, . Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014;348:g2035. PMID: 24690624.24690624
Tiedemann A, Paul S, Ramsay E, . What is the effect of a combined physical activity and fall prevention intervention enhanced with health coaching and pedometers on older adults’ physical activity levels and mobility-related goals? Study protocol for a randomised controlled trial. BMC Public Health. 2015;15:477. PMID: 25956926.25956926
Tiedemann A, Rissel C, Howard K, . Health coaching and pedometers to enhance physical activity and prevent falls in community-dwelling people aged 60 years and over: study protocol for the Coaching for Healthy AGEing (CHAnGE) cluster randomised controlled trial. BMJ Open. 2016;6(5):e012277. PMID: 27165652.27165652
van der Meer HG, Wouters H, van Hulten R, . Decreasing the load? Is a Multidisciplinary Multistep Medication Review in older people an effective intervention to reduce a patient’s Drug Burden Index? Protocol of a randomised controlled trial. BMJ Open. 2015;5(12):e009213. PMID: 26700279.26700279
Zheng YT, Cui QQ, Hong YM, . A meta-analysis of high dose, intermittent vitamin D supplementation among older adults. PLoS ONE. 2015;10(1):e0115850. PMID: 25602255.25602255
Zijlstra GA, van Haastregt JC, van Eijk JT, . Mediating effects of psychosocial factors on concerns about falling and daily activity in a multicomponent cognitive behavioral group intervention. Aging Ment Health. 2011;15(1):68-77. PMID: 20924813.20924813

### No additional relevant data (primary article included)

Dorresteijn TA, Zijlstra GA, Ambergen AW, . Erratum to: Effectiveness of a homebased cognitive behavioral program to manage concerns about falls in community-dwelling, frail older people: results of a randomized controlled trial. BMC Geriatr. 2016;16(1):108. PMID: 27220990.27220990
Iliffe S, Kendrick D, Morris R, . Promoting physical activity in older people in general practice: ProAct65+ cluster randomised controlled trial. Br J Gen Pract. 2015;65(640):e731-8. PMID: 26500320.26500320
Irvine L, Conroy SP, Sach T, . Cost-effectiveness of a day hospital falls prevention programme for screened community-dwelling older people at high risk of falls. Age Ageing. 2010;39(6):710-6. PMID: 20833862.20833862
Keall MD, Pierse N, Howden-Chapman P, . Cost-benefit analysis of fall injuries prevented by a programme of home modifications: a cluster randomised controlled trial. Inj Prev. 2016. PMID: 27312961.27312961
Kojima G, Bowling A, Iliffe S. 71 effects of multicentre cluster randomised controlled trial of group- and home-based exercise programmes on quality of life among communitydwelling older people: the PROACT65+ Trial - British Geriatrics Society Communications to the Spring Meeting 23 – 25 April 2014 Manchester, England. Age Ageing. 2014;43(suppl2):ii21-ii. PMID: None.
Palvanen M, Kannus P, Parkkari J, . The chaos clinic-a randomized controlled trial of a falls clinic for prevention of falls and related fractures. Osteoporos Int. 2011;22:S651. PMID: None.
Palvanen M, Kannus P, Piirtola M, . The chaos falls clinic in preventing falls and injuries among home-dwelling older adults: A randomised controlled trial. Osteoporos Int. 2012;23:S140. PMID: None.
Patil R, Uusi-Rasi K, Tokola K, . Effects of a Multimodal Exercise Program on Physical Function, Falls, and Injuries in Older Women: A 2-Year Community-Based, Randomized Controlled Trial. J Am Geriatr Soc. 2015;63(7):1306-13. PMID: 26115073.26115073
Sach TH, Logan PA, Coupland CA, . Community falls prevention for people who call an emergency ambulance after a fall: an economic evaluation alongside a randomised controlled trial. Age Ageing. 2012;41(5):635-41. PMID: 22695789.22695789
Trombetti A, Hars M, Bianco S, . A randomized controlled trial of music-based multitask training on gait, balance and falls risk. J Bone Miner Res. 2010;25:S210. PMID: None.

### Only intermediate outcomes reported

Brooke-Wavell K, Duckham RL, Taylor R, . Effectiveness of community group and home based falls prevention exercise programmes on bone health in older people: The proact65+ bone study. Osteoporos Int. 2014;25(6 suppl. 1):S676. PMID: None.
Casteel C, Blalock SJ, Ferreri S, . Implementation of a community pharmacy-based falls prevention program. Am J Geriatr Pharmacother. 2011;9(5):310-9.e2. PMID: 21925959.21925959
Celletti C, Fattorini L, Camerota F, . Focal muscle vibration as a possible intervention to prevent falls in elderly women: a pragmatic randomized controlled trial. Aging Clin Exp Res. 2015;27(6):857-63. PMID: 25850540.25850540
Chang M, Huang YH, Jung H. The effectiveness of the exercise education programme on fall prevention of the community-dwelling elderly: A preliminary study. Hong Kong Journal of Occupational Therapy. 2011;21(2):56-63. PMID: None.
Dae-Sik K, Dae-In J, Mi-Ae J. Analysis of Core Stability Exercise Effect on the Physical and Psychological Function of Elderly Women Vulnerable to Falls during Obstacle Negotiation. J Phys Ther Sci. 2014;26(11):1697-700. PMID: 25435680.25435680
Donath L, Faude O, Bridenbaugh SA, . Transfer effects of fall training on balance performance and spatiotemporal gait parameters in healthy community-dwelling older adults: a pilot study. J Aging Phys Act. 2014;22(3):324-33. PMID: 23881433.23881433
Freiberger E, Blank WA, Salb J, . Effects of a complex intervention on fall risk in the general practitioner setting: a cluster randomized controlled trial. Clin Interv Aging. 2013;8:1079-88. PMID: 23983460.23983460
Halvarsson A, Olsson E, Elin F, . A new individually adjusted, progressive balance group training program for elderly with fear of falling and a tendency to fall. Physiotherapy. 2011;97:eS448-eS9. PMID: None.
Hegeman J, Nienhuis B, van den Bemt B, . The effect of a non-steroidal antiinflammatory drug on two important predictors for accidental falls: postural balance and manual reaction time. A randomized, controlled pilot study. Hum Mov Sci. 2011;30(2):384-95. PMID: 20708287.20708287
Jacobson BH, Thompson B, Wallace T, . Independent static balance training contributes to increased stability and functional capacity in community-dwelling elderly people: a randomized controlled trial. Clin Rehabil. 2011;25(6):549-56. PMID: 21402649.21402649
Jeon MY, Jeong H, Petrofsky J, . Effects of a randomized controlled recurrent fall prevention program on risk factors for falls in frail elderly living at home in rural communities. Med Sci Monit. 2014;20:2283-91. PMID: 25394805.25394805
Jung DI, Ko DS, Jeong MA. Kinematic effect of Nintendo Wii(TM) sports program exercise on obstacle gait in elderly women with falling risk. J Phys Ther Sci. 2015;27(5):1397-400. PMID: 26157228.26157228
Krampe J. Dance-based therapy to decrease fall risk in older persons: University of Missouri - Columbia; 2010.
Lai CH, Peng CW, Chen YL, . Effects of interactive video-game based system exercise on the balance of the elderly. Gait Posture. 2013;37(4):511-5. PMID: 23177921.23177921
Marques EA, Mota J, Machado L, . Multicomponent training program with weightbearing exercises elicits favorable bone density, muscle strength, and balance adaptations in older women. Calcif Tissue Int. 2011;88(2):117-29. PMID: 21113584.21113584
Martinez-Amat A, Hita-Contreras F, Lomas-Vega R, . Effects of 12-week proprioception training program on postural stability, gait, and balance in older adults: a controlled clinical trial. J Strength Cond Res. 2013;27(8):2180-8. PMID: 23207891.23207891
McMahon SK, Wyman JF, Belyea MJ, . Combining Motivational and Physical Intervention Components to Promote Fall-Reducing Physical Activity Among CommunityDwelling Older Adults: A Feasibility Study. Am J Health Promot. 2015. PMID: 26389979.26389979
Melzer I, Oddsson L. Improving balance control and self-reported lower extremity function in community-dwelling older adults: a randomized control trial. Clin Rehabil. 2013;27(3):195-206. PMID: 22837541.22837541
Roaldsen KS, Halvarsson A, Sahlstrom T, . Task-specific balance training improves selfassessed function in community-dwelling older adults with balance deficits and fear of falling: a randomized controlled trial. Clin Rehabil. 2014;28(12):1189-97. PMID: 24895381.24895381
Salonoja M, Salminen M, Aarnio P, . One-time counselling decreases the use of benzodiazepines and related drugs among community-dwelling older persons. Age Ageing. 2010;39(3):313-9. PMID: 20089547.20089547
Sanders KM, Duque G, McCorquodale T, . Annual high-dose oral vitamin D3: Is the increased risk of falls attributable to changes in muscle strength? Osteoporos Int. 2011;22:S552-s3. PMID: None.
Seo BD, Kim BJ, Singh K. The comparison of resistance and balance exercise on balance and falls efficacy in older females. Eur Geriatr Med. 2012;3(5):312-6. PMID: None.
Sousa N, Mendes R, Silva A, . Combined exercise is more effective than aerobic exercise in the improvement of fall risk factors: A randomized controlled trial in communitydwelling older men. Clin Rehabil. 2016. PMID: 27353246.27353246
Tatsuya H, Shigeru I, Nobuou M, . Effectiveness of a balance-training program provided by qualified care workers for community-based older adults: A preliminary study. Geriatr Nurs. 2015;36(3):219-23. PMID: 25846053.25846053
van Haastregt JC, Zijlstra GA, Hendriks MR, . Cost-effectiveness of an intervention to reduce fear of falling. Int J Technol Assess Health Care. 2013;29(3):219-26. PMID: 23778198.23778198
Williams HG, Ullmann G. Development of a community-based fall prevention program: Stay In Balance. J Phys Act Health. 2012;9(4):571-80. PMID: 21946291.21946291
Yoo EJ, Jun TW, Hawkins SA. The effects of a walking exercise program on fall-related fitness, bone metabolism, and fall-related psychological factors in elderly women. Res Sports Med. 2010;18(4):236-50. PMID: 21058209.21058209

### Less than 6 months followup

Arkkukangas M, Johnson ST, Hellstrom K, . A feasibility study of a randomised controlled trial comparing fall prevention using exercise with or without the support of motivational interviewing. Prev Med Rep. 2015;2:134-40. PMID: 26844061.26844061
Beling J, Roller M. Multifactorial intervention with balance training as a core component among fall-prone older adults. J Geriatr Phys Ther. 2009;32(3):125-33. PMID: 20128337.20128337
Chao Y-Y, Scherer YK, Montgomery CA, . Physical and Psychosocial Effects of Wii Fit Exergames Use in Assisted Living Residents. Clin Nurs Res. 2015;24(6):589-603. PMID: 25488422.25488422
Clarke S, Bradley R, Simmonds B, . Can paramedics use FRAX (the WHO Fracture Risk Assessment Tool) to help GPs improve future fracture risk in patients who fall? Protocol for a randomised controlled feasibility study. BMJ Open. 2014;4(9):e005744. PMID: 25186156.25186156
Clegg A, Barber S, Young J, . The Home-Based Older People’s Exercise (HOPE) trial: study protocol for a randomised controlled trial. Trials. 2011;12:143. PMID: 21651805.21651805
Franco JR, Jacobs K, Inzerillo C, . The effect of the Nintendo Wii Fit and exercise in improving balance and quality of life in community dwelling elders. Technol Health Care. 2012;20(2):95-115. PMID: 22508022.22508022
Giusti A, Giovale M, Ponte M, . Short-term effect of low-intensity, pulsed, electromagnetic fields on gait characteristics in older adults with low bone mineral density: a pilot randomized-controlled trial. Geriatr Gerontol Int. 2013;13(2):393-7. PMID: 22817664.22817664
Gschwind Y, Eichberg S, Ejupi A, . ICT-based system to predict and prevent falls (iStoppFalls): results from an international multicenter randomized controlled trial. Eur Rev Aging Phys Act. 2015;12(1):1-11. PMID: 26865874.26865865
Gschwind YJ, Eichberg S, Marston HR, . ICT-based system to predict and prevent falls (iStoppFalls): study protocol for an international multicenter randomized controlled trial. BMC Geriatr. 2014;14:91. PMID: 25141850.25141850
Gschwind YJ, Kressig RW, Lacroix A, . A best practice fall prevention exercise program to improve balance, strength / power, and psychosocial health in older adults: study protocol for a randomized controlled trial. BMC Geriatr. 2013;13:105. PMID: 24106864.24106864
Gyeong Hee C, Gak H, Hyung Soo S. The Effects of Virtual Reality-based Balance Training on Balance of the Elderly. J Phys Ther Sci. 2014;26(4):615-7. PMID: 24764645.24764645
Hill AM, Etherton-Beer C, Haines TP. Tailored education for older patients to facilitate engagement in falls prevention strategies after hospital discharge--a pilot randomized controlled trial. PLoS ONE. 2013;8(5):e63450. PMID: 23717424.23717424
Houston DK, Tooze JA, Demons JL, . Delivery of a Vitamin D Intervention in Homebound Older Adults Using a Meals-on-Wheels Program: A Pilot Study. J Am Geriatr Soc. 2015. PMID: 26277680.26277680
Huang TT, Yang LH, Liu CY. Reducing the fear of falling among community-dwelling elderly adults through cognitive-behavioural strategies and intense Tai Chi exercise: a randomized controlled trial. J Adv Nurs. 2011;67(5):961-71. PMID: 21214623.21214623
Iwamoto J, Suzuki H, Tanaka K, . Preventative effect of exercise against falls in the elderly: a randomized controlled trial. Osteoporos Int. 2009;20(7):1233-40. PMID: 19011727.19011727
Marston H, Woodbury A, Gschwind Y, . The design of a purpose-built exergame for fall prediction and prevention for older people. Eur Rev Aging Phys Act. 2015;12(1):1-12. PMID: 26865877.26865865
Ohtake M, Morikagi Y, Suzuki I, . Effects of exercise on the prevention of conditions leading to the need for long-term care. Aging Clin Exp Res. 2013;25(1):49-57. PMID: 23740633.23740633
Parijat P, Lockhart TE. Effects of moveable platform training in preventing slip-induced falls in older adults. Ann Biomed Eng. 2012;40(5):1111-21. PMID: 22134467.22134467
Rubenstein LZ, Josephson KR, Trueblood PR, . Effects of a group exercise program on strength, mobility, and falls among fall-prone elderly men. J Gerontol A Biol Sci Med Sci. 2000;55(6):M317-M21. PMID: 10843351.10843351
Schepens SL, Panzer V, Goldberg A. Randomized controlled trial comparing tailoring methods of multimedia-based fall prevention education for community-dwelling older adults. Am J Occup Ther. 2011;65(6):702-9. PMID: 22214115.22214115
Sheffield C, Smith CA, Becker M. Evaluation of an agency-based occupational therapy intervention to facilitate aging in place. Gerontologist. 2013;53(6):907-18. PMID: 23213082.23213082
Ullmann G, Williams HG, Hussey J, . Effects of Feldenkrais exercises on balance, mobility, balance confidence, and gait performance in community-dwelling adults age 65 and older. J Altern Complement Med. 2010;16(1):97-105. PMID: 20070145.20070145
Wolf SL, Barnhart HX, Kutner NG, . Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies of Intervention Techniques. J Am Geriatr Soc. 1996;44(5):489-97. PMID: 8617895.8617895

### Comparative effectiveness trial

Barker AL, Talevski J, Bohensky MA, . Feasibility of Pilates exercise to decrease falls risk: A pilot randomized controlled trial in community-dwelling older people. Clin Rehabil. 2015. PMID: 26385357.26385357
Bhatt T, Yang F, Pai YC. Learning to resist gait-slip falls: long-term retention in communitydwelling older adults. Arch Phys Med Rehabil. 2012;93(4):557-64. PMID: 22341989.22341989
Bischoff-Ferrari HA, Dawson-Hughes B, Orav E, . Monthly high-dose vitamin d treatment for the prevention of functional decline: A randomized clinical trial. JAMA Intern Med. 2016;176(2):175-83. PMID: 26747333.26747333
Burton E, Lewin G, Clemson L, . Effectiveness of a lifestyle exercise program for older people receiving a restorative home care service: study protocol for a pragmatic randomised controlled trial. BMC Health Serv Res. 2013;13:419. PMID: 24134491.24134491
Burton E, Lewin G, Clemson L, . Effectiveness of a lifestyle exercise program for older people receiving a restorative home care service: a pragmatic randomized controlled trial. Clin Interv Aging. 2013;8:1591-601. PMID: 24324331.24324331
Calder CG, Mannion J, Metcalf PA. Low-intensity whole-body vibration training to reduce fall risk in active, elderly residents of a retirement village. J Am Geriatr Soc. 2013;61(8):1424-6. PMID: 23937498.23937498
Clemson L, Fiatarone Singh MA, Bundy A, . Integration of balance and strength training into daily life activity to reduce rate of falls in older people (the LiFE study): randomised parallel trial. BMJ. 2012;345:e4547. PMID: 22872695.22872695
Davis JC, Marra CA, Robertson MC, . Economic evaluation of dose-response resistance training in older women: a cost-effectiveness and cost-utility analysis. Osteoporos Int. 2011;22(5):1355-66. PMID: 20683707.20683707
Day L, Hill KD, Stathakis VZ, . Impact of tai-chi on falls among preclinically disabled older people. A randomized controlled trial. J Am Med Dir Assoc. 2015;16(5):420-6. PMID: 25769960.25769960
Dunlop RA. An inexpensive and accessible exercise regime significantly improves balance and reduces injuries in the elderly. Focus Altern Complement Ther. 2011;16(1):56-7. PMID: None.
Duque G, Boersma D, Loza-Diaz G, . Effects of balance training using a virtual-reality system in older fallers. Clin Interv Aging. 2013;8:257-63. PMID: 23467506.23467506
Fox PJ, Vazquez L, Tonner C, . A randomized trial of a multifaceted intervention to reduce falls among community-dwelling adults. Health Educ Behav. 2010;37(6):831-48. PMID: 21051772.21051772
Gianoudis J, Bailey CA, Ebeling PR, . Effects of a targeted multimodal exercise program incorporating high-speed power training on falls and fracture risk factors in older adults: a community-based randomized controlled trial. J Bone Miner Res. 2014;29(1):182-91. PMID: 23775701.23775701
Gianoudis J, Bailey CA, Sanders KM, . Osteo-cise: strong bones for life: protocol for a community-based randomised controlled trial of a multi-modal exercise and osteoporosis education program for older adults at risk of falls and fractures. BMC Musculoskelet Disord. 2012;13:78. PMID: 22640372.22640372
Hiyamizu M, Morioka S, Shomoto K, . Effects of dual task balance training on dual task performance in elderly people: a randomized controlled trial. Clin Rehabil. 2012;26(1):58-67. PMID: 21421689.21421689
Hornbrook M, Stevens V, Wingfield D, . Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34(1):16-23. PMID: 8150304.8150304
Kemmler W, von Stengel S, Engelke K, . Exercise effects on bone mineral density, falls, coronary risk factors, and health care costs in older women: the randomized controlled senior fitness and prevention (SEFIP) study. Arch Intern Med. 2010;170(2):179-85. PMID: 20101013.20101013
Kim H, Yoshida H, Suzuki T. The effects of multidimensional exercise on functional decline, urinary incontinence, and fear of falling in community-dwelling elderly women with multiple symptoms of geriatric syndrome: a randomized controlled and 6-month follow-up trial. Arch Gerontol Geriatr. 2011;52(1):99-105. PMID: 20211501.20211501
Li F, Harmer P, Fisher KJ, . Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60(2):187-94. PMID: 15814861.15814861
Liston MB, Alushi L, Bamiou DE, . Feasibility and effect of supplementing a modified OTAGO intervention with multisensory balance exercises in older people who fall: a pilot randomized controlled trial. Clin Rehabil. 2014;28(8):784-93. PMID: 24776526.24776526
Liu-Ambrose T, Davis JC, Nagamatsu LS, . Changes in executive functions and selfefficacy are independently associated with improved usual gait speed in older women. BMC Geriatr. 2010;10:25. PMID: 20482830.20482830
Markle-Reid M, Browne G, Gafni A. Nurse-led health promotion interventions improve quality of life in frail older home care clients: lessons learned from three randomized trials in Ontario, Canada. J Eval Clin Pract. 2013;19(1):118-31. PMID: 22029487.22029487
Markle-Reid M, Browne G, Gafni A, . The effects and costs of a multifactorial and interdisciplinary team approach to falls prevention for older home care clients ’at risk’ for falling: a randomized controlled trial. Can J Aging. 2010;29(1):139-61. PMID: 20202271.20202271
Mirelman A, Rochester L, Reelick M, . V-TIME: a treadmill training program augmented by virtual reality to decrease fall risk in older adults: study design of a randomized controlled trial. BMC Neurol. 2013;13:15. PMID: 23388087.23388087
Oh S, Lim JM, Kim Y, . Comparison of the effects of water- and land-based exercises on the physical function and quality of life in community-dwelling elderly people with history of falling: a single-blind, randomized controlled trial. Arch Gerontol Geriatr. 2015;60(2):288-93. PMID: 25522928.25522928
Otaka Y, Morita M, Mimura T, . Establishment of an appropriate fall prevention program: A community-based study. Geriatr Gerontol Int. 2016. PMID: 27492888.27492888
Pai YC, Bhatt T, Yang F, . Perturbation training can reduce community-dwelling older adults’ annual fall risk: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2014;69(12):1586-94. PMID: 24966227.24966227
Parry SW, Bamford C, Deary V, . Cognitive-behavioural therapy-based intervention to reduce fear of falling in older people: therapy development and randomised controlled trial the Strategies for Increasing Independence, Confidence and Energy (STRIDE) study. Health Technol Assess. 2016;20(56):1-206. PMID: 27480813.27480813
Parry SW, Deary V, Finch T, . The STRIDE (Strategies to Increase confidence, InDependence and Energy) study: cognitive behavioural therapy-based intervention to reduce fear of falling in older fallers living in the community - study protocol for a randomised controlled trial. Trials. 2014;15:210. PMID: 24906406.24906406
Pollock RD, Newham DJ, Martin FC. Randomised clinical trial of the effects of whole body vibration therapy, in addition to a supervised exercise programme, on measures of Falls related physical performance. Age Ageing. 2011;40:ii52. PMID: None.
Posadzki P. Tai chi improves self-efficacy and decreases the incidence of falls in older adults. Focus Altern Complement Ther. 2012;17(3):177-8. PMID: None.
Reed-Jones RJ, Dorgo S, Hitchings MK, . Vision and agility training in community dwelling older adults: incorporating visual training into programs for fall prevention. Gait Posture. 2012;35(4):585-9. PMID: 22206782.22206782
Schoenmakers I, Francis RM, McColl E, . Vitamin D supplementation in older people (VDOP): Study protocol for a randomised controlled intervention trial with monthly oral dosing with 12,000 IU, 24,000 IU or 48,000 IU of vitamin D3. Trials. 2013;14:299. PMID: 24041337.24041337
Shigematsu R, Okura T, Nakagaichi M, . Square-stepping exercise and fall risk factors in older adults: a single-blind, randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(1):76-82. PMID: 18245764.18245764
Singh DK, Rajaratnam BS, Palaniswamy V, . Participating in a virtual reality balance exercise program can reduce risk and fear of falls. Maturitas. 2012;73(3):239-43. PMID: 22884437.22884437
Stengel S, Kemmler W, Engelke K, . Effects of whole body vibration on bone mineral density and falls: results of the randomized controlled ELVIS study with postmenopausal women. Osteo Int. 2011 22(1):317-25. PMID: 20306017.20306017
Swart KM, Ham AC, van Wijngaarden JP, . A Randomized Controlled Trial to Examine the Effect of 2-Year Vitamin B12 and Folic Acid Supplementation on Physical Performance, Strength, and Falling: Additional Findings from the B-PROOF Study. Calcified Tissue International. 2016;98(1):18-27. PMID: 26412463.26412463
Taylor D, Hale L, Schluter P, . Effectiveness of tai chi as a community-based falls prevention intervention: a randomized controlled trial. J Am Geriatr Soc. 2012;60(5):841-8. PMID: 22587850.22587850
Taylor SF. Community-dwelling older adults’ adherence to fall prevention recommendations: Virginia Commonwealth University; 2014.
von Stengel S, Kemmler W, Engelke K, . Effects of whole body vibration on bone mineral density and falls: results of the randomized controlled ELVIS study with postmenopausal women. Osteoporos Int. 2011;22(1):317-25. PMID: 20306017.20306017
Yamada M, Higuchi T, Nishiguchi S, . Multitarget stepping program in combination with a standardized multicomponent exercise program can prevent falls in communitydwelling older adults: a randomized, controlled trial. J Am Geriatr Soc. 2013;61(10):1669-75. PMID: 24001116.24001116
Yoo HN, Chung E, Lee BH. The Effects of Augmented Reality-based Otago Exercise on Balance, Gait, and Falls Efficacy of Elderly Women. J Phys Ther Sci. 2013;25(7):797-801. PMID: 24259856.24259856

### Not an included intervention type

Beck BR, Norling TL. The effect of 8 mos of twice-weekly low- or higher intensity whole body vibration on risk factors for postmenopausal hip fracture. Am J Phys Med Rehabil. 2010;89(12):997-1009. PMID: 21403595.21403595
Birks YF, Porthouse J, Addie C, . Randomized controlled trial of hip protectors among women living in the community. Osteoporosis International. 2004;15(9):701-6. PMID: 14997286.14997286
Cameron ID, Cumming RG, Kurrle SE, . A randomised trial of hip protector use by frail older women living in their own homes. Inj Prev. 2003;9(2):138-41. PMID: 12810740.12810740
Chung M, Lee J, Terasawa T, . Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Annals of internal medicine. 2011;155(12):827-38. PMID: 22184690.22184690
Cumming RG, Ivers R, Clemson L, . Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175-81. PMID: 17302652.17302652
Foss AJ, Harwood RH, Osborn F, . Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial. Age Ageing. 2006;35(1):66-71. PMID: 16364936.16364936
Gray-Donald K, Payette H, Boutier V. Randomized clinical trial of nutritional supplementation shows little effect on functional status among free-living frail elderly. J Nutr. 1995;125(12):2965-71. PMID: 7500174.7500174
Harwood RH, Foss AJ, Osborn F, . Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial. Br J Ophthalmol. 2005;89(1):53-9. PMID: 15615747.15615747
Leung KS, Li CY, Tse YK, . Effects of 18-month low-magnitude high-frequency vibration on fall rate and fracture risks in 710 community elderly--a cluster-randomized controlled trial. Osteoporos Int. 2014;25(6):1785-95. PMID: 24676848.24676848
Li CY. Efficacy of Low-Magnitude High-Frequency Vibration on Preventing Fall and Muscle Loss in Community Elderly: Chinese University of Hong Kong (Hong Kong); 2014.
Li CY, Leung KS, Cheung WH. Low-magnitude, high-frequency vibration treatment reduced fall incidences and fracture risks in community elderly: A prospective cluster- randomized controlled trial and 1 year follow-up. Osteoporos Int. 2013;24:S529. PMID: None.

### Poor study quality

Campbell AJ, Robertson MC, Gardner MM, . Psychotropic medication withdrawal and a home-based exercise program to prevent falls: a randomized, controlled trial. J Am Geriatr Soc. 1999;47(7):850-3. PMID: 10404930.10404930
Clemson L, Singh MF, Bundy A, . LiFE Pilot Study: A randomised trial of balance and strength training embedded in daily life activity to reduce falls in older adults. Aust Occup Ther J. 2010;57(1):42-50. PMID: 20854564.20854564
Coleman EA, Grothaus LC, Sandhu N, . Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47(7):775-83. PMID: 10404919.10404919
Gine-Garriga M, Guerra M, Unnithan VB. The effect of functional circuit training on selfreported fear of falling and health status in a group of physically frail older individuals: a randomized controlled trial. Aging Clin Exp Res. 2013;25(3):329-36. PMID: 23740589.23740589
Haines T, Russell T, Brauer S, . Effectiveness of a video-based exercise programme to reduce falls and improve health-related quality of life among older adults discharged from hospital: a pilot randomized controlled trial. Clin Rehabil. 2009;23(11):973-85. PMID: None.19675115
Halvarsson A, Franzen E, Faren E, . Long-term effects of new progressive group balance training for elderly people with increased risk of falling - a randomized controlled trial. Clin Rehabil. 2013;27(5):450-8. PMID: 23113989.23113989
Huang HC, Liu CY, Huang YT, . Community-based interventions to reduce falls among older adults in Taiwan - long time follow-up randomised controlled study. J Clin Nurs. 2010;19(7-8):959-68. PMID: 20492040.20492040
Karkkainen MK, Tuppurainen M, Salovaara K, . Does daily vitamin D 800IU and calcium 1000mg supplementation decrease the risk of falling in ambulatory women aged 6571 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010. PMID: 20060665.20060665
Lord SR, Ward JA, Williams P, . The effect of a 12-month exercise trial on balance, strength, and falls in older women: a randomized controlled trial. J Am Geriatr Soc. 1995;43(11):1198-206. PMID: 7594152.7594152
Luck T, Motzek T, Luppa M, . Effectiveness of preventive home visits in reducing the risk of falls in old age: a randomized controlled trial. Clin Interv Aging. 2013;8:697-702. PMID: 23788832.23788832
Rosenblatt NJ, Marone J, Grabiner MD. Preventing Trip- Related Falls by Community-Dwelling Adults: A Prospective Study. J Am Geriatr Soc. 2013;61(9):1629-31. PMID: 24028366.24028366
Smith H, Anderson F, Raphael H, . Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebocontrolled trial. Rheumatology (Oxford). 2007;46(12):1852-7. PMID: 17998225.17998225