# Appendix A Recommendations on Falls Prevention

Appendix A Society and Professional Organization Recommendations on Falls Prevention in Community-Dwelling Older Adults

Society or Professional Organization | Year | Age, years | Recommendation
U.S. Preventive Services Task Force^52^ | 2012 | ≥65 | Recommends exercise or physical therapy and vitamin D supplementation to prevent falls in community-dwelling adults who are at increased risk for falls. Does not recommend automatically performing an in-depth multifactorial risk assessment in conjunction with comprehensive management of identified risks to prevent falls in community-dwelling adults aged 65 years or older because the likelihood of benefit is small.
CDC^29^ | 2013 | ≥65 | Recommends STEADI, a coordinated approach to implementing the AGS/BGS clinical practice guidelines for fall prevention that consists of 3 core elements: screen to identify fall risk, assess modifiable risk factors, and intervene using effective clinical and community strategies to reduce the identified risk. Clinical strategies include but are not limited to physical therapy and medication management. Community strategies include but are not limited to evidence-based exercise programs and home modification.
National Institute for Health and Care Excellence^206^ | 2015 | ≥65 | Older adults in contact with health professionals should be asked routinely whether they have fallen in the past year and asked about the frequency, context, and characteristics of the fall(s). Older people at risk of falling should be observed for balance and gait defects and considered for their ability to benefit from interventions to improve strength and balance. Older adults who present for medical attention because of a fall, or report recurrent falls in the past year, or demonstrate abnormalities of gait and/or balance should be offered a multifactorial falls risk assessment. Recommended interventions: Multifactorial interventions; strength and balance training; exercise in extended care settings; home hazard and safety intervention; psychotropic medication review; cardiac pacing.
Royal Australian College of General Practitioners^207^ | 2012 | ≥65 | Recommend assessing risk of falls and if indicated by the screening questions, determine multifactorial fall risk and obtain relevant medical history, conduct a complete physical examination, and perform cognitive and functional assessments. Recommended interventions: exercise programs; medication review; vitamin D supplementation; podiatry intervention if indication; discuss dangers of bifocal and multifocal glasses when walking outdoors and recommend single lens glasses when outdoors; identify cataracts; occupational therapy home assessment (if history of recent falls)
American Geriatrics Society/British Geriatrics Society^208^ | 2010 | NR | Recommend a multifactorial fall risk assessment for all older adults who present with a fall or who have gait and balance problems. Also recommend a multifactorial falls risk assessment for individuals who simply report difficulties with gait or balance. A falls risk assessment is not considered necessary for older persons reporting only a single fall without reported or demonstrated difficulty or unsteadiness. Recommend that assessments include examination of the feet and footwear, functional assessment (assessment of activity of daily living skills, including use of adaptive equipment and mobility aids, as appropriate); assessment of the individual’s perceived functional ability and fear related to falling; and environmental assessment, including home safety. Recommended components of multifactorial interventions: exercise, specifically programs that include balance, gait, and strength training, such as tai chi or physical therapy, in group programs or as individual programs at home; environmental adaptation or modification; medication reduction or withdrawal; assessment and treatment of postural hypotension; cataract surgery on the first eye should be expedited in older persons in which the surgery is indicated; dual-chamber cardiac pacing when indicated; and vitamin D supplementation.

Abbreviations: NR = not reported.