# References

1 Cancer Facts and Figures 2017. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2017/cancer-facts-and-figures-2017.pdf. (Last accessed January 31, 2017).
2 U.S. Preventive Services Task Force. Screening for cervical cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;156:880-91.22711081
3 Saslow D, Solomon D, Lawson HW, et al. American Cancer Society, American Society for Colposcopy and Cervical Pathology, and American Society for Clinical Pathology screening guidelines for the prevention and early detection of cervical cancer. CA Cancer J Clin. 2012;62:147-72.22422631
4 ACOG Practice Bulletin Number 131: screening for cervical cancer. Obstet Gynecol. 2012;120:1222-38.23090560
5 Huh WK, Ault KA, Chelmow D, et al. Use of primary high-risk human papillomavirus testing for cervical cancer screening: Interim clinical guidance. Gynecol Oncol. 2015; 136(2):178-82.25579107
6 Melnikow J, Henderson JT, Burda BU, et al. Screening for Cervical Cancer With High-Risk Human Papillomavirus Testing: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 158. AHRQ Publication No. 17-05231-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2017.
7 Campos NG, Burger EA, Sy S, et al. An updated natural history model of cervical cancer: derivation of model parameters. Am J Epidemiol. 2014;180:545-55.25081182
8 Kim JJ, Campos NG, Sy S, et al. Inefficiencies and high-value improvements in U.S. cervical cancer screening practice: a cost-effectiveness analysis. Ann Intern Med. 2015;163:589-97.26414147
9 National Center for Health Statistics. 2010 National Hospital Discharge Survey (NHDS) Public Use Micro-Data File and Documentation. Available at https://www.cdc.gov/nchs/nhds/nhds_questionnaires.htm. (Last accessed January 31, 2017).
10 University of California Berkeley. Berkeley Mortality Database. Available at http://demog.berkeley.edu/~bmd. (Data downloaded on August 2, 2016).
11 U.S. National Cancer Institute. Surveillance, Epidemiology, End Results (SEER) Cancer Statistics Review, 1975-2013. Available at https://seer.cancer.gov/csr/1975_2013/. (Last accessed January 31, 2017).
12 Campos NG, Burger EA, Sy S, et al. An updated natural history model of cervical cancer: derivation of model parameters. Am J Epidemiol. 2014;180(5):545-555.25081182
13 Munoz N, Mendez F, Posso H, et al. Incidence, duration, and determinants of cervical human papillomavirus infection in a cohort of Colombian women with normal cytological results. J Infect Dis. 2004;190(12):2077-2087.15551205
14 Herrero R, Hildesheim A, Rodriguez AC, et al. Rationale and design of a community-based double-blind randomized clinical trial of an HPV 16 and 18 vaccine in Guanacaste, Costa Rica. Vaccine. 2008;26(37):4795-4808.18640170
15 Bratti MC, Rodriguez AC, Schiffman M, et al. Description of a seven-year prospective study of human papillomavirus infection and cervical neoplasia among 10000 women in Guanacaste, Costa Rica. Rev Panam Salud Publica. 2004;15(2):75-89.15030652
16 Keefe KA, Schell MJ, Brewer C, et al. A randomized, double blind, Phase III trial using oral beta-carotene supplementation for women with high-grade cervical intraepithelial neoplasia. Cancer Epidemiol Biomarkers Prev. 2001;10(10):1029-1035.11588128
17 Meyskens FL, Jr., Surwit E, Moon TE, et al. Enhancement of regression of cervical intraepithelial neoplasia II (moderate dysplasia) with topically applied all-trans-retinoic acid: a randomized trial. J Natl Cancer Inst. 1994;86(7):539-543.8133537
18 Castle PE, Schiffman M, Wheeler CM, Solomon D. Evidence for frequent regression of cervical intraepithelial neoplasia-grade 2. Obstet Gynecol. 2009;113(1):18-25.19104355
19 Moscicki AB, Ma Y, Wibbelsman C, et al. Rate of and risks for regression of cervical intraepithelial neoplasia 2 in adolescents and young women. Obstet Gynecol. 2010;116(6):1373-1380.21099605
20 Wang SM, Colombara D, Shi JF, et al. Six-year regression and progression of cervical lesions of different human papillomavirus viral loads in varied histological diagnoses. Int J Gynecol Cancer. 2013;23(4):716-723.23455757
21 McCredie MR, Sharples KJ, Paul C, et al. Natural history of cervical neoplasia and risk of invasive cancer in women with cervical intraepithelial neoplasia 3: a retrospective cohort study. Lancet Oncol. 2008;9(5):425-434.18407790
22 McCrory D, Mather D, Bastian L, et al. Evaluation of cervical cytology. Evidence report/technology assessment No. 5. AHCPR publication no. 99-E010. Rockville: Agency for Health Care Policy and Research; 1999.
23 Wheeler CM, Hunt WC, Cuzick J, et al. A population-based study of human papillomavirus genotype prevalence in the United States: baseline measures prior to mass human papillomavirus vaccination. Int J Cancer. 2013;132:198-207.22532127
24 Joste NE, Ronnett BM, Hunt WC, et al. Human papillomavirus genotype-specific prevalence across the continuum of cervical neoplasia and cancer. Cancer Epidemiol Biomarkers Prev. 2015;24:230-40.25363635
25 Saraiya M, Unger ER, Thompson TD, et al. US assessment of HPV types in cancers: implications for current and 9-valent HPV vaccines. J Natl Cancer Inst. 2015;107:djv086.25925419
26 Laskey PW, Meigs JW, Flannery JT. Uterine cervical carcinoma in Connecticut, 1935-1973: evidence for two classes of invasive disease. J Natl Cancer Inst. 1976;57:1037-43.1003540
27 International Agency for Research on Cancer. Cancer in Five Continents, Volume 1. Available at http://ci5.iarc.fr/Default.aspx. (Last accessed January 31, 2017).
28 Cuzick J, Myers O, Hunt WC, et al. A population-based evaluation of cervical screening in the United States: 2008-2011. Cancer Epidemiol Biomarkers Prev. 2014;23:765-73.24302677
29 Cuzick J, Myers O, Hunt WC, et al. Human papillomavirus testing 2007-2012: co-testing and triage utilization and impact on subsequent clinical management. Int J Cancer. 2015;136:2854-63.25447979
30 Kinney W, Hunt WC, Dinkelspiel H, et al. Cervical excisional treatment of young women: a population-based study. Gynecol Oncol. 2014;132:628-35.24395062
31 Ogilvie GS, Krajden M, van Niekerk D, et al. HPV for cervical cancer screening (HPV FOCAL): complete round 1 results of a randomized trial comparing HPV-based primary screening to liquid-based cytology for cervical cancer. Int J Cancer. 2017;140:440-8.27685757
32 Massad LS, Einstein MH, Huh WK, et al. 2012 updated consensus guidelines for the management of abnormal cervical cancer screening tests and cancer precursors. J Low Genit Tract Dis. 2013;17:S1-S27.23519301
33 Koliopoulos G, Arbyn M, Martin-Hirsch P, Kyrgiou M, Prencliville W, Paraskevaidis E. Diagnostic accuracy of human papillomavirus testing in primary cervical screening: a systematic review and meta-analysis of non-randomized studies. Gynecol Oncol. 2007;104:232-46.17084886
34 Cox JT, Castle PE, Behrens CM, Sharma A, Wright TC Jr, Cuzick J. Comparison of cervical cancer screening strategies incorporating different combinations of cytology, HPV testing, and genotyping for HPV 16/18: results from the ATHENA HPV study. Am J Obstet Gynecol. 2013;208:184 e1-e11.23174289
35 Arbyn M, Ronco G, Anttila A, et al. Evidence regarding human papillomavirus testing in secondary prevention of cervical cancer. Vaccine. 2012;30(Suppl 5):F88-99.23199969
36 Ronco G, Giorgi-Rossi P,Carozzi F, et al. Human papillomavirus testing and liquid-based cytology in primary screening of women younger than 35 years: results at recruitment for a randomised controlled trial. Lancet Oncol. 2006;7:547-55.16814206
37 Ronco G, Segnan N, Giorgi-Rossi P, et al. Human papillomavirus testing and liquid-based cytology: results at recruitment from the new technologies for cervical cancer randomized controlled trial. J Natl Cancer Inst. 2006;98:765-74.16757701
38 Wright TC, Stoler MH, Behrens CM, Sharma A, Zhang G, Wright TL. Primary cervical cancer screening with human papillomavirus: end of study results from the ATHENA study using HPV as the first-line screening test. Gynecol Oncol. 2015;136:189-97.25579108
39 Stoler MH, Ronnett BM, Joste NE, et al. The interpretive variability of cervical biopsies and its relationship to HPV status. Am J Surg Pathol. 2015;39:729-36.25602796
40 Ghaem-Maghami S, Sagi S, Majeed G, Soutter WP. Incomplete excision of cervical intraepithelial neoplasia and risk of treatment failure: a meta-analysis. Lancet Oncol. 2007;8:985-93.17928267
41 Kulasingam SL, Havrilesky LJ, Ghebre R, Myers ER. Screening for cervical cancer: a modeling study for the US Preventive Services Task Force. J Low Genit Tract Dis. 2013;17:193-202.23519288
42 Kim JJ, Tosteson AN, Zauber AG, et al. Cancer models and real-world data: better together. J Natl Cancer Inst. 2016; 108.
43 Beavis AL, Gravitt PE, Rositch AF. Hysterectomy-corrected cervical cancer mortality rates reveal a larger racial disparity in the United States. Cancer. 2017 Jan 23.
44 Rositch AF, Nowak RG, Gravitt PE. Increased age and race-specific incidence of cervical cancer after correction for hysterectomy prevalence in the United States from 2000 to 2009. Cancer. 2014;120:2032-8.24821088
45 Blatt AJ, Kennedy R, Luff RD, Austin RM, Rabin DS. Comparison of cervical cancer screening results among 256,648 women in multiple clinical practices. Cancer Cytopathol. 2015;123:282-8.25864682