# 4 Discussion

This report summarizes the findings from a model-based decision analysis on the long-term health effects, harms, and efficiency of primary HPV testing strategies to inform the updated USPSTF recommendations for cervical cancer screening in the United States. This analysis extends the 2012 decision analysis, which primarily evaluated cytology-based strategies,^41^ by focusing specifically on HPV testing for primary screening and including variations in age to switch from cytology-only screening to HPV testing, the rescreening interval, triage options for HPV-positive women, and screening end age. For strategies that overlapped in both reports (e.g., 3-year cytology alone, strategy 1), our results were quite similar to the findings from the previous report.

Consistent with short-term evidence from clinical studies, the model projected that strategies employing primary HPV testing or cotesting were associated with greater health benefits compared to current guidelines-based cytology testing alone but come at a harm of greater testing, colposcopies, and false positives. In all analyses, across three different efficiency measures, primary HPV testing strategies occurring at 5-year intervals were efficient, with the harm-to-benefit ratio decreasing (i.e., becoming more attractive) as the switch age extended from 25 to 30 years. By comparison, the more effective strategies involving 3-year HPV testing generally had exceedingly high ratios. Which HPV testing triage option was efficient depended on the measure of harm used: in terms of colposcopies per life-year gained or per cancer case averted, cytology triage for HPV-positive women was uniformly more efficient than 16/18 genotyping triage; most of the efficient strategies when using colposcopies as a measure of harm consistently involved 5-year HPV testing (switching at ages 25, 27, and 30 years). In contrast, in terms of screening tests per life-year gained, 16/18 genotyping triage was more efficient, mostly involving switching to primary HPV testing at age 25 years (5- and 3-year intervals).

Cotesting strategies were predominantly inefficient and appeared on the efficiency frontier only under two scenarios (repeat followup HPV testing at 6 months and in low-risk, HPV-vaccinated women), but in both of those cases were associated with much higher ratios compared to strategies involving HPV testing alone. When colposcopies were used as the measure of harm, cytology testing alone every 3 years was associated with very low (i.e., attractive) ratios; however, when using total tests as the measure of harm, cytology testing was inefficient across all analyses.

These findings were robust when varying age to end screening from age 65 to 70 and 75 years (assuming no recent abnormal results) with only slight increases in each of the ratios due to decreased efficiency of screening in older ages. When competing all strategies, including end ages for screening, we found that most of the efficient strategies across the three outcomes involved extending the screening age to 70 or 75 years. However, given the vast uncertainties regarding the natural history of HPV infection and screening effectiveness in older women, which were not extensively explored in the current analysis, our findings of screening end age should be interpreted with caution.

When multiple strategies are identified as efficient, selecting the “optimal” strategy depends on a threshold ratio that would be considered a reasonable balance of harms and benefits. The desired thresholds for each of the three efficiency measures is not clear when using intermediate metrics such as colposcopies or screening tests as a proxy for harm, as it is difficult to compare head-to-head against other (noncervical cancer) health interventions. Although costs were not considered in this analysis, the relative efficiency with respect to costs per life-year gained, a standard metric in traditional cost-effectiveness analysis, can provide another dimension of the tradeoff of harms and benefits that can more easily be benchmarked against other health interventions. In the absence of such a standard metric in this report, we elected to express results using three different metrics of efficiency to help interpret results in the context of different potential tradeoffs that might be considered important by decisionmakers.

## Strengths and Limitations of Modeling

Disease simulation models, when paired with robust data on disease burden and intervention effects, can be powerful tools in projecting long-term outcomes to inform decisionmaking in a timely manner.^42^ While most empirical studies on screening effectiveness report findings after only one or two rounds of screening, we can use the model to evaluate the implications of multiple screenings over an extended period and under different combinations of ages to switch, screening intervals, and management algorithms of screen-positive women. As with all model-based analyses, however, this analysis is subject to important limitations.

First, our analysis is based on assumptions of perfect compliance to screening intervals and management of screen-positive women; however, it is well documented that screening practice is not perfect and quite variable across the United States. How loss to followup might differ across testing modalities, age, and interval is uncertain but could impact the overall effectiveness and relative efficiency of the screening strategy. Second, although we examined a number of unique strategies, there may be other strategies that could lead to a more attractive balance of harms and benefits; for example, we restricted our rescreening interval to be no less frequent than every 5 years, but extending intervals to be even longer (e.g., 7 or 10 years) may be more efficient without compromising on effectiveness. Third, as mentioned previously, we did not explore different assumptions regarding the natural history of HPV infection in older women, nor did we examine other strategies or criteria to determine when to stop screening. There is much uncertainty regarding the prevalence and clinical importance of a newly-acquired HPV infection versus reactivation of a previously-acquired infection in older ages, which may impact the optimal age at which to stop screening. Furthermore, recent studies indicate that the incidence and mortality rates from cervical cancer are grossly underestimated by SEER given high rates of hysterectomies in U.S. women, and suggest that the current recommendation for terminating screening may not be optimal.^43,44^ The findings from our model, which do correct for hysterectomy rates by age in the population, indicate efficiency and greater effectiveness by extending the screening end age to 70 or 75 years; however, other screening exit criteria and strategies should be further explored in future analyses under various assumptions of disease risk and screening effect at older ages.

Fourth, issues regarding HPV-negative cancers and the implications for the relative effectiveness of HPV testing alone versus cytology alone or cotesting were not fully addressed.^45^ The sensitivity analysis in which HPV relative test sensitivity (compared to cytology) was decreased to a lower bound estimate mimics a scenario of greater missed disease due to HPV negativity; this scenario was the only one in which strategies involving 3-yearl HPV screening became more efficient with ratios comparable to 5-yearl HPV screening in the base-case analysis. In our assessment of screening in a low-risk population, we only represented one very specific subset of low-risk women, those who receive protection against HPV-16/18 infection and disease from vaccination. While there are other low-risk segments of the population, this question will become increasingly more pertinent as vaccinated women enter screening age. Finally, it is important to underscore that the results from the model represent average outcome across the whole population and is intended to inform guidelines at the population level, not at an individual level.

## Summary

In summary, the results from the model indicate that primary HPV screening has the potential to increase the effectiveness of screening compared to current U.S. guidelines-based strategies and may represent a reasonable balance of harms and benefits when administered every 5 years. The optimal age at which to switch from cytology to HPV testing and the optimal management of HPV-positive women depend on which outcome (colposcopies or tests) is used as the proxy for harms.