# 3 Results

## Health Benefits and Harms

In the absence of screening, the lifetime risk of cervical cancer was 1.9% (range across 50 best-fitting sets, 1.3% to 2.4%) and lifetime mortality from cervical cancer was 0.83% (range, 0.58% to 1.08%), resulting in a life expectancy of 63.921 years (range, 63.845 to 64.006 years) for 20-year-old women. Under scenarios of screening, model outcomes of screening tests (cytology, HPV, and total), colposcopies, CIN2/CIN3 detected, CIN3+ detected, false positives, cervical cancer cases, cervical cancer deaths, and life-years per 1,000 women were projected, separately for screening end ages of 65, 70, and 75 years (Tables 5-7). Compared to no screening, all cervical cancer screening strategies led to substantial reductions in cancer cases and deaths and gains in life-years. Compared to the current guidelines-based strategies of cytology alone every 3 years starting at age 21 years, with or without a switch to cotesting every 5 years starting at age 30 years, all new alternative strategies were more effective. For example, when screening ended at age 65 years (Table 5), cervical cancer deaths associated with the guidelines-based strategies (strategies 1 and 2) ranged from 0.30 to 0.76 deaths per 1,000 women, whereas the new alternative strategies involving primary HPV testing or cotesting (strategies 3–19) had fewer cervical cancer deaths, ranging from 0.23 to 0.29 deaths per 1,000 women.

Table 5 Outcomes for Cervical Cancer Screening Strategies Over the Lifetime of Screening (Screening End Age 65 Years)^*^

| | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^†^ | Colpos | CIN2,3 detected | CIN3+ detected^‡^ | False positives^§^ | CC cases | CC deaths | Life-years
0 | No screening | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 18.86 | 8.34 | 63921.34
1 | CYTO-3Y, 21-65 | 13877 | 786 | 14662 | 645 | 160 | 46 | 484 | 2.34 | 0.76 | 64181.89
2 | CYTO-3Y, 21 / COTEST-5Y, 30-65 | 11425 | 8380 | 19806 | 1630 | 201 | 54 | 1429 | 1.08 | 0.30 | 64192.97
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-65 | 1905 | 14807 | 16712 | 2530 | 218 | 57 | 2312 | 0.74 | 0.23 | 64195.61
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-65 | 2876 | 13772 | 16648 | 2278 | 214 | 56 | 2063 | 0.83 | 0.25 | 64195.08
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-65 | 3824 | 12428 | 16252 | 1978 | 205 | 54 | 1773 | 1.01 | 0.27 | 64193.51
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | 1706 | 10065 | 11771 | 2068 | 211 | 55 | 1857 | 0.79 | 0.25 | 64195.39
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-65 | 2697 | 9290 | 11987 | 1861 | 207 | 55 | 1655 | 0.89 | 0.28 | 64194.69
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-65 | 3675 | 8476 | 12151 | 1635 | 199 | 53 | 1435 | 1.05 | 0.29 | 64193.38
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-65 | 2277 | 14790 | 17067 | 2209 | 217 | 56 | 1992 | 0.75 | 0.23 | 64195.53
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-65 | 3205 | 13738 | 16943 | 1992 | 213 | 56 | 1779 | 0.85 | 0.25 | 64194.82
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-65 | 4102 | 12397 | 16499 | 1734 | 203 | 54 | 1530 | 1.04 | 0.28 | 64193.19
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-65 | 1993 | 10049 | 12042 | 1826 | 209 | 55 | 1617 | 0.81 | 0.25 | 64195.35
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-65 | 2950 | 9273 | 12223 | 1648 | 205 | 54 | 1443 | 0.91 | 0.28 | 64194.44
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-65 | 3888 | 8459 | 12348 | 1452 | 198 | 53 | 1254 | 1.08 | 0.29 | 64193.07
15 | CYTO-4Y, 21 / COTEST-3Y, 25-65 | 15723 | 14693 | 30416 | 2535 | 223 | 57 | 2312 | 0.76 | 0.23 | 64195.50
16 | CYTO-3Y, 21 / COTEST-3Y, 27-65 | 15765 | 13723 | 29488 | 2303 | 218 | 57 | 2084 | 0.83 | 0.25 | 64194.75
17 | CYTO-3Y, 21 / COTEST-3Y, 30-65 | 15456 | 12411 | 27867 | 2021 | 209 | 55 | 1812 | 1.03 | 0.27 | 64193.17
18 | CYTO-4Y, 21 / COTEST-5Y, 25-65 | 10944 | 9914 | 20859 | 2029 | 213 | 55 | 1816 | 0.82 | 0.26 | 64195.26
19 | CYTO-3Y, 21 / COTEST-5Y, 27-65 | 11275 | 9233 | 20508 | 1846 | 209 | 55 | 1637 | 0.89 | 0.27 | 64194.40

* Outcomes calculated from age 20 to 100 years.

† Total number of tests, irrespective of primary, triage, or surveillance context.

‡ CIN3+ includes CIN3s and cervical cancers detected through screening (excludes clinically detected cancers).

§ Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: Human papillomavirus.

Table 6 Outcomes for Cervical Cancer Screening Strategies Over the Lifetime of Screening (Screening End Age 70 Years)^*^

| | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^†^ | Colpos | CIN2,3 detected | CIN3+ detected^‡^ | False positives^§^ | CC cases | CC deaths | Life-years
0 | No screening | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 18.86 | 8.34 | 63921.34
1 | CYTO-3Y, 21-70 | 15149 | 855 | 16004 | 689 | 166 | 48 | 522 | 1.98 | 0.55 | 64184.58
2 | CYTO-3Y, 21 / COTEST-5Y, 30-70 | 12173 | 9128 | 21301 | 1705 | 207 | 55 | 1498 | 0.88 | 0.19 | 64194.07
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 1940 | 16024 | 17965 | 2620 | 224 | 58 | 2395 | 0.56 | 0.13 | 64196.60
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-70 | 2914 | 15055 | 17968 | 2373 | 220 | 57 | 2153 | 0.64 | 0.14 | 64196.14
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-70 | 3861 | 13721 | 17582 | 2074 | 210 | 56 | 1863 | 0.82 | 0.17 | 64194.60
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 1729 | 10807 | 12536 | 2134 | 216 | 56 | 1917 | 0.60 | 0.15 | 64196.47
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-70 | 2722 | 10049 | 12771 | 1930 | 212 | 56 | 1718 | 0.68 | 0.17 | 64195.84
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-70 | 3698 | 9216 | 12914 | 1700 | 204 | 55 | 1495 | 0.85 | 0.18 | 64194.50
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-6570 | 2327 | 15979 | 18306 | 2283 | 222 | 58 | 2060 | 0.58 | 0.13 | 64196.52
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-70 | 3260 | 15035 | 18295 | 2073 | 218 | 57 | 1854 | 0.66 | 0.14 | 64195.91
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-70 | 4157 | 13704 | 17861 | 1816 | 209 | 56 | 1606 | 0.85 | 0.17 | 64194.31
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 2028 | 10790 | 12818 | 1881 | 214 | 56 | 1667 | 0.62 | 0.15 | 64196.41
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 2986 | 10032 | 13017 | 1706 | 210 | 56 | 1496 | 0.71 | 0.17 | 64195.57
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 3923 | 9198 | 13121 | 1508 | 203 | 55 | 1304 | 0.88 | 0.18 | 64194.18
15 | CYTO-4Y, 21 / COTEST-3Y, 25-70 | 16929 | 15899 | 32829 | 2640 | 229 | 58 | 2411 | 0.58 | 0.14 | 64196.49
16 | CYTO-3Y, 21 / COTEST-3Y, 27-70 | 17021 | 14979 | 32000 | 2412 | 224 | 58 | 2188 | 0.65 | 0.15 | 64195.78
17 | CYTO-3Y, 21 / COTEST-3Y, 30-70 | 16722 | 13677 | 30399 | 2131 | 215 | 56 | 1916 | 0.84 | 0.17 | 64194.21
18 | CYTO-4Y, 21 / COTEST-5Y, 25-70 | 11696 | 10666 | 22361 | 2105 | 219 | 57 | 1886 | 0.63 | 0.15 | 64196.31
19 | CYTO-3Y, 21 / COTEST-5Y, 27-70 | 12038 | 9995 | 22033 | 1922 | 215 | 56 | 1707 | 0.69 | 0.17 | 64195.50

* Outcomes calculated from age 20 to 100 years.

† Total number of tests, irrespective of primary, triage, or surveillance context.

‡ CIN3+ includes CIN3 and cervical cancer detected through screening (excludes clinically-detected cancer).

§ Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: Human papillomavirus.

Table 7 Outcomes for Cervical Cancer Screening Strategies Over the Lifetime of Screening (Screening End Age 75 Years)^*^

| | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^†^ | Colpos | CIN2,3 detected | CIN3+ detected^‡^ | False positives^§^ | CC cases | CC deaths | Life-years
0 | No screening | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 18.86 | 8.34 | 63921.34
1 | CYTO-3Y, 21-75 | 16213 | 913 | 17127 | 724 | 170 | 49 | 554 | 1.76 | 0.42 | 64185.93
2 | CYTO-3Y, 21 / COTEST-5Y, 30-75 | 12848 | 9803 | 22651 | 1767 | 211 | 56 | 1556 | 0.77 | 0.13 | 64194.54
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 1967 | 17051 | 19018 | 2687 | 228 | 59 | 2459 | 0.47 | 0.09 | 64197.01
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-75 | 2942 | 16156 | 19098 | 2446 | 224 | 58 | 2222 | 0.54 | 0.09 | 64196.58
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-75 | 3890 | 14825 | 18715 | 2147 | 215 | 57 | 1931 | 0.72 | 0.12 | 64195.03
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 1748 | 11473 | 13222 | 2186 | 220 | 58 | 1966 | 0.49 | 0.09 | 64196.93
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-75 | 2741 | 10730 | 13472 | 1984 | 216 | 57 | 1768 | 0.58 | 0.11 | 64196.36
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-75 | 3717 | 9880 | 13597 | 1752 | 208 | 56 | 1544 | 0.75 | 0.13 | 64194.93
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2366 | 17013 | 19380 | 2340 | 226 | 59 | 2114 | 0.49 | 0.09 | 64196.93
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-75 | 3301 | 16112 | 19413 | 2132 | 223 | 58 | 1910 | 0.56 | 0.10 | 64196.32
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-75 | 4198 | 14784 | 18983 | 1876 | 213 | 57 | 1662 | 0.75 | 0.12 | 64194.71
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 2057 | 11455 | 13512 | 1926 | 218 | 57 | 1708 | 0.51 | 0.09 | 64196.89
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 3015 | 10712 | 13728 | 1752 | 215 | 57 | 1537 | 0.59 | 0.11 | 64196.12
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 3952 | 9861 | 13813 | 1552 | 207 | 56 | 1345 | 0.78 | 0.13 | 64194.63
15 | CYTO-4Y, 21 / COTEST-3Y, 25-75 | 18009 | 16979 | 34988 | 2726 | 233 | 60 | 2493 | 0.49 | 0.09 | 64196.92
16 | CYTO-3Y, 21 / COTEST-3Y, 27-75 | 18113 | 16071 | 34184 | 2500 | 229 | 59 | 2271 | 0.55 | 0.10 | 64196.20
17 | CYTO-3Y, 21 / COTEST-3Y, 30-75 | 17813 | 14768 | 32581 | 2218 | 219 | 58 | 1999 | 0.75 | 0.12 | 64194.61
18 | CYTO-4Y, 21 / COTEST-5Y, 25-75 | 12372 | 11342 | 23714 | 2166 | 223 | 58 | 1943 | 0.52 | 0.10 | 64196.81
19 | CYTO-3Y, 21 / COTEST-5Y, 27-75 | 12724 | 10681 | 23405 | 1985 | 219 | 57 | 1766 | 0.58 | 0.11 | 64196.01

* Outcomes calculated from age 20 to 100 years.

† Total number of tests, irrespective of primary, triage, or surveillance context.

‡ CIN3+ includes CIN3 and cervical cancer detected through screening (excludes clinically-detected cancer).

§ Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: Human papillomavirus.

Earlier switch age, more frequent intervals, and cotesting strategies generally led to a greater number of lifetime total tests. The proportion of tests that were cytology versus HPV test depended on the particular strategy. Screening strategies that involved switching to primary HPV testing alone (strategies 3–14) were associated with a substantially lower total number of cytology tests—3 to 8 times fewer cytology tests than with cytology alone or cotesting. In contrast, strategies involving HPV testing alone with 16/18 genotype triage (strategies 3–8) had the highest number of HPV tests, followed closely by HPV testing alone with cytology triage (strategies 9–14) and cotesting (strategies 2 and 15–19); cytology only, which utilizes HPV testing only for triage of ASC-US, had the lowest number of HPV tests. In total, the cotesting strategies had nearly double the total tests of the primary HPV testing strategies. The HPV testing strategy with cytology triage (strategies 9–14) led to a slightly higher number of tests than HPV testing with 16/18 genotyping (strategies 3–8). Continually screening with cytology alone every 3 years (strategy 1) had the fewest number of total tests than other HPV testing and cotesting strategies involving 3-year screening.

Cytology testing alone every 3 years also yielded the lowest number of lifetime colposcopies (i.e., 645 per 1,000 women). All other strategies increased colposcopies substantially, ranging from 1,452 to 2,535 per 1,000 women—up to 4-fold higher when screening with primary HPV testing or cotesting every 3 years starting at age 25 years. All else equal, colposcopies were generally highest for cotesting (strategies 2 and 15–19), followed closely by primary HPV testing with 16/18 genotype triage (strategies 3–8). HPV testing with 16/18 genotype triage had 12% to 14% greater colposcopies than HPV testing with cytology triage.

Likewise, the lowest numbers of CIN2/CIN3 and CIN3+ detected were from cytology testing alone every 3 years; for example, 160 CIN2/CIN3 cases detected per 1,000 women (strategy 1) versus 198 to 223 CIN2/CIN3 cases detected per 1,000 women for the strategies involving primary HPV testing and cotesting (strategies 2–19). Cotesting strategies (strategies 2 and 15– 19) yielded the highest numbers of CIN2/CIN3 and CIN3+ detected, but only marginally higher than primary HPV testing with 16/18 genotype triage (strategies 3–8), followed by primary HPV testing with cytology triage (strategies 9–14). Mimicking the trend of colposcopies, the number of false positives increased dramatically from cytology testing every 3 years to HPV testing or cotesting, irrespective of screening switch age or interval, up to 5-fold greater with cotesting or HPV testing every 3 years starting at age 25 years (strategies 3, 9, and 15).

The current guidelines-based strategy of cytology alone every 3 years (strategy 1) was the least effective in terms of cervical cancer cases, deaths, and life-years. Across the testing modalities, the most effective strategy was primary HPV testing with 16/18 genotype triage (strategies 3–8); the lowest number of cancer cases and deaths, and highest number of life years, occurred with 3-year screening with a switch age to primary HPV testing of 25 years (strategy 3). However, the difference in benefit between strategies involving primary HPV testing with 16/18 genotype triage compared to HPV testing with cytology triage and cotesting were quite small, especially at earlier switch ages and more frequent intervals.

As the screening end age extended to age 70 and 75 years (Tables 6 and 7), the absolute number of screening tests, colposcopies, CIN2/CIN3 detected, CIN3+ detected, false positives, and life-years increased, while the cervical cancer cases and deaths decreased. The trends in outcomes between the strategies (i.e., by screening modality, switch age, and interval) remained consistent irrespective of screening end age.

## Relative Efficiency Analysis

Three different metrics of colposcopies per life-year gained, screening tests per life-year gained, and colposcopies per cancer case averted were calculated to reflect different tradeoffs in harms and benefits. Each scenario analysis (A–D), representing different assumptions of the availability of triage strategies for primary HPV testing, included the current guidelines-based strategies of cytology testing alone every 3 years, with or without a switch to cotesting every 5 years at age 30 years (Figures 9-11 and Appendix Tables 2-4). These analyses were repeated assuming extension of the screening end age to 70 and 75 years (Figures 12-14 and Appendix Tables 5-10), and a comprehensive analysis included all screening strategies, varying screening test modality, triage approach, age to switch to HPV primary testing, interval, and age to end screening (Figures 15-17 and Appendix Tables 11-13).

Figure 9 Efficiency Frontiers: Colposcopies per Life-Year Gained, Varying HPV Testing Switch Age and Interval (Screening End Age 65 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of colposcopy per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability. The strategy with the lowest number of colposcopies per life-year gained was the current guidelines-based strategy of cytology testing alone every 3 years (strategy 1), with 2.5 colposcopies per life-year gained compared to no screening. By comparison, primary HPV and cotesting strategies increased both life-years and number of colposcopies. Efficient strategies included primary HPV testing, either with 16/18 genotyping or cytology triage, every 5 years with a switch age of 25, 27, and 30 years (strategies 6-8 and 12-14). Screening every 3 years with either triage strategy required a much greater number of colposcopies per life-year gained. The guidelines-based cotesting strategy (strategy 2) and additional cotesting strategies with earlier switch ages (25 and 27 years) and greater frequency (every 3 years) were not efficient in any scenario (strategies 15-19).

Figure 10 Efficiency Frontiers: Tests per Life-Year Gained, Varying HPV Testing Switch Age and Interval (Screening End Age 65 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of tests per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability. The only efficient strategies were primary HPV testing at a switch age of 25 years, with either 5- or 3-year screening (strategies 3, 6, 9, 12). When both triage options were available (Scenarios C and D), 16/18 genotyping was more efficient than cytology triage. Cytology-only and cotesting strategies (strategies 1-2 and 15-19) were not efficient in any of the scenarios compared to primary HPV testing.

Figure 11 Efficiency Frontiers: Colposcopies per Cervical Cancer Case Averted Varying HPV Testing Switch Age and Interval (Screening End Age 65 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of colposcopies per cervical cancer case averted for all four scenarios (A-D) of HPV triage and cotesting availability. Across all scenarios, cytology-only screening every 3 years (strategy 1) had the lowest ratio of 39 colposcopies per case averted. In Scenario A, primary HPV testing every 5 years with a switch age of 30 years (strategy 8) was associated with a ratio of 766 colposcopies per case averted; shifting the age of switching from cytology to primary HPV testing required a greater number of colposcopies per case averted. By comparison, when cytology was the only triage option for HPV-positive women (Scenario B), the corresponding ratios were uniformly lower. When both triage options were equally available, the strategies involving cytology triage for HPV-positive women were more efficient than 16/18 genotyping; 3-year HPV testing at age 25 with 16/18 genotyping (strategy 3), the most effective strategy, had a much higher ratio of colposcopies per case averted. In all scenarios, cotesting strategies (strategies 2 and 15-19) were not efficient.

Figure 12 Efficiency Frontiers: Colposcopies per Life-Year Gained When Varying Screening End Age (65, 70, or 75 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of colposcopies per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability when varying the screening end age from 65 years (base case) to 70 and 75 years. The findings were very robust, and all of the same strategies were on the efficiency frontier as in the base-case analysis for each of the three efficiency outcomes. The corresponding ratios increased (i.e., became less attractive) as the end age increased, indicating that although screening is more effective when continued to later ages, it also becomes less efficient.

Figure 13 Efficiency Frontiers: Tests per Life-Year Gained When Varying Screening End Age (65, 70, or 75 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of tests per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability when varying the screening end age from 65 years (base case) to 70 and 75 years. The findings were very robust, and all of the same strategies were on the efficiency frontier as in the base-case analysis for each of the three efficiency outcomes. The corresponding ratios increased (i.e., became less attractive) as the end age increased, indicating that although screening is more effective when continued to later ages, it also becomes less efficient.

Figure 14 Efficiency Frontiers: Colposcopies per Cervical Cancer Case Averted When Varying Screening End Age (65, 70, or 75 Years), Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of colposcopies per cervical cancer case averted for all four scenarios (A-D) of HPV triage and cotesting availability when varying the screening end age from 65 years (base case) to 70 and 75 years. The findings were very robust, and all of the same strategies were on the efficiency frontier as in the base-case analysis for each of the three efficiency outcomes. The corresponding ratios increased (i.e., became less attractive) as the end age increased, indicating that although screening is more effective when continued to later ages, it also becomes less efficient.

Figure 15 Efficiency Frontiers: Colposcopies per Life-Year Gained for All Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age, Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of colposcopies per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability when we conducted a comprehensive analysis with all possible strategies, varying screening strategy, interval, switch age, and end age. We found that most of the strategies on the efficiency frontier involved extending the screening end age to 70 and 75 years. Screening with cytology alone every 3 years (strategy 1) was efficient when screening ended at age 65, 70, and 75 years. Next efficient strategies included switching to 5-year primary HPV testing with cytology triage at age 30 (strategy 14), with screening end ages of 70 and 75 years. Strategies with earlier switch ages (27 and 25 years; strategies 13 and 12) increased the number of colposcopies required per life-year gained. 3-year HPV testing with 16/18 genotype triage at a switch age of 25 years (strategy 3) until age 75 years was the most effective strategy, with the highest ratio.

Figure 16 Efficiency Frontiers: Tests per Life-Year Gained for All Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age, Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A–D)

These graphs show results from the efficiency analysis in terms of tests per life-year gained for all four scenarios (A-D) of HPV triage and cotesting availability when we conducted a comprehensive analysis with all possible strategies, varying screening strategy, interval, switch age, and end age. The only efficient strategies involved primary HPV testing with 16/18 genotype triage at a switch age of 25 years (strategies 3 and 6). Extending the end age of screening, as well as screening every 3 years up to age 75, increased efficiency ratios dramatically.

Figure 17 Efficiency Frontiers: Colposcopies per Cervical Cancer Case Averted for All Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age, Under Different Scenarios of Triage Options for HPV-Positive Women (Scenarios A –D)

These graphs show results from the efficiency analysis in terms of colposcopies per cervical cancer case averted for all four scenarios (A-D) of HPV triage and cotesting availability when we conducted a comprehensive analysis with all possible strategies, varying screening strategy, interval, switch age, and end age. Nearly all of the same strategies were efficient, similar to the results in terms of colposcopies per life-year gained. Strategies with a switch to HPV testing at an age younger than 30 years required more than 1,000 colposcopies per case averted; strategies with a switch age of 25 years increased ratios dramatically.

### Summary by Efficiency Outcome

#### Colposcopies per Life-Year Gained

In all four scenarios of HPV triage and cotesting availability (Figure 9 and Appendix Table 2), the strategy with the lowest number of colposcopies per life-year gained was the current guidelines-based strategy of cytology testing alone every 3 years (strategy 1), with 3 colposcopies per life-year gained compared to no screening. By comparison, primary HPV and cotesting strategies increased both life-years and number of colposcopies. Efficient strategies included primary HPV testing, either with 16/18 genotyping or cytology triage, every 5 years with a switch age of 25, 27, and 30 years (strategies 6–8 and 12–14). For example, with 16/18 genotype triage availability (Scenario A), number of colposcopies per life-year gained increased from 86 to 297, as the switch age from cytology to HPV primary testing decreased from 30 to 25 years. Switching to 3-year primary HPV testing at age 25 years (strategy 3), the most effective strategy, had a substantially higher ratio of 2,082 colposcopies per life-year gained, compared to 5-year screening at the same switch age of 25 years (strategy 6). When assuming cytology triage for HPV-positive women (Scenario B), the corresponding ratios were lower for every 5-year screening with HPV primary testing, but slightly higher for every 3-year screening. In both Scenarios C and D, which included both triage strategies for HPV-positive women, followup with 16/18 genotype triage was not efficient when compared against cytology triage when HPV primary testing was conducted every 5 years. Screening every 3 years with either triage strategy required a much greater number of colposcopies per life-year gained, ranging from 2,188 (cytology triage, strategy 9) to 3,822 (16/18 genotype triage, strategy 3). The guidelines-based cotesting strategy (strategy 2) and additional cotesting strategies with earlier switch ages (25 and 27 years) and greater frequency (3-year interval) were not efficient in any scenario (strategies 15–19).

#### Tests per Life-Year Gained

When the analysis was expressed in terms of tests (both cytology and HPV) per life-year gained, the only efficient strategies were primary HPV testing at a switch age of 25 years, with either 5-or 3-year screening (strategies 3, 6, 9, and 12) (Figure 10 and Appendix Table 3). In Scenario A, HPV primary testing with 16/18 genotype triage every 5 years (strategy 6) was associated with 43 tests per life-year gained; the ratio for this same strategy increased substantially to 22,335 tests per life-year gained with every 3-year screening (strategy 3). In Scenario B, with cytology triage, the corresponding ratios increased slightly to 44 tests per life-year gained with 5-year screening (strategy 12), and 28,636 tests per life-year gained with 3-year screening (strategy 9). When both triage options were available (Scenarios C and D), 16/18 genotyping was more efficient than cytology triage. Cytology only and cotesting strategies (strategies 1, 2, and 15–19) were not efficient in any of the scenarios compared to primary HPV testing.

#### Colposcopies per Cervical Cancer Case Averted

Efficient strategies were consistent with those identified in the analysis of colposcopies per life-year gained (Figure 11 and Appendix Table 4). Across all scenarios, cytology-only screening every 3 years (strategy 1) had the lowest ratio of 39 colposcopies per case averted. In Scenario A, primary HPV testing every 5 years with a switch age of 30 years (strategy 8) was associated with a ratio of 766 colposcopies per case averted; shifting the age of switching from cytology to primary HPV testing required a greater number of colposcopies per case averted (1,432 for switch age 27 years and 2,120 for switch age 25 years). The most effective strategy, HPV testing every 3 years with a switch age of 25 years (strategy 3), increased the ratio to 8,580 colposcopies per case averted. By comparison, when cytology was the only triage option for HPV-positive women (Scenario B), the corresponding ratios were uniformly lower, ranging from 640 to 1,735 colposcopies per case averted for HPV testing every 5 years at switch ages of 30 to 25 years, respectively; 3-year primary HPV testing with a switch age of 25 years (strategy 9) was associated with 7,018 colposcopies per case averted. When both triage options were equally available, we found that the strategies involving cytology triage for HPV-positive women were more efficient than 16/18 genotyping; 3-year HPV testing at age 25 years with 16/18 genotyping (strategy 3), the most effective strategy, had a much higher ratio of 23,974 colposcopies per case averted. In all scenarios, cotesting strategies (strategies 2 and 15–19) were not efficient.

### Summary by Screening Modality, Screening Interval, and Ages

#### Screening Modality and Triage

Across all three efficiency outcomes, strategies involving primary HPV testing, with either 16/18 genotype or cytology triage (depending on the scenario), consistently remained on the efficiency frontier. When the two triage strategies were compared in the same analysis (Scenarios C and D), cytology triage was more efficient than 16/18 genotype triage for the two efficiency metrics that used colposcopy as a measure of harm (per life-year gained and per case averted); however, 16/18 genotype testing was the preferred triage option when using screening tests as the measure of harm (per life-year gained).

Cytology only, reflecting a currently recommended strategy, had the lowest benefit in terms of life-years and cancer cases, as well as the lowest number of colposcopies, and therefore yielded the lowest ratios when considering colposcopies as the measure of harm. When instead considering screening tests, cytology only was no longer on the efficiency frontier. Strategies involving cotesting, including one that is current recommended in the United States, were universally not efficient across any of the measures.

#### Screening Interval

Strategies involving 5-year screening were much more efficient than strategies with 3-year screening, which either were not on the efficiency frontier or had exceedingly high (i.e., unattractive) harm-to-benefit ratios. For all three efficiency measures, strategies involving switching to primary HPV testing every 5 years remained on the efficiency frontier.

#### Age to Switch From Cytology-Only Screening

For efficiency outcomes using colposcopies as a measure of harm, switching from cytology only to primary HPV testing at ages 25, 27, and 30 years were found to be efficient, and the harm-to-benefit ratios decreased (i.e., became more attractive) as the switch age extended from age 25 to 30 years. When using screening tests as the measure of harm, only two strategies were efficient, both involving switching to primary HPV testing at age 25 years (5- and 3-year intervals).

#### Age to End Screening

When the analyses were repeated with the age to end screening extended to 70 and 75 years (base case, 65 years), we found that our findings were very robust and that all of the same strategies were on the efficiency frontier, as in the base-case analysis for each of the three efficiency outcomes (Figures 12-14 and Appendix Tables 5-10). The corresponding ratios increased (i.e., became less attractive) as the end age increased, indicating that although screening is more effective when continued to later ages, it also becomes less efficient.

When we conducted a comprehensive analysis with all possible strategies, including varying screening end age, we found that most of the strategies on the efficiency frontier involved extending screening end age to 70 and 75 years (Figures 15-17 and Appendix Tables 11-13). When using colposcopies as a measure for harms under Scenario D, screening with cytology alone every 3 years (strategy 1) was efficient when screening ended at 65, 70, and 75 years; ratios for colposcopies per life-year gained were 3, 17, and 26, respectively. Next efficient strategies included switch to 5-year primary HPV testing with cytology triage at age 30 years (strategy 14), with screening end ages of 70 and 75 years, which increased colposcopies per life-year gained to 95 and 99 colposcopies per life-year gained, respectively. Those strategies with earlier switch ages (27 and 25 years, strategies 13 and 12) increased the number of colposcopies required per life-year gained to 135 and 225, respectively. Three-year HPV testing with 16/18 genotype triage at a switch age of 25 years (strategy 3) until age 75 years was the most effective strategy, with the highest ratio of 6,239 colposcopies per life-year gained. When considering colposcopies per case averted, nearly all of the same strategies were efficient, except that the screening end age for primary HPV testing was 75 years. Strategies with a switch to HPV testing before age 30 years required greater than 1,000 colposcopies per case averted; strategies with a switch age of 25 years had ratios ranging from 2,064 to 25,112 colposcopies per case averted, depending on triage strategy and interval.

When using screening tests as a measure of harms, we again found that the only efficient strategies involved primary HPV testing with 16/18 genotype triage at a switch age of 25 years (strategies 3 and 6). Extending the end age of screening increased efficiency ratios dramatically, from 43 to 707 to 1,497 screening tests per life-year gained when screening occurred every 5 years up to ages 65 to 70 to 75 years, respectively. This same strategy occurring every 3 years up to age 75 years required 69,064 screening tests per life-year gained.

## Sensitivity Analysis

Because of the inherent uncertainty in key model parameters, we undertook several sensitivity analyses to explore the robustness of results. The range (minimum and maximum) of base-case results across the 50 best-fitting parameter sets are presented in Appendix Table 14 to show the variation in outcomes when taking into account the uncertainty in the natural history parameters. Despite these variations, the rank order of the strategies according to each outcome was stable over the multiple sets.

### Test Characteristics

We undertook several analyses to assess the impact of test performance characteristics on base-case results (Scenario D) (Tables 810 and Appendix Tables 15-19). When test sensitivity for cytology was increased to the upper-bound, best-case value (81.5%), with a corresponding decrease in specificity (88.0%), we found that both cervical cancer cases and deaths decreased for all strategies, with the biggest decrease in the cytology-only strategy (decrease of 15% in cervical cancer cases and 13% in cervical cancer deaths, strategy 1) (Appendix Table 15). Nonetheless, because of the lower specificity, both numbers of colposcopies and false positives increased considerably, whereas the number of tests only increased marginally. For all three efficiency metrics, the efficient strategies remained the same as in the base case, but the ratios generally increased (i.e., became less attractive) given the increase in resource use. For example, ratios associated with a switch to 5-year primary HPV testing at ages 30, 27, and 25 years increased to 80, 167, and 323 colposcopies per life-year gained (strategies 12–14) (Table 8); switching to 3-year primary HPV testing at age 25 years (strategies 3 and 9) was still associated with ratios greater than 2,000 colposcopies per life-year gained. The increase in ratios in terms of tests per life-year gained (Table 9) and colposcopies per cancer case averted (Table 10) was not as pronounced.

Table 8 Sensitivity Analysis Summary: Impact of Uncertainty on Colposcopies per Life-Year Gained

# | Strategy^*^ | Base case | Screen end age 70 years | Screen end age 75 years | Cyto sens 81.5%, spec 88.0% | Cyto sens 51.4%, spec 93.6% | HPV relative sens 1.15 | Imperfect colpo | CIN treat efficacy 82% | LSIL threshold to colpo^†^ | 6-month follow up^‡^ | 24-month follow up^‡^ | Direct colpo referral^§^ | 16/18 vacc∥
0 | No Screening^¶^ | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | --
1 | CYTO-3Y, 21-65 | 3 | 3 | 3 | 3 | 2 | 2 | 3 | 3 | 2 | 2 | 2 | 3 | 5
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-65 | 73 | 85 | 95 | 80 | 38 | 66 | 42 | 69 | 71 | 90 | 48 | 73 | 113
2 | CYTO-3Y, 21 / COTEST-5Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-65 | 143 | 143 | 135 | 167 | 67 | 116 | 89 | 115 | 128 | 222 | 109 | 143 | 402
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-65 | 195 | 208 | 225 | 323 | 104 | X | 136 | 212 | 184 | 255 | 114 | 195 | 463
19 | CYTO-3Y, 21 / COTEST-5Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-65 | X | X | X | X | X | 127 | X | X | X | X | X | X | X
17 | CYTO-3Y, 21 / COTEST-3Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
18 | CYTO-4Y, 21 / COTEST-5Y, 25-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | X | X | X | X | 873 | X | 1,251 | X | X | X | X | X | X
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-65 | 2,188 | 3,758 | X | 2,590 | X | 234 | 1,741 | 2,016 | 1,789 | X | 1,369 | 2,188 | 8,163
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
16 | CYTO-3Y, 21 / COTEST-3Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-65 | 3,822 | 4,014 | 6,239 | 3,347 | 2,147 | 459 | 2,064 | 4,661 | 2,783 | X | 2,0/4 | 3,822 | X
15 | CYTO-4Y, 21 / COTEST-3Y, 25-65 | X | X | X | X | X | X | X | X | X | 3,887 | X | X | 10,884
25 | CYTO-3Y, 21 / HPV-5Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
24 | CYTO-3Y, 21 / HPV-5Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
22 | CYTO-3Y, 21 / HPV-3Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
23 | CYTO-4Y, 21 / HPV-5Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
21 | CYTO-3Y, 21 / HPV-3Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
20 | CYTO-4Y, 21 / HPV-3Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | X | na

* Strategies are listed in order of increasing colposcopies in the base-case analysis. “HPV (colpo)” strategies involved direct colposcopy referral for all HPV-positive women, which were only included in one sensitivity analysis.

† Among HPV-positive women who received cytology triage, LSIL was used as a threshold for colposcopy referral (base-case analysis assumed ASC-US); see Figure 8.

‡ Among HPV-positive women who received cytology triage and were referred for follow up testing, interval was varied 6 to 24 months (base-case analysis assumed 12 months); see Figure 8.

§ All strategies involving direct colposcopy referral for all HPV-positive women were inefficient.

∥ Screening was evaluated in women fully vaccinated with HPV-16/18 vaccines in preadolescence.

¶ No screening was the baseline comparator strategy in all analyses.

Abbreviations: Colpo: colposcopy; Cyto: cytology; HPV: Human papillomavirus; LSIL: low-grade squamous intraepithelial lesion; na: not analyzed; sens: sensitivity; spec: specificity; vacc: vaccinated, “x” marks strategies that were inefficient (i.e., more harmful and less beneficial than another strategy, or had a higher harm-to-benefit ratio than a strategy with greater harms).

Table 9 Sensitivity Analysis Summary: Impact of Uncertainty on Tests per Life-Year Gained

# | Strategy^*^ | Base case | Screen end age 70 years | Screen end age 75 years | Cyto sens 81.5%, spec 88.0% | Cyto sens 51.4%, spec 93.6% | HPV relative sens 1.15 | Imperfect colpo | CIN treat efficacy 82% | LSIL threshold to colpo^†^ | 6-month follow up^‡^ | 24-month follow up^‡^ | Direct colpo referral^§^ | 16/18 vacc∥
0 | No Screening^¶^ | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | --
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | 43 | 46 | 48 | 43 | 43 | 42 | 42 | 43 | 43 | 44 | 41 | X | X
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | | X | X | X
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-65 | X | X | X | X | X | X | X | X | X | 6,359 | X | X | 107
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
1 | CYTO-3Y, 21-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-65 | 22,335 | 41,852 | 69,063 | 23,126 | 23,131 | 3,111 | 24,006 | 24,871 | 21,594 | 45,833 | 25,769 | 35,241 | X
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-65 | X | X | X | X | X | X | X | X | X | X | X | X | 159,953
2 | CYTO-3Y, 21 / COTEST-5Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
19 | CYTO-3Y, 21 / COTEST-5Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
18 | CYTO-4Y, 21 / COTEST-5Y, 25-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
17 | CYTO-3Y, 21 / COTEST-3Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
16 | CYTO-3Y, 21 / COTEST-3Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
15 | CYTO-4Y, 21 / COTEST-3Y, 25-65 | X | X | X | X | X | X | X | X | X | 134,110 | X | X | 429,590
23 | CYTO-4Y, 21 / HPV-5Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | 42 | na
24 | CYTO-3Y, 21 / HPV-5Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
25 | CYTO-3Y, 21 1 HPV-5Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
22 | CYTO-3Y, 21 / HPV-3Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
20 | CYTO-4Y, 21 / HPV-3Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | 29,184 | na
21 | CYTO-3Y, 21 / HPV-3Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na

* Strategies are listed in order of increasing tests in the base-case analysis. “HPV (colpo)” strategies involved direct colposcopy referral for all HPV-positive women, which were only included in one sensitivity analysis.

† Among HPV-positive women who received cytology triage, LSIL was used as a threshold for colposcopy referral (base-case analysis assumed ASC-US); see Figure 8.

‡ Among HPV-positive women who received cytology triage and were referred for follow up testing, interval was varied 6 to 24 months (base-case analysis assumed 12 months); see Figure 8.

§ Rank order of efficient strategies in scenario including colposcopy referral for all HPV-positive women differed from base-case analysis.

∥ Screening was evaluated in women fully vaccinated with HPV-16/18 vaccines in preadolescence.

¶ No screening was the baseline comparator strategy in all analyses.

Abbreviations: Colpo: colposcopy; Cyto: cytology; HPV: Human papillomavirus; LSIL: low-grade squamous intraepithelial lesion; na: not analyzed; sens: sensitivity; spec: specificity; vacc: vaccinated, “x” marks strategies that were inefficient (i.e., more harmful and less beneficial than another strategy, or had a higher harm-to-benefit ratio than a strategy with greater harms).

Table 10 Sensitivity Analysis Summary: Impact of Uncertainty on Colposcopies per Cervical Cancer Case Averted

# | Strategy^*^ | Base case | Screen end age 70 years | Screen end age 75 years | Cyto sens 81.5%, spec 88.0% | Cyto sens 51.4%, spec 93.6% | HPV relative sens 1.15 | Imperfect colpo | CIN treat efficacy 82% | LSIL threshold to colpo^†^ | 6-month follow up^‡^ | 24-month follow up^‡^ | Direct colpo referral^§^ | 16/18 vacc∥
0 | No Screening^¶^ | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | -- | --
1 | CYTO-3Y, 21-65 | 39 | 41 | 42 | 54 | 33 | 38 | 42 | 41 | 39 | 39 | 39 | 39 | 77
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30-65 | 640 | 748 | 847 | 638 | 399 | 551 | 375 | 601 | 624 | 792 | 423 | 640 | 900
2 | CYTO-3Y, 21 /COTEST-5Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27-65 | 1,161 | 1,134 | 1,081 | 1,495 | 647 | 1,138 | 681 | 1,028 | 1,118 | 1,601 | 879 | 1,161 | 2,900
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25-65 | 1,735 | 1,914 | 2,064 | 2,017 | 974 | X | 1,101 | 1,543 | 1,682 | 2,023 | 1,449 | 1,735 | 3,247
19 | CYTO-3Y, 21 / COTEST-5Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27-65 | X | X | X | X | X | 1,307 | X | X | X | X | X | X | X
17 | CYTO-3Y, 21 / COTEST-3Y, 30-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
18 | (JY I 0-4Y, 21 / CO ! ESF-5Y, 25-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | X | X | 15,899 | X | X | X | X | X | X | X | X | X | X
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25-65 | 7,018 | 9,848 | 19,645 | 7,240 | 6,223 | 1,757 | 6,261 | 6,879 | 6,132 | 17,353 | 4,839 | 7,018 | 19,066
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
16 | CYTO-3Y, 21 / COTEST-3Y, 27-65 | X | X | X | X | X | X | X | X | X | X | X | X | X
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25-65 | 23,974 | 23,361 | 25,112 | 37,553 | 11,659 | 4,500 | 16,287 | 15,224 | 12,647 | X | 7,646 | 23,974 | X
15 | CYTO-4Y, 21 / COTEST-3Y, 25-65 | X | X | X | X | X | X | X | X | X | 27,217 | X | X | 418,870
23 | CYTO-4Y, 21 / HPV-5Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
24 | CYTO-3Y, 21 / HPV-5Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
2b | CYTO-3Y, 21 / HPV-5Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
22 | CYTO-3Y, 21 / HPV-3Y (colpo), 30-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
20 | CYTO-4Y, 21 / HPV-3Y (colpo), 25-65 | na | na | na | na | na | na | na | na | na | na | na | X | na
21 | CYTO-3Y, 21 / HPV-3Y (colpo), 27-65 | na | na | na | na | na | na | na | na | na | na | na | X | na

* Strategies are listed in order of increasing colposcopies in the base-case analysis. “HPV (colpo)” strategies involved direct colposcopy referral for all HPV-positive women, which were only included in one sensitivity analysis.

† Among HPV-positive women who received cytology triage, LSIL was used as a threshold for colposcopy referral (base-case analysis assumed ASC-US); see Figure 8.

‡ Among HPV-positive women who received cytology triage and were referred for follow up testing, interval was varied 6 to 24 months (base-case analysis assumed 12 months); see Figure 8.

§ All strategies involving direct colposcopy referral for HPV-positive women were inefficient.

∥ Screening was evaluated in women fully vaccinated with HPV-16/18 vaccines in preadolescence.

¶ No screening was the baseline comparator strategy in all analyses.

Abbreviations: Colpo: colposcopy; Cyto: cytology; HPV: Human papillomavirus; LSIL: low-grade squamous intraepithelial lesion; na: not analyzed; sens: sensitivity; spec: specificity; vacc: vaccinated. “x” marks strategies that were inefficient (i.e., more harmful and less beneficial than another strategy, or had a higher harm-to-benefit ratio than a strategy with greater harms).

When cytology specificity was increased (93.6%), with a decrease in sensitivity (51.4%) (Appendix Table 16), the effectiveness of all strategies decreased—especially for screening with cytology alone—but given the corresponding decrease in colposcopies, the ratios using this measure decreased (became more attractive) for all strategies. Efficiency ratios that used colposcopies as a measure of harm decreased by up to 60% for the HPV testing strategies (Tables 8 and 10). While switching to 5-year primary HPV testing with 16/18 genotype triage at age 25 years (strategy 6) became an efficient strategy in terms of colposcopies per life-year gained (873 colposcopies per life-year gained) (Table 8); the same strategy with cytology triage was associated with a far lower ratio (104 colposcopies per life-year gained, strategy 12). Since screening tests changed only marginally, the ratios using tests per life-year gained were stable (Table 9), switching to 5-year primary HPV testing starting at age 25 years at 43 tests per life-year gained; this same strategy at 3-year intervals remained exceedingly high.

We explored the lower-bound (worst-case) relative sensitivity of HPV testing, which impacted both HPV testing alone and cotesting, and found that despite a decrease in the effectiveness of the primary HPV testing strategies, they still provided greater benefits than the current guidelines-based strategies (Appendix Table 17). Since the decrease in effectiveness was also accompanied by a decrease in colposcopies, the ratios among efficient strategies improved and more strategies involving 3-year screening with HPV testing alone (strategies 3, 9, and 10) (Tables 8 and 10) became efficient, likely to offset the lower sensitivity value.

When we introduced error in the performance of colposcopy/biopsy in classifying a woman’s true histologic status, we found that the number of lifetime colposcopies decreased by up to 16% for the HPV and cotesting strategies; this decrease in colposcopies was also accompanied by a decrease in false-positive results, but also an increase in cancer cases and deaths (Appendix Table 18). When the effectiveness of precancer treatment (i.e., LEEP) was decreased to 82%, we found only small changes in the number of tests and colposcopies, but 12% to 17% increase in cervical cancer cases and 4% to 7% increase in cervical cancer deaths across all strategies (Appendix Table 19). Despite these variations in outcomes, the base-case results of the efficiency analyses remained stable under both sensitivity analyses, with slight decreases in the ratios due to the relatively greater reductions in harms (i.e., colposcopies and tests) than benefits (i.e., life-years and cases averted).

### Followup of HPV-Positive Women

Given that the effectiveness and efficiency of HPV testing depends heavily on the management of screen-positive women, we examined alternative followup algorithms based on protocols from empirical studies (Tables 8-10 and Appendix Tables 20-23). In either primary HPV testing strategy, for women who receive cytology triage (i.e., non-16/18, high-risk positive women in 16/18 triage option; all high-risk positive women in cytology triage option), we explored a more stringent cutoff of LSIL or worse as the threshold to refer women directly to colposcopy (vs. ASC-US or worse in the base case). Overall, all HPV testing strategies had lower effectiveness, as well as decreases in number of tests, colposcopies, and false-positive results (Appendix Table 20). Since the change in the measures of harms was slightly larger than the change in measures of benefit, the ratios for all strategies across the three efficiency outcomes marginally decreased (i.e., became more attractive).

We also varied the time to repeat testing for women who receive a normal results upon cytology triage (in both 16/18 genotype and cytology triage options for HPV testing), as well as those who receive HPV-positive and cytology-negative results on cotesting (12 months in the base case). In one scenario, we decreased the time to followup to 6 months, and in another scenario, we increased the time to followup to 24 months. We found that varying the followup interval had a large impact on number of colposcopies and false positives and a smaller impact on effectiveness, especially for HPV testing with cytology triage and cotesting, which send greater proportions of women to repeat testing. When followup was 6 months (Appendix Table 21), both colposcopies and effectiveness increased; this result led to similar efficient strategies as in the base-case analysis, but overall higher ratios indicating lower efficiency. Additionally, switching to 3-year cotesting at age 25 years (strategy 15) became the most effective strategy, although with relative high ratios for all three efficiency outcomes. In contrast, when time to followup was extended to 24 months (Appendix Table 22), HPV testing and cotesting strategies were less effective, but were more efficient in terms of colposcopies per life-year gained and per cancer case averted. For example, colposcopies per life-year gained associated with switching to 5-year HPV testing at ages 30, 27, and 25 years decreased to 48, 109, and 114 (73, 143, and 195 in the base case; strategies 14, 13, and 12), respectively (Table 8).

We evaluated a third alternative triage option in which all HPV-positive women are referred directly to colposcopy. Not surprisingly, the number of colposcopies and false positives was much greater (25% to 29% higher than with 16/18 genotype triage; 40% to 48% higher than with cytology triage), with only a nominal increase in effectiveness (Appendix Table 23). For ratios that used colposcopies as a measure of harm, all strategies that referred HPV-positive women to colposcopy without further testing were not efficient, and the base-case strategies and ratios remained the same. Because the number of tests decreased given the removal of repeat testing for HPV-positive women, when defining efficiency in terms of tests per life-year gained, the efficient strategies of 16/18 genotype triage in the base case were replaced by the same strategies of referring all HPV-positive women to colposcopy (i.e., switching to primary HPV testing at age 25 years); as in the base-case analysis, ratios associated with 3-year HPV testing (>29,000 tests per life-year gained) were much higher than with 5-year testing (42 tests per life-year gained).

### HPV-16/18 Vaccinated Women

We evaluated the screening strategies in women assumed to be completely protected from HPV-16/18 infections over the lifetime due to vaccination, to reflect a low-risk population (Tables 8-10 and Appendix Table 24). When protection against HPV-16/18 is complete, the 16/18 genotype and cytology triage options become equivalent, and therefore, our analysis set reduced to cytology alone, HPV primary testing with cytology triage, and cotesting. Women in this low-risk group faced significant reductions in cervical cancer cases and deaths, as well as high reductions in colposcopies and false-positive results. The same strategies were identified as efficient as in the base case; however, the ratios for all efficiency outcomes increased considerably, likely because these strategies (targeted to unvaccinated women in our base-case analysis) remain too intensive in women with considerably lower cervical cancer risk. For example, in terms of colposcopies per life-year gained, the ratio for switching to 5-year HPV testing at age 30 years (strategy 14) increased from 73 to 113; ratios for switching to 5-year HPV testing at younger ages, 27 and 25 years, more than doubled, to 402 and 463, respectively (143 and 195 in the base case; strategies 13 and 12). A similar trend was observed in terms of colposcopies per cancer case averted. When testing was used as a measure of harm, the ratios associated with 5-year HPV testing at age 25 years also doubled; ratios associated with 3-year screening ranged from 159,953 per life-year gained (primary HPV testing, strategy 9) to 429,590 per life-year gained (cotesting, strategy 15).