# 2 Methods

## Model

An overview of the decision model in terms of model attributes, natural history, and screening strategies is provided below and summarized in Table 1. The model is a microsimulation (i.e., individual-based) model of HPV-induced cervical carcinogenesis, in which individual women enter the model at an early age (i.e., age 9 years) and are followed over their lifetimes.^7,8^ The main health states of the model comprise HPV infection (by genotype), precancer (i.e., cervical intraepithelial neoplasia [CIN], grades 2 and 3) and invasive cancer (by stage) (Figure 1). The model focuses on squamous cell carcinoma (SCC), the most common histologic subtype of cervical cancer.

Table 1 Key Model Attributes

Attribute | Model
Mode of analysis, simulating life histories | Individual-based
Cycle length | Monthly
HPV types included | HPV-16; HPV-18; HPV-31; HPV-33; HPV-45; HPV-52; HPV-58; pooled HPV other high-risk; pooled HPV low-risk
Natural immunity | Reduced probability of future type-specific infection
Health states included | Healthy, HPV, CIN2, CIN3, Cancer^*^
Progression and regression probabilities | Age-specific, function of HPV persistence
Cancer staging | Local, regional, distant
Screening | Yes
Diagnosis | Yes
Precancer treatment | Yes
Vaccination | Yes

* The model focuses on squamous cell carcinoma, the most common histologic subtype of cervical cancer.

Abbreviations: CIN: cervical intraepithelial neoplasia; HPV: human papillomavirus.

Figure 1 Model Schematic

The main health states of the model comprise HPV infection (by genotype), precancer (e.g., cervical intraepithelial neoplasia [CIN], grades 2 and 3), and invasive cancer (by stage). The model focuses on squamous cell carcinoma, the most common histologic subtype of cervical cancer.

Screening is used to detect the presence of high-grade precancer, which may resolve spontaneously or can be treated and removed before progressing to cancer, as well as for early detection of invasive cancer. The effectiveness of screening strategies depends on coverage by age, interval, test characteristics, treatment efficacy, and compliance to followup visits.

This figures displays the main health states of the model: HPV infection (by genotype), precancer (e.g., CIN grades 2 and 3), and invasive cancer (by stage). The model focuses on squamous cell carcinoma, the most common histologic subtype of cervical cancer. Screening is used to detect the presence of high-grade precancer, which may resolve spontaneously or can be treated and removed before progressing to cancer, as well as for early detection of invasive cancer. The effectiveness of screening strategies depends on coverage by age, interval, test characteristics, treatment efficacy, and compliance to followup visits.

The current analysis was conducted using a single hypothetical birth cohort assumed to be born in year 1996 that would begin screening at age 21 years in year 2017. Screening is used to detect the presence of high-grade precancer, which may resolve spontaneously or can be treated and removed before progressing to cancer; therefore, reductions in cervical cancer morbidity and mortality due to screening result from both the prevention and the earlier detection of invasive cancer. The effectiveness of screening strategies depends on screening ages, screening interval, test characteristics, management of abnormal/positive results, and treatment efficacy. The model was used to project estimates of both benefits and harms, including life-years gained, cervical cancer cases and deaths, screening tests, diagnostic procedures, and false-positive results under various scenarios of primary screening tests, screening ages, screening intervals, and triage algorithms for screen-positive women. These measures are calculated as the cumulative number of events or time spent in the different health states, which are then modified by the interventions, over the selected time horizon (e.g., lifetime). These measures in totality capture the benefits and harms for the strategies being considered. To examine the relative tradeoff of harms versus benefits among the strategies, we calculated three efficiency outcomes in terms of the incremental number colposcopies per life-year gained, incremental number of screening tests per life-year gained, and incremental number of colposcopies per cervical cancer case averted.

### Natural History

Upon entry into the model, each woman faces monthly transitions between health states that describe underlying true health, including HPV infection, precancer (i.e., CIN2 and CIN3), and invasive cancer (i.e., local, regional, and distant). CIN2 and CIN3 are modeled as nonsequential precancerous health states with distinct probabilities of regression to normal or progression to cancer, whereas CIN1 is interpreted as a microscopic manifestation of acute HPV infection and is therefore incorporated into the HPV-infected state. States are further stratified into oncogenic HPV types 16, 18, 31, 33, 45, 52, and 58, each considered separately; pooled other high-risk types; and pooled low-risk HPV types. Transition probabilities can vary by age, HPV type, duration of infection or lesion, and history of prior HPV infection and CIN treatment. Cancer detection can occur through symptoms or screening. Each month, all women are subjected to rates of hysterectomy and all-cause mortality^9,10^ and excess mortality from cervical cancer.^10^

### Screening, Diagnosis, and Precancer Treatment

Screening assumptions in the model can vary by screening start age, stop age, interval between negative screens, coverage, triage testing, and compliance to recommended followup. Tests for primary screening and triage include cytology (conventional or liquid-based), and high-risk HPV DNA testing (pooled or genotyping), as well as cytology and HPV cotesting. Management of screen-positive women can vary by age, followup test, time to followup test(s), and number of negative followup tests required to return to routine screening.

### Cancer Treatment and Survival

Cancer staging (i.e., local to regional to distant) and progression is modeled, accounting for symptomatic detection and the possibility of downstaging at diagnosis due to screening. In addition to all-cause mortality, women with cervical cancer are subject to excess mortality, based on 5-year survival estimates depending on cancer stage, age, and time since diagnosis according to Surveillance, Epidemiology, and End Results (SEER) data.^11^

## Model Calibration

A process of model calibration and validation was undertaken to ensure fit to observed data. Calibrated parameters included HPV incidence (by age and genotype), CIN progression and regression, and HPV natural immunity following type-specific HPV infection and clearance. Baseline values for each of the uncertain parameters were randomly selected from a predetermined plausible range, creating a unique natural history parameter set. Goodness of fit was ascertained by calculating the likelihood of model-projected outcomes from each parameter set against corresponding calibration targets. To capture uncertainty in the natural history parameters, the 50 best-fitting sets were used in all analyses; the results are reported as the mean value across the 50 sets (the minimum and maximum values are also reported in a sensitivity analysis). The calibrated model parameter values used in this analysis are summarized in Appendix Table 1.^12-22^

For calibration target data, the data sources were selected on the basis of representativeness of the general population, sampling methods, and sample size. All data were from populations prior to HPV vaccination. Age-specific prevalence of HPV infections was based on data from the New Mexico HPV Pap Registry (NMHPVPR), the only statewide screening registry in the United States.^23^ The model was fitted to prevalence of HPV types 16, 18, 31, 33, 45, 52, and 58 separately, as well as other pooled high-risk HPV types. HPV type distribution in cases of CIN and cancer were also included as calibration target data. For CIN2 and CIN3, HPV type distribution was based on data from the NMHPVPR;^24^ for cancer, HPV type distribution in SCC was based on a recent study by the Centers for Disease Control and Prevention using tissue samples from U.S. population-based cancer registries.^25^ Model fit to calibration targets are displayed in Figures 2-4.

Figure 2 Prevalence of HPV by Age and Type

These graphs show postcalibration model fit to age- and type-specific HPV prevalence from the New Mexico HPV Pap Registry.^23^ The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

These graphs show post-calibration model fit to age- and type-specific HPV prevalence from the New Mexico HPV Pap Registry. The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

Figure 3 Type Distribution of HPV in CIN2 and CIN3

These graphs show postcalibration model fit to HPV type distribution in CIN2 and CIN3 from the New Mexico HPV Pap Registry.^24^ The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

These graphs show post-calibration model fit to HPV type distribution in CIN 2 and CIN 3 from the New Mexico HPV Pap Registry. The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

Figure 4 Type Distribution of HPV in Cancer

This graph shows postcalibration model fit to HPV type distribution in cancer from U.S. population-based cancer registries.^25^ The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

This graph shows post-calibration model fit to HPV type distribution in cancer from U.S. population-based cancer registries. The model range shows the variation in model fit across the 50 best-fitting parameter sets; the red line shows the mean fit across the 50 sets.

## Model Validation

Age-specific cervical cancer incidence rates under an assumption of no intervention (i.e., natural history) were projected by the model and compared against cancer registry data from the 1950s and early 1960s, before Pap smear screening was widely performed (Figure 5).^26,27^ Given the limited data from only a few states (Connecticut, New York, and Hawaii), and the potential changes in sexual behavior and other risk factors since the prescreening era, these data were not used directly to calibrate the model but instead were used to assess predictive validity for overall underlying risk.

Figure 5 Cervical Cancer Incidence per 100,000 Women, by Age and Model (Natural History)

This graph shows model-projected cervical cancer incidence rates under a scenario of no intervention (i.e., natural history) compared against cancer registry data from the 1950s and early 1960s, before Pap smear screening was widely available in the United States. Data are from the Connecticut Tumor Registry (CTR) and IARC Cancer in Five Continents (volume 1), which included data from Connecticut, New York, and Hawaii.^26,27^ Given the limited data from only a few states, and the potential changes in sexual behavior and other risk factors since the prescreening era, these data were not used directly to calibrate either model but instead were used to assess predictive validity for overall underlying risk. The model range shows the variation in model projections across the 50 best-fitting parameter sets; the red line shows the mean projection across the 50 sets. [Note: Both incidence and mortality rates from the model were calculated using the number of women alive as the denominator, not adjusting for women with hysterectomy, to match the estimates from the cancer registries.]

This graph shows model-projected cervical cancer incidence rates under a scenario of no intervention (i.e., natural history) compared with cancer registry data from the 1950s and early 1960s, before Pap test screening was widely available in the United States. Data were from the Connecticut Tumor Registry and IARC Cancer in Five Continents (Volume 1), which included data from Connecticut, New York, and Hawaii. Given the limited data from only a few states, and the potential changes in sexual behavior and other risk factors since the prescreening era, these data were not used directly to calibrate either model but instead were used to assess predictive validity for overall underlying risk. The model range shows the variation in model projections across the 50 best-fitting parameter sets; the red line shows the mean projection across the 50 sets. (Note: both incidence and mortality rates from the model were calculated using the number of women alive as the denominator, not adjusting for women with hysterectomy, to match the estimates from the cancer registries.)

In addition, model-projected outcomes of cervical cancer incidence and mortality rates were compared against those reported in SEER cancer registries in recent years (i.e., 2000–2012), under assumptions of screening practice patterns reported in the NMHPVPR (Figure 6).^8,28-30^ Screening practice patterns included estimated proportions of women never screened and screened at different intervals (e.g., annual or biennial) and proportions of women who do not comply to followup diagnostic testing, precancer treatments, or both.

Figure 6 Cervical Cancer Incidence and Mortality by Age (With Screening)

This graph shows model-projected cervical cancer incidence and mortality rates under assumptions of screening practice patterns reported in the New Mexico HPV Pap Registry,^8,28-30^ compared against those reported in SEER cancer registries in recent years (i.e., 2000–2013).^11^ The model range shows the variation in model projections under different assumptions of noncompliance to followup diagnostic testing and/or precancer treatments. [Note: Both incidence and mortality rates from the model were calculated using the number of women alive as the denominator, not adjusting for women with hysterectomy, to match the estimates from SEER.]

These graphs show model-projected cervical cancer incidence and mortality rates under assumptions of screening practice patterns reported in the New Mexico HPV Pap Registry compared with those reported in SEER cancer registries in recent years (i.e., 2000 to 2012). The model range shows the variation in model projections under different assumptions of noncompliance to followup diagnostic testing and/or precancer treatments. (Note: both incidence and mortality rates from the model were calculated using the number of women alive as the denominator, not adjusting for women with hysterectomy, to match the estimates from SEER.)

Additional model validation exercises included simulating the protocol from the HPV-FOCAL trial and comparing model projections against reported outcomes.^31^ We simulated three screening scenarios involving switching to primary HPV testing at ages 27, 34, and 52 years to reflect women who switch from cytology-based routine screening to primary HPV testing under the trial screening protocol. We projected the baseline and cumulative 12-month CIN2+, CIN3+, and colposcopy rates per 1,000 women in the first round of the HPV and control arms of the HPV-FOCAL trial for ages 25–29, 30–34, and 35–65 years (Figure 7). Comparisons of model projections against observational data have been previously reported.^8^

Figure 7 Outcomes From HPV-FOCAL Trial (With Screening)

This graph shows model validation against baseline and 12-month outcomes reported in the HPV-FOCAL trial.^31^ We simulated the trial protocol, including three screening scenarios involving switching to primary HPV testing at ages 27, 34, and 52 years. The model range shows the variation in projections across the 50 best-fitting parameter sets.

These graphs show model validation against baseline and 12-month outcomes reported in the HPV FOCAL trial. We simulated the trial protocol including three screening scenarios involving switching to primary HPV testing at ages 27, 34 and 52 years. The model range shows the variation in projections across the 50 best-fitting parameter sets.

## Screening Strategies

The analysis focused on the comparative effectiveness and harms of primary HPV testing, compared to currently recommended screening strategies, as well as other variations of cotesting. Table 2 summarizes the 19 main strategies evaluated. Guideline-based screening strategies comprised cytology alone every 3 years from ages 21 to 65 years (strategy 1) and cytology alone every 3 years from ages 21 to 29 years, with a switch to cytology and HPV cotesting every 5 years from ages 30 to 65 years (strategy 2).^2-4^ Management of women with equivocal or abnormal tests was assumed to follow established guidelines.^3,32^ For cotesting, HPV-positive/cytology-negative women were managed by repeat cotesting at 12 months, with referral to colposcopy for any positive result.

Table 2 Cervical Cancer Screening Strategies^*^

# | Strategy Name | Screen (1) test, interval | Screen (1) start age | Screen (2) test, interval | Screen (2) start age | Triage strategies for HPV+ results
1 | CYTO-3Y, 21 | Cytology, 3y | 21 | -- | -- | HPV for ASC-US
2 | CYTO-3Y, 21/COTEST-5Y, 30 | Cytology, 3y | 21 | Cotest, 5y | 30 | Repeat cotest, 12 mos
3 | CYTO-4Y, 21/HPV-3Y (16/18), 25 | Cytology, 4y | 21 | HPV, 3y | 25 | HPV-16/18 genotype
4 | CYTO-3Y, 21/HPV-3Y (16/18), 27 | Cytology, 3y | 21 | HPV, 3y | 27 | HPV-16/18 genotype
5 | CYTO-3Y, 21/HPV-3Y (16/18), 30 | Cytology, 3y | 21 | HPV, 3y | 30 | HPV-16/18 genotype
6 | CYTO-4Y, 21/HPV-5Y (16/18), 25 | Cytology, 4y | 21 | HPV, 5y | 25 | HPV-16/18 genotype
7 | CYTO-3Y, 21/HPV-5Y (16/18), 27 | Cytology, 3y | 21 | HPV, 5y | 27 | HPV-16/18 genotype
8 | CYTO-3Y, 21/HPV-5Y (16/18), 30 | Cytology, 3y | 21 | HPV, 5y | 30 | HPV-16/18 genotype
9 | CYTO-4Y, 21/HPV-3Y (cyto), 25 | Cytology, 4y | 21 | HPV, 3y | 25 | Cytology triage
10 | CYTO-3Y, 21/HPV-3Y (cyto), 27 | Cytology, 3y | 21 | HPV, 3y | 27 | Cytology triage
11 | CYTO-3Y, 21/HPV-3Y (cyto), 30 | Cytology, 3y | 21 | HPV, 3y | 30 | Cytology triage
12 | CYTO-4Y, 21/HPV-5Y (cyto), 25 | Cytology, 4y | 21 | HPV, 5y | 25 | Cytology triage
13 | CYTO-3Y, 21/HPV-5Y (cyto), 27 | Cytology, 3y | 21 | HPV, 5y | 27 | Cytology triage
14 | CYTO-3Y, 21/HPV-5Y (cyto), 30 | Cytology, 3y | 21 | HPV, 5y | 30 | Cytology triage
15 | CYTO-4Y, 21/COTEST-3Y, 25 | Cytology, 4y | 21 | Cotest, 3y | 25 | Repeat cotest, 12 mos
16 | CYTO-3Y, 21/COTEST-3Y, 27 | Cytology, 3y | 21 | Cotest, 3y | 27 | Repeat cotest, 12 mos
17 | CYTO-3Y, 21/COTEST-3Y, 30 | Cytology, 3y | 21 | Cotest, 3y | 30 | Repeat cotest, 12 mos
18 | CYTO-4Y, 21/COTEST-5Y, 25 | Cytology, 4y | 21 | Cotest, 5y | 25 | Repeat cotest, 12 mos
19 | CYTO-3Y, 21/COTEST-5Y, 27 | Cytology, 3y | 21 | Cotest, 5y | 27 | Repeat cotest, 12 mos

* Management of women with abnormal screening results was assumed to follow clinical guidelines^3,32^ and includes: for cytology testing, reflex HPV testing for women with atypical squamous cells of undetermined significance (ASC-US) and referral to colposcopy for women with more severe abnormal results; for cotesting, repeat cotesting in 12 months for women with cytology-negative, HPV-positive results; for HPV testing, two triage options were evaluated: “HPV (16/18)” strategies involved referral to colposcopy for women positive on HPV-16/18 genotype testing and cytology triage for women positive for other (non-16/18) high-risk HPV, and “HPV (cyto)” strategies involved cytology triage for all high-risk HPV-positive women. Strategies were evaluated in context of screening end age of 65, 70, and 75 years in separate analyses.

Abbreviations: Cyto: cytology; HPV: human papillomavirus.

The primary HPV testing strategies (strategies 3–14) were varied by: 1) age to switch from cytology to HPV screening, 2) rescreening interval following an HPV-negative result, and 3) triage options for an HPV-positive result. For the base case, age to switch to HPV screening was evaluated at ages 25, 27, and 30 years, following cytology-only screening starting at age 21 years. Age 25 years was selected to reflect the FDA-approved age threshold for primary HPV testing; age 27 years was selected to coincide with timing of 3-year cytology testing (at ages 21 and 24 years); and age 30 years was selected to be consistent with the age threshold to begin cotesting. The rescreening interval for primary HPV testing was evaluated at every 3 years and every 5 years, consistent with current U.S. guidelines for cytology-only screening and cotesting. Two triage strategies for HPV-positive screening results were examined (Figure 8): a) assuming HPV-16/18 genotype information is available, HPV 16/18-positive women are referred to colposcopy, whereas women positive for other high-risk HPV types receive cytology triage (those with a cytology result of atypical squamous cells of undetermined significance [ASC-US] or worse are referred to colposcopy; those with a cytology-negative result receive a followup test in 12 months); and b) all women with high-risk HPV receive cytology triage. A referral threshold of a cytology result of low-grade squamous intraepithelial lesion (LSIL) or worse was also evaluated, and the interval for followup testing was varied (e.g., 6 or 24 months) in sensitivity analysis. An additional triage strategy in which all women with high-risk HPV are referred for immediate colposcopy was also included in sensitivity analysis. Additional cotesting strategies (strategies 15–19) were included, varying the age to switch and rescreening interval.

Figure 8 Flow Diagram for Alternative Triage Strategies for (hr)HPV-Positive Women

* These variables were varied in sensitivity analysis.

Two triage strategies for HPV-positive screening results were examined: a) assuming HPV-16/18 genotype information is available, 16/18-positive women are referred to colposcopy, whereas women positive for other high-risk HPV types receive cytology triage (cytology of ASC-US or worse is referred to colposcopy; cytology-negative receives a followup test in 12 months); b) all women with high-risk HPV receive cytology triage (cytology of ASC-US or worse is referred to colposcopy; cytology-negative receives a followup test in 12 months). A referral threshold of cytology of LSIL or worse was also evaluated, and the interval for followup testing was varied (e.g., 6 or 24 months) in sensitivity analysis.

This figure displays the two triage strategies for HPV-positive screening results: 1) assuming HPV-16/18 genotype information is available, HPV 16/18-positive women are referred to colposcopy, whereas women positive for other high-risk HPV types receive cytology triage (cytology ≥ASCUS are referred to colposcopy; cytology-negative receive a followup test in 12 months); and 2) all women with high-risk HPV receive cytology triage (cytology ≥ASCUS are referred to colposcopy; cytology-negative receive a followup test in 12 months). A referral threshold of cytology ≥LSIL was also evaluated, and the interval for followup testing was varied (e.g., 6 or 24 months) in sensitivity analysis.

In the base-case analysis, age to stop screening was 65 years, assuming no recent history of abnormal results, consistent with current guidelines; we evaluated the impact of extending the age threshold at which to terminate screening to ages 70 and 75 years. We assumed full compliance to screening initiation, rescreening interval, and followup for both diagnostic and precancer treatment referrals. Furthermore, the base-case analysis focused on women who did not receive HPV vaccination.

## Screening Inputs

### Screening Test Characteristics

Test sensitivity and specificity values, defined at a disease threshold of CIN2 or worse (CIN2+), were required as model inputs and were informed from the studies reviewed by the EPC,^6^ as well as from the published literature (Table 3).^33-37^ For strategies involving cytology testing, we applied estimates of test sensitivity and specificity assuming a positivity threshold of ASC-US, with base-case values obtained from a meta-analysis conducted by Koliopoulos et al.^33^ These pooled estimates of sensitivity and specificity of cytology for detection of CIN2+ (72.7% and 91.9%, respectively) were based on 18 studies identified in a systematic review. The ranges of test performance values for cytology were informed by the Koliopoulos study, as well as estimates reported in the recent U.S.-based Addressing the Need for Advanced HPV Diagnostics (ATHENA) study.^34^

Table 3 Screening Test Characteristics

Test Characteristic^*^ | Base-Case Value | Source | Worst-Case Value | Best-Case Value | Source
Cytology^†^ Sensitivity Specificity | 0.727 0.919 | ^ 33 ^ | 0.514 0.880 | 0.815 0.936 | ^33,34^
HPV^‡^ Relative sensitivity Relative specificity | 1.24 0.97 | ^ 34 ^ | 1.15 0.96 | 1.37 0.98 | ^34-37^
Cotest^‡^ Relative sensitivity Relative specificity | 1.31 0.93 | ^ 34 ^ | 1.20 0.93 | 1.42 0.94 | ^34-37^

* Sensitivity (specificity) for all tests defined as probability to detect presence (absence) of CIN2+.

† For cytology testing, positivity threshold is ASC-US.

‡ For HPV testing and cotesting, sensitivity and specificity are relative to cytology test characteristics.

The model also required data on the distribution of abnormal cytology results (e.g., proportion of women with ASC-US, LSIL, and high-grade squamous intraepithelial lesion result) conditional on histologic diagnosis (Table 4). These estimates were based on data from the ATHENA study, which reported the baseline cytology results by central pathology review diagnosis of 8,000 women age 25 years and older.^38^

Table 4 Distribution of Abnormal Cytology Results Conditioned on Histology Result^38^

Cytology result | <CIN 2 | CIN 2 | CIN 3+
ASC-US | 0.6674 | 0.3026 | 0.2518
LSIL | 0.2994 | 0.5395 | 0.2734
ASC-H | 0.0130 | 0.0395 | 0.1007
HSIL | 0.0202 | 0.1184 | 0.3741

Abbreviations: ASC-H: atypical squamous cells, cannot exclude HSIL; ASC-US: atypical squamous cells of undetermined significance; CIN: cervical intraepithelial neoplasia; HSIL: high-grade squamous intraepithelial lesion; LSIL: low-grade squamous intraepithelial lesion.

The main inputs of test performance for primary HPV testing, alone and as part of cotesting, were based on ATHENA and studies that were included in EPC review.^34-37^ Given the wide variation in absolute test characteristics across studies due to differences in protocols and populations, we elected to utilize relative sensitivity and specificity values, compared with cytology testing (positivity threshold of ASC-US+) (Table 3). Our base-case estimates were anchored on the ATHENA study,^34^ which provided verification bias–adjusted estimates and included both HPV (cobas HPV test [Roche]) and cotesting strategies with similar followup algorithms as what was evaluated in this analysis. The worst- and best-case values for sensitivity and specificity for all screening test modalities were informed by data reported in ATHENA,^34^ a meta-analysis by Arbyn et al,^35^ and the New Technology in Cervical Cancer (NTCC) trial,^36,37^ which reflect variations across testing modalities that include the cobas HPV test, Hybrid Capture 2 (Qiagen), and polymerase chain reaction–based tests.

### Colposcopy/Biopsy and Precancer Treatment

The sensitivity and specificity of colposcopy and biopsy were assumed to be perfect (100%) in the base case, although we explored the impact of error in histologic diagnosis using data from the NMHPVPR in sensitivity analysis.^39^ We assumed that, with active surveillance of women who receive precancer treatment, the effectiveness of treatment in removing a CIN2 or CIN3 lesion (e.g., via loop electrosurgical excisional procedure [LEEP]) is ultimately 100%, but also explored a lower treatment effectiveness of 82%.^40^ The model assumed that HPV infections are also removed with precancer treatment, and therefore, treated women return to an uninfected state.

## Outcomes

The model generated a number of outcomes associated with each screening strategy, reflecting both health effects and harms over the lifetime of the screening cohort (i.e., ages 21 to 100 years): total number of cytology and HPV tests (including screening, triage, and surveillance), colposcopies, CIN2 and CIN3 detected, CIN3+ detected (including CIN3 and cervical cancers detected through screening), false-positive screening results (defined as total number of colposcopies without underlying CIN2, CIN3, or cancer), cervical cancer cases, cervical cancer deaths, and life-years.

(Colposcopies_Strat ⁢ x_ − Colposcopies_Strat ⁢ y_)/(Life-years_Strat ⁢ x_ − Life-years_Strat ⁢ y_ ⁢)

Strategies with a higher number of colposcopies and lower life-years than an alternative strategy were considered “inefficient” and eliminated from the calculation; all other strategies were considered “efficient.” Because there is no consensus on the appropriate metric to assess efficiency, we also presented results in terms of the incremental number of total screening tests per life-year gained and the incremental number of colposcopies per cervical cancer case averted.

## Scenario Analysis

For primary HPV testing, the different options for triaging HPV-positive women are not equally available or preferred; therefore, analyses to determine the relative efficiency of the screening strategies were conducted under four different scenarios of triage availability:

- Scenario A: Included only 16/18 genotype triage option for HPV-positive women (strategies 3–8)
- Scenario B: Included only cytology triage option for HPV-positive women (strategies 9– 14)
- Scenario C: Included both 16/18 genotyping and cytology triage options for HPV-positive women (strategies 3-14)
- Scenario D: Included both 16/18 genotyping and cytology triage options for HPV-positive women, plus additional cotesting strategies (strategies 3–19)

Each scenario analysis above also included the current guidelines-based strategies of cytology testing alone every 3 years, with or without a switch to cotesting every 5 years at age 30 years (strategies 1 and 2).

## Sensitivity Analysis

We assessed the impact of uncertainty in the data, alternative screening management protocols, and screening in HPV-vaccinated women. Data uncertainty focused on the underlying natural history of disease (i.e., transition probabilities), screening test characteristics, colposcopy/biopsy performance, and precancer treatment effectiveness. Alternative screening scenarios included variations in management of HPV-positive women, including cytology triage with a colposcopy referral threshold of LSIL (base case assumed ASC-US), varying intervals for followup testing from 6 to 24 months (base case assumed 12 months), and immediate colposcopy for all HPV-positive women. To reflect a low-risk population, we evaluated screening in HPV-vaccinated women. We assumed women were fully vaccinated with the three-dose HPV-16/18 vaccine in preadolescence and that vaccination conferred 100% protection against HPV-16 and HPV-18 infections over the lifetime.