# 1 Introduction

Despite dramatic reductions in cervical cancer since the introduction of Papanicolaou (Pap) cytology testing in the United States, roughly 12,820 women are expected to develop and 4,210 women are expected to die from cervical cancer in 2017.^1^ Information on the natural history of human papillomavirus (HPV) and its causal role in cervical disease, coupled with technologies to improve detection of precancerous lesions, continue to emerge and have prompted revisions to screening guidelines. In 2012, cervical cancer screening guidelines were harmonized across several major guidelines-making organizations, including the U.S. Preventive Services Task Force (USPSTF),^2-4^ with recommendations for routine cytology screening every 3 years starting at age 21 years, with an option to switch to cytology and HPV “cotesting” every 5 years starting at age 30 years. Screening end age is recommended at age 65 years, provided a history of regular screening without abnormalities in the past 10 to 20 years.^2-4^ Since 2012, new evidence on primary HPV testing has emerged, contributing to the U.S. Food and Drug Administration (FDA) approval of the first standalone HPV test for primary screening in women age 25 years and older. Interim clinical guidance on the use of primary HPV testing has been issued from several professional organizations.^5^

While empirical studies such as randomized clinical trials provide high-quality evidence on the effectiveness of screening, outcomes are usually based on intermediate endpoints after a limited number of rounds of screening. Mathematical disease simulation models can complement such evidence by extrapolating data beyond the trial period to project the benefits and harms of screening in the long term, over multiple rounds. Models can also explore the impact of alternative scenarios that have not been examined in empirical studies.

This decision analysis using a cervical cancer disease simulation model accompanies the systematic review that is being conducted by the Kaiser Permanente Evidence-based Practice Center (EPC) to update the evidence and address gaps in the expected benefits and harms of cervical cancer screening strategies in primary care.^6^ The key questions for the decision analysis center around the long-term impact of primary HPV screening compared to current guidelines-based screening strategies in terms of health benefits and harms in the general population:

1. How does the effectiveness of primary HPV screening in reducing cervical cancer incidence and mortality vary by 1) age to start HPV screening, 2) rescreening interval (following an HPV-negative result), and 3) age to stop HPV screening?
2. How do the harms of primary HPV screening vary by 1) age to start HPV screening, 2) rescreening interval, and 3) age to stop HPV screening?
3. Which cervical cancer screening strategies are considered efficient?

Two variations of triage of HPV-positive women were included in the base case. While the key questions of the analysis focused on primary HPV testing alone, we also considered other variations of cotesting. In addition, sensitivity analysis was conducted to assess the impact of uncertainty in the data and alternative screening scenarios.