# Appendix Tables

Appendix Table 1 Natural History Model Parameters, Post-Calibration

Model parameter | Range of values for 50 best-fitting sets^*^
HPV-16 incidence^12,13^
Age <20 years | 0.00003-0.01018
Age 20-24 years | 0.00170-0.00842
Age 25-29 years | 0.00147-0.00416
Age 30-34 years | 0.00136-0.00373
Age 35-39 years | 0.00132-0.00344
Age 40-44 years | 0.00124-0.00328
Age 45-49 years | 0.00113-0.00312
Age 50-54 years | 0.00102-0.00282
Age 55-59 years | 0.00093-0.00255
Age 60+ years | 0.00041-0.00231
HPV-18 incidence^12,13^
Age <20 years | 0.00001-0.00328
Age 20-24 years | 0.00101-0.00348
Age 25-29 years | 0.00074-0.00297
Age 30-34 years | 0.00062-0.00172
Age 35-39 years | 0.00048-0.00142
Age 40-44 years | 0.00041-0.00113
Age 45-49 years | 0.00037-0.00097
Age 50-54 years | 0.00034-0.00088
Age 55-59 years | 0.00030-0.00079
Age 60+ years | 0.00013-0.00072
HPV-31 incidence^12,13^
Age <20 years | 0.00001-0.00515
Age 20-24 years | 0.00188-0.00505
Age 25-29 years | 0.00126-0.00290
Age 30-34 years | 0.00088-0.00198
Age 35-39 years | 0.00070-0.00137
Age 40-44 years | 0.00068-0.00120
Age 45-49 years | 0.00063-0.00118
Age 50-54 years | 0.00057-0.00106
Age 55-59 years | 0.00052-0.00096
Age 60+ years | 0.00023-0.00087
HPV-33 incidence^12,13^
Age <20 years | 0.00001-0.00243
Age 20-24 years | 0.00056-0.00228
Age 25-29 years | 0.00034-0.00111
Age 30-34 years | 0.00025-0.00068
Age 35-39 years | 0.00022-0.00054
Age 40-44 years | 0.00020-0.00048
Age 45-49 years | 0.00018-0.00044
Age 50-54 years | 0.00016-0.00040
Age 55-59 years | 0.00015-0.00036
Age 60+ years | 0.00007-0.00034
HPV-45 incidence^12,13^
Age <20 years | 0.00001-0.00314
Age 20-24 years | 0.00057-0.00295
Age 25-29 years | 0.00044-0.00116
Age 30-34 years | 0.00038-0.00096
Age 35-39 years | 0.00031-0.00082
Age 40-44 years | 0.00026-0.00068
Age 45-49 years | 0.00023-0.00054
Age 50-54 years | 0.00019-0.00047
Age 55-59 years | 0.00017-0.00042
Age 60+ years | 0.00008-0.00038
HPV-52 incidence^12,13^
Age <20 years | 0.00002-0.00711
Age 20-24 years | 0.00108-0.00623
Age 25-29 years | 0.00074-0.00152
Age 30-34 years | 0.00067-0.00104
Age 35-39 years | 0.00063-0.00099
Age 40-44 years | 0.00060-0.00093
Age 45-49 years | 0.00060-0.00096
Age 50-54 years | 0.00054-0.00089
Age 55-59 years | 0.00049-0.00080
Age 60+ years | 0.00022-0.00073
HPV-58 incidence^12,13^
Age <20 years | 0.00001-0.00376
Age 20-24 years | 0.00087-0.00366
Age 25-29 years | 0.00069-0.00174
Age 30-34 years | 0.00059-0.00142
Age 35-39 years | 0.00050-0.00123
Age 40-44 years | 0.00040-0.00101
Age 45-49 years | 0.00036-0.00083
Age 50-54 years | 0.00033-0.00076
Age 55-59 years | 0.00029-0.00068
Age 60+ years | 0.00008-0.00062
Other carcinogenic incidence^12,13^
Age <20 years | 0.00003-0.02953
Age 20-24 years | 0.01021-0.02870
Age 25-29 years | 0.00679-0.02033
Age 30-34 years | 0.00498-0.01315
Age 35-39 years | 0.00419-0.00980
Age 40-44 years | 0.00368-0.00861
Age 45-49 years | 0.00341-0.00770
Age 50-54 years | 0.00308-0.00705
Age 55-59 years | 0.00279-0.00638
Age 60+ years | 0.00123-0.00578
Noncarcinogenic incidence^12,13^
Age <20 years | 0.00001-0.03840
Age 20-24 years | 0.00260-0.02043
Age 25-29 years | 0.00204-0.01950
Age 30-34 years | 0.00158-0.01471
Age 35-39 years | 0.00143-0.01194
Age 40-44 years | 0.00124-0.01083
Age 45-49 years | 0.00086-0.00891
Age 50-54 years | 0.00065-0.00633
Age 55-59 years | 0.00047-0.00474
Age 60+ years | 0.00022-0.00356
Natural immunity^12†^ | 0.502-0.803
HPV-16 clearance^12,14‡^
Year 1 | 0.04189
Year 2 | 0.04075
Year 3 | 0.03390
Year 4 | 0.03189
Year 5+ | 0.01985
HPV-18 clearance^12,14‡^
Year 1 | 0.07334
Year 2 | 0.06324
Year 3 | 0.05360
Year 4 | 0.02062
Year 5+ | 0.02062
HPV-31 clearance^12,14‡^
Year 1 | 0.06345
Year 2 | 0.03383
Year 3 | 0.03383
Year 4 | 0.03383
Year 5+ | 0.03383
HPV-33 clearance^12,14‡^
Year 1 | 0.08345
Year 2 | 0.04496
Year 3 | 0.03616
Year 4 | 0.03616
Year 5+ | 0.03616
HPV-45 clearance^12,14‡^
Year 1 | 0.07852
Year 2 | 0.04258
Year 3 | 0.04168
Year 4 | 0.03013
Year 5+ | 0.01507
HPV-52 clearance^12,14‡^
Year 1 | 0.06300
Year 2 | 0.04440
Year 3 | 0.04440
Year 4 | 0.03933
Year 5+ | 0.03933
HPV-58 clearance^12,14‡^
Year 1 | 0.06557
Year 2 | 0.05443
Year 3 | 0.05397
Year 4 | 0.03332
Year 5+ | 0.01666
Other carcinogenic clearance^12,14‡^
Year 1 | 0.08077
Year 2 | 0.06663
Year 3 | 0.05397
Year 4 | 0.04923
Year 5+ | 0.00509
Noncarcinogenic clearance^12,14,15‡^
Year 1 | 0.05189
Year 2 | 0.05001
Year 3 | 0.03465
Year 4 | 0.03465
Year 5+ | 0.02861
HPV-16 progression to CIN2^12,14‡^
Year 1 | 0.00171
Year 2 | 0.00242
Year 3 | 0.00258
Year 4 | 0.00552
Year 5 | 0.01500
Years 6-10 | 0.0152-0.04489
Years 11+ | 0.0195-0.07437
HPV-16 progression to CIN3^12,14‡^
Year 1 | 0.00057
Year 2 | 0.00081
Year 3 | 0.00086
Year 4 | 0.00184
Year 5 | 0.00502
Years 6-10 | 0.00509-0.01504
Years 11+ | 0.00653-0.02491
HPV-18 progression to CIN2^12,14‡^
Year 1 | 0.00004
Year 2 | 0.00019
Year 3 | 0.00019
Year 4 | 0.00773
Year 5 | 0.00773
Years 6-10 | 0.00784-0.02314
Years 11+ | 0.01005-0.03835
HPV-18 progression to CIN3^12,14‡^
Year 1 | 0.00001
Year 2 | 0.00005
Year 3 | 0.00005
Year 4 | 0.00194
Year 5 | 0.00194
Years 6-10 | 0.00196-0.00580
Years 11+ | 0.00252-0.00961
HPV-31 progression to CIN2^12,14‡^
Year 1 | 0.00026
Year 2 | 0.00278
Year 3 | 0.00309
Year 4 | 0.00693
Year 5 | 0.00693
Years 6-10 | 0.00702-0.02074
Years 11+ | 0.00901-0.03437
HPV-31 progression to CIN3^12,14‡^
Year 1 | 0.00007
Year 2 | 0.00070
Year 3 | 0.00077
Year 4 | 0.00174
Year 5 | 0.00174
Years 6-10 | 0.00176-0.00520
Years 11+ | 0.00226-0.00861
HPV-33 progression to CIN2^12,14‡^
Year 1 | 0.00072
Year 2 | 0.00072
Year 3 | 0.00494
Year 4 | 0.00494
Year 5 | 0.00494
Years 6-10 | 0.00500-0.01478
Years 11+ | 0.00642-0.02449
HPV-33 progression to CIN3^12,14‡^
Year 1 | 0.00018
Year 2 | 0.00018
Year 3 | 0.00124
Year 4 | 0.00124
Year 5 | 0.00124
Years 6-10 | 0.00125-0.00370
Years 11+ | 0.00161-0.00613
HPV-45 progression to CIN2^12,14‡^
Year 1 | 0.00000
Year 2 | 0.00000
Year 3 | 0.00226
Year 4 | 0.00533
Year 5 | 0.00533
Years 6-10 | 0.00540-0.01596
Years 11+ | 0.00693-0.02645
HPV-45 progression to CIN3^12,14‡^
Year 1 | 0.00000
Year 2 | 0.00000
Year 3 | 0.00056
Year 4 | 0.00134
Year 5 | 0.00134
Years 6-10 | 0.00135-0.00400
Years 11+ | 0.00174-0.00662
HPV-52 progression to CIN2^12,14‡^
Year 1 | 0.00088
Year 2 | 0.00168
Year 3 | 0.00168
Year 4 | 0.00198
Year 5 | 0.00568
Years 6-10 | 0.00575-0.01699
Years 11+ | 0.00738-0.02816
HPV-52 progression to CIN3^12,14‡^
Year 1 | 0.00022
Year 2 | 0.00042
Year 3 | 0.00042
Year 4 | 0.00049
Year 5 | 0.00142
Years 6-10 | 0.00144-0.00426
Years 11+ | 0.00185-0.00705
HPV-58 progression to CIN2^12,14‡^
Year 1 | 0.00059
Year 2 | 0.00247
Year 3 | 0.00247
Year 4 | 0.00462
Year 5 | 0.01025
Years 6-10 | 0.01038-0.03066
Years 11+ | 0.01332-0.05080
HPV-58 progression to CIN3^12,14‡^
Year 1 | 0.00015
Year 2 | 0.00062
Year 3 | 0.00062
Year 4 | 0.00116
Year 5 | 0.00257
Years 6-10 | 0.00261-0.00770
Years 11+ | 0.00334-0.01275
Other carcinogenic HPV progression to CIN2^12,14‡^
Year 1 | 0.00013
Year 2 | 0.00037
Year 3 | 0.00196
Year 4 | 0.00196
Year 5 | 0.00196
Years 6-10 | 0.00199-0.00587
Years 11+ | 0.00255-0.00972
Other carcinogenic HPV progression to CIN3^12,14‡^
Year 1 | 0.00003
Year 2 | 0.00009
Year 3 | 0.00049
Year 4 | 0.00049
Year 5 | 0.00049
Years 6-10 | 0.00050-0.00147
Years 11+ | 0.00064-0.00243
Noncarcinogenic HPV progression to CIN2^12,14‡^
Year 1 | 0.00021
Year 2 | 0.00029
Year 3 | 0.00031
Year 4 | 0.00066
Year 5 | 0.00066
Years 6-10 | 0.00067-0.00199
Years 11+ | 0.00086-0.00329
Noncarcinogenic HPV progression to CIN3^12,14‡^
Year 1 | 0.00002
Year 2 | 0.00003
Year 3 | 0.00003
Year 4 | 0.00007
Year 5 | 0.00007
Years 6-10 | 0.00007-0.00022
Years 11+ | 0.00010-0.00037
Regression of CIN2 related to HPV-16^12,16-20§^
Years 1-5 | 0.04500
Years 6-10 | 0.03600
Years 11-20 | 0.02700
Years 21-30 | 0.00180
Years 31-40 | 0.00090
Years 41 + | 0.00045
Regression of CIN2 related to other hrHPV^12,16-20§^
Years 1-5 | 0.05000
Years 6-10 | 0.04000
Years 11-20 | 0.03000
Years 21-30 | 0.00200
Years 31-40 | 0.00100
Years 41 + | 0.00050
Regression of CIN3 related to HPV-16^12,16-20§^
Years 1-5 | 0.02250
Years 6-10 | 0.01800
Years 11-20 | 0.01350
Years 21-30 | 0.00090
Years 31-40 | 0.00045
Years 41 + | 0.00023
Regression of CIN3 related to other hrHPV^12,16-20§^
Years 1-5 | 0.02500
Years 6-10 | 0.02000
Years 11-20 | 0.01500
Years 21-30 | 0.00100
Years 31-40 | 0.00050
Years 41 + | 0.00025
Progression of CIN2 to invasive cancer related to HPV-16^12,21¶^
Years 1-5 | 0.00003-0.00004
Years 6-10 | 0.00004-0.00005
Years 11-20 | 0.00086-0.00111
Years 21-29 | 0.00251-0.00325
Years 30-34 | 0.00502-0.00650
Years 35-39 | 0.00544-0.00704
Years 40-44 | 0.01171-0.01516
Years 45-49 | 0.01255-0.01624
Years 50+ | 0.07512-0.09724
Progression of CIN2 to invasive cancer related to HPV-18^2,21¶^
Years 1-5 | 0.00003-0.00004
Years 6-10 | 0.00004-0.00005
Years 11-20 | 0.00086-0.00110
Years 21-29 | 0.00252-0.00323
Years 30-34 | 0.00504-0.00646
Years 35-39 | 0.00546-0.00700
Years 40-44 | 0.01177-0.01508
Years 45-49 | 0.01261-0.01615
Years 50+ | 0.07547-0.09671
Progression of CIN2 to invasive cancer related to HPV-33^12,21¶^
Years 1-5 | 0.00003-0.00004
Years 6-10 | 0.00004-0.00005
Years 11-20 | 0.00087-0.00111
Years 21-29 | 0.00254-0.00324
Years 30-34 | 0.00509-0.00648
Years 35-39 | 0.00551-0.00702
Years 40-44 | 0.01187-0.01511
Years 45-49 | 0.01272-0.01619
Years 50+ | 0.07613-0.09693
Progression of CIN2 to invasive cancer related to HPV-31/45/52/58^12,21¶^
Years 1-5 | 0.00002
Years 6-10 | 0.00002
Years 11-20 | 0.00057
Years 21-29 | 0.00167
Years 30-34 | 0.00334
Years 35-39 | 0.00362
Years 40-44 | 0.00780
Years 45-49 | 0.00835
Years 50+ | 0.05000
Progression of CIN2 to invasive cancer related to other hrHPV^12,21¶^
Years 1-5 | 0.00000
Years 6-10 | 0.00000
Years 11-20 | 0.00006-0.00011
Years 21-29 | 0.00017-0.00033
Years 30-34 | 0.00034-0.00067
Years 35-39 | 0.00037-0.00072
Years 40-44 | 0.00079-0.00156
Years 45-49 | 0.00085-0.00167
Years 50+ | 0.00085-0.00167
Progression of CIN3 to invasive cancer related to HPV-16^12,21¶^
Years 1-5 | 0.00017-0.00021
Years 6-10 | 0.00018-0.00023
Years 11-20 | 0.00430-0.00556
Years 21-29 | 0.01259-0.01625
Years 30-34 | 0.02518-0.03251
Years 35-39 | 0.02728-0.03522
Years 40-44 | 0.05875-0.07585
Years 45-49 | 0.06294-0.08127
Years 50+ | 0.07536-0.09731
Progression of CIN3 to invasive cancer related to HPV-18^12,21¶^
Years 1-5 | 0.00017-0.00021
Years 6-10 | 0.00018-0.00023
Years 11-20 | 0.00431-0.00556
Years 21-29 | 0.01259-0.01626
Years 30-34 | 0.02519-0.03253
Years 35-39 | 0.02729-0.03524
Years 40-44 | 0.05877-0.07590
Years 45-49 | 0.06297-0.08132
Years 50+ | 0.07539-0.09737
Progression of CIN3 to invasive cancer related to HPV-33^12,21¶^
Years 1-5 | 0.00016-0.00021
Years 6-10 | 0.00018-0.00023
Years 11-20 | 0.00429-0.00553
Years 21-29 | 0.01254-0.01618
Years 30-34 | 0.02507-0.03237
Years 35-39 | 0.02716-0.03506
Years 40-44 | 0.05850-0.07552
Years 45-49 | 0.06268-0.08092
Years 50+ | 0.07505-0.09688
Progression of CIN3 to invasive cancer related to HPV-31 /45/52/58^12,21¶^
Years 1-5 | 0.00011
Years 6-10 | 0.00012
Years 11-20 | 0.00286
Years 21-29 | 0.00835
Years 30-34 | 0.01670
Years 35-39 | 0.01810
Years 40-44 | 0.03898
Years 45-49 | 0.04176
Years 50+ | 0.05000
Progression of CIN3 to invasive cancer related to other hrHPV^12,21¶^
Years 1-5 | 0.00001-0.00002
Years 6-10 | 0.00001-0.00002
Years 11-20 | 0.00029-0.00056
Years 21-29 | 0.00084-0.00165
Years 30-34 | 0.00168-0.00330
Years 35-39 | 0.00182-0.00358
Years 40-44 | 0.00392-0.00770
Years 45-49 | 0.00420-0.00825
Years 50+ | 0.00420-0.00825
Progression of invasive cancer stages^11,22^
Local to regional | 0.02000
Regional to distant | 0.02500
Invasive cancer mortality^11∥^
Local
Year 1 | 0.00159
Years 2-3 | 0.00141
Years 4-20 | 0.00094
Regional
Year 1 | 0.00946
Years 2-3 | 0.00781
Years 4-20 | 0.00362
Distant
Year 1 | 0.02934
Years 2-3 | 0.01947
Years 4-20 | 0.00760
Probability of symptom detection^11,22^
Local | 0.01740
Regional | 0.07350
Distant | 0.17460

* Values represent monthly probabilities, unless otherwise noted; values represent the range of probabilities across the 50 best-fitting sets; parameters without a range of values were held constant across the 50 best-fitting sets.

† Natural immunity represents the percentage reduction in risk of subsequent, type-specific infection after a woman has cleared a carcinogenic infection with the same type. Risk reduction is assumed to be constant across age, time, and genotype.

‡ HPV clearance and progression probabilities are a function of time since infection (i.e., persistence).

§ Precancer regression probabilities decrease by time since lesion onset and are constant across carcinogenic HPV types. Given limited data, we assumed that the monthly CIN3 regression probability is 50% of CIN2 regression; 50% regress to type-specific HPV-infected health states and 50% regress to the normal health state.

¶ Precancer progression probabilities increase by time since lesion onset and are constant across carcinogenic HPV types, CIN2 progression is set at 20% of CIN3 progression (for carcinogenic types only).

∥ In addition to time since diagnosis, cancer mortality was adjusted for age at diagnosis by applying stage-specific multipliers to the baseline probabilities that ranged from 0.30 to 7.39 for local cancer; 0.39 to 1.30 for regional cancer; and 0.002 to 15.16 for distant cancer.

Abbreviations: CIN2, cervical intraepithelial neoplasia grade 2; CIN3, cervical intraepithelial neoplasia grade 3; HPV, human papillomavirus; HR, high-risk.

Appendix Table 2 Efficient Cervical Cancer Screening Strategies (Screening End Age 65) in Terms of Colposcopies per Life-Year Gained

#, Strategy | Colpos | Δ Colpos^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δcolpo/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21 | 645 | 645 | 64181.89 | 260.56 | 3
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 1635 | 990 | 64193.38 | 11.45 | 86
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 1861 | 227 | 64194.69 | 1.31 | 173
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 2068 | 206 | 64195.39 | 0.69 | 297
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2528 | 461 | 64195.61 | 0.22 | 2,082
Scenario B
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21 | 645 | 645 | 64181.89 | 260.56 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 64193.07 | 11.14 | 73
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 64194.44 | 1.37 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 64195.35 | 0.91 | 195
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 64195.53 | 0.18 | 2,188
Scenario C
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21 | 645 | 645 | 64181.89 | 260.56 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 64193.07 | 11.14 | 73
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 64194.44 | 1.37 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 64195.35 | 0.91 | 19
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 64195.53 | 0.18 | 2,188
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2530 | 321 | 64195.61 | 0.08 | 3,822
Scenario D
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21 | 645 | 645 | 64181.89 | 260.56 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 64193.07 | 11.14 | 73
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 64194.44 | 1.37 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 64195.35 | 0.91 | 195
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 64195.53 | 0.18 | 2,188
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2530 | 321 | 64195.61 | 0.08 | 3,822

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 3 Efficient Cervical Cancer Screening Strategies (Screening End Age 65 Years) in Terms of Tests per Life-Year Gained

#, Strategy | Screening tests | Δ Tests^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δtests/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 11771 | 11771 | 64195.39 | 274.05 | 43
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 16712 | 4942 | 64195.61 | 0.22 | 22,335
Scenario B
0, No screening | 0 | | 63921.34
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 12042 | 12042 | 64195.35 | 274.01 | 44
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 17067 | 5025 | 64195.53 | 0.18 | 28,636
Scenario C
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 11771 | 11771 | 64195.39 | 274.05 | 43
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 16712 | 4942 | 64195.61 | 0.22 | 22,335
Scenario D
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 11771 | 11771 | 64195.39 | 274.05 | 43
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 16712 | 4942 | 64195.61 | 0.22 | 22,335

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 4 Efficient Cervical Cancer Screening Strategies (Screening End Age 65 Years) in Terms of Colposcopies per Cervical Cancer Case Averted^*^

#, Strategy | Colpos | Δ Colpos^†^ | Cancer cases averted | Δ Cases averted^†^ | Efficiency ratio (Δcolpo/Δcases averted)
Scenario A
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21 | 645 | 645 | 16.52 | 16.52 | 39
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 1635 | 990 | 17.81 | 1.29 | 766
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 1861 | 227 | 17.97 | 0.16 | 1,432
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 2068 | 206 | 18.07 | 0.10 | 2,120
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2530 | 463 | 18.12 | 0.05 | 8,580
Scenario B
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21 | 645 | 645 | 16.52 | 16.52 | 39
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 17.78 | 1.26 | 640
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 17.95 | 0.17 | 1,161
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 18.05 | 0.10 | 1,735
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 18.11 | 0.05 | 7,018
Scenario C
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21 | 645 | 645 | 16.52 | 16.52 | 39
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 17.78 | 1.26 | 640
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 17.95 | 0.17 | 1,161
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 18.05 | 0.10 | 1,735
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 18.11 | 0.05 | 7,018
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2530 | 321 | 18.12 | 0.01 | 23,974
Scenario D
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21 | 645 | 645 | 16.52 | 16.52 | 39
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 1452 | 807 | 17.78 | 1.26 | 640
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 1648 | 196 | 17.95 | 0.17 | 1,161
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1826 | 177 | 18.05 | 0.10 | 1,735
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2209 | 384 | 18.11 | 0.05 | 7,018
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 2530 | 321 | 18.12 | 0.01 | 23,974

* Cervical cancer cases averted, compared to no intervention (i.e., natural history).

† Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 5 Efficient Cervical Cancer Screening Strategies (Screening End Age 70 Years) in Terms of Colposcopies per Life-Year Gained

#, Strategy | Colpos | Δ Colpos^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δcolpo/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-70 | 689 | 689 | 64184.58 | 263.24 | 3
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-70 | 1700 | 1011 | 64194.50 | 9.93 | 102
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-70 | 1930 | 230 | 64195.84 | 1.34 | 172
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 2134 | 203 | 64196.47 | 0.63 | 321
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 486 | 64196.60 | 0.13 | 3,747
Scenario B
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-70 | 689 | 689 | 64184.58 | 263.24 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 64194.18 | 9.61 | 85
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 64195.57 | 1.39 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 64196.41 | 0.84 | 208
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 64196.52 | 0.11 | 3,758
Scenario C
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-70 | 689 | 689 | 64184.58 | 263.24 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 64194.18 | 9.61 | 85
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 64195.57 | 1.39 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 64196.41 | 0.84 | 208
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 64196.52 | 0.11 | 3,758
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 337 | 64196.60 | 0.08 | 4,014
Scenario D
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-70 | 689 | 689 | 64184.58 | 263.24 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 64194.18 | 9.61 | 85
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 64195.57 | 1.39 | 143
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 64196.41 | 0.84 | 208
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 64196.52 | 0.11 | 3,758
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 337 | 64196.60 | 0.08 | 4,014

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 6 Efficient Cervical Cancer Screening Strategies (Screening End Age 70 Years) in Terms of Tests per Life-Year Gained

#, Strategy | Screening tests | Δ Tests^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δtests/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 12536 | 64196.47 | 275.14 | 46
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 17965 | 5428 | 64196.60 | 0.13 | 41,852
Scenario B
0, No screening | 0 | | 63921.34
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 12818 | 12818 | 64196.41 | 275.07 | 47
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 18306 | 5488 | 64196.52 | 0.11 | 51,383
Scenario C
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 12536 | 64196.47 | 275.14 | 46
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 17965 | 5428 | 64196.60 | 0.13 | 41,852
Scenario D
0, No screening | | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 12536 | 64196.47 | 275.14 | 46
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 17965 | 5428 | 64196.60 | 0.13 | 41,852

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 7 Efficient Cervical Cancer Screening Strategies (Screening End Age 70 Years) in Terms of Colposcopies per Cervical Cancer Case Averted^*^

#, Strategy | Colpos | Δ Colpos^†^ | Cancer cases averted | Δ Cases averted^†^ | Efficiency ratio (Δcolpo/Δcases averted)
Scenario A
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-70 | 689 | 689 | 16.88 | 16.88 | 41
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-70 | 1700 | 1011 | 18.01 | 1.13 | 898
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-70 | 1930 | 230 | 18.17 | 0.17 | 1,391
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 2134 | 203 | 18.26 | 0.09 | 2,375
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 486 | 18.30 | 0.04 | 12,631
Scenario B
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-70 | 689 | 689 | 16.88 | 16.88 | 41
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 17.97 | 1.09 | 748
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 18.15 | 0.18 | 1,134
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 18.24 | 0.09 | 1,914
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 18.28 | 0.04 | 9,848
Scenario C
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-70 | 689 | 689 | 16.88 | 16.88 | 41
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 17.97 | 1.09 | 748
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 18.15 | 0.18 | 1,134
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 18.24 | 0.09 | 1,914
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 18.28 | 0.04 | 9,848
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 337 | 18.30 | 0.01 | 23,361
Scenario D
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-70 | 689 | 689 | 16.88 | 16.88 | 41
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 819 | 17.97 | 1.09 | 748
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-70 | 1706 | 199 | 18.15 | 0.18 | 1,134
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 1881 | 175 | 18.24 | 0.09 | 1,914
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-70 | 2283 | 401 | 18.28 | 0.04 | 9,848
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-70 | 2620 | 337 | 18.30 | 0.01 | 23,361

* Cervical cancer cases averted, compared to no intervention (i.e., natural history).

† Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 8 Efficient Cervical Cancer Screening Strategies (Screening End Age 75 Years) in Terms of Colposcopies per Life-Year Gained

#, Strategy | Colpos | Δ Colpos^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δcolpo/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-75 | 724 | 724 | 64185.93 | 264.59 | 3
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-75 | 1752 | 1028 | 64194.93 | 9.00 | 114
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-75 | 1984 | 232 | 64196.36 | 1.43 | 163
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 202 | 64196.93 | 0.57 | 353
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 501 | 64197.01 | 0.08 | 5,972
Scenario B
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-75 | 724 | 724 | 64185.93 | 264.59 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 64194.63 | 8.71 | 95
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 414 | 64196.93 | 0.04 | 10,854
Scenario C
0. No screening | 0 | | 63921.34
1, CYTO-3Y, 21-75 | 724 | 724 | 64185.93 | 264.59 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 64194.63 | 8.71 | 95
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 762 | 64197.01 | 0.12 | 6,239
Scenario D
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-75 | 724 | 724 | 64185.93 | 264.59 | 3
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 64194.63 | 8.71 | 95
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
3, CYTO-4Y, 21 / HPV-3Y (16/18). 25-75 | 2687 | 762 | 64197.01 | 0.12 | 6,239

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos; colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 9 Efficient Cervical Cancer Screening Strategies (Screening End Age 75 Years) in Terms of Tests per Life-Year Gained

#, Strategy | Screening tests | Δ Tests^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δtests/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 13222 | 64196.93 | 275.59 | 48
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063
Scenario B
0, No screening | 0 | | 63921.34
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 13512 | 13512 | 64196.89 | 275.55 | 49
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 19380 | 5868 | 64196.93 | 0.04 | 153,816
Scenario C
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 13222 | 64196.93 | 275.59 | 48
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063
Scenario D
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 13222 | 64196.93 | 275.59 | 48
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 10 Efficient Cervical Cancer Screening Strategies (Screening End Age 75 Years) in Terms of Colposcopies per Cervical Cancer Case Averted^*^

#, Strategy | Colpos | Δ Colpos^†^ | Cancer cases averted | Δ Cases averted^†^ | Efficiency ratio (Δcolpo/Δcases averted)
Scenario A
0, No screening | 0 | | 0.00 | | --
1, CYTO-3Y, 21-75 | 724 | 724 | 17.10 | 17.10 | 42
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-75 | 1752 | 1028 | 18.11 | 1.01 | 1,020
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-75 | 1984 | 232 | 18.28 | 0.17 | 1,333
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 202 | 18.36 | 0.08 | 2,479
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 501 | 18.38 | 0.02 | 23,138
Scenario B
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-75 | 724 | 724 | 17.10 | 17.10 | 42
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 414 | 18.37 | 0.02 | 17,110
Scenario C
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-75 | 724 | 724 | 17.10 | 17.10 | 42
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 260 | 18.36 | 0.02 | 15,899
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 154 | 18.37 | 0.01 | 19,645
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 348 | 18.38 | 0.01 | 25,112
Scenario D
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-75 | 724 | 724 | 17.10 | 17.10 | 42
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 260 | 18.36 | 0.02 | 15,899
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 154 | 18.37 | 0.01 | 19,645
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 348 | 18.38 | 0.01 | 25,112

* Cervical cancer cases averted, compared to no intervention (i.e., natural history).

† Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 11 Efficient Cervical Cancer Screening Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age in Terms of Colposcopies per Life-Year Gained

#, Strategy | Colpos | Δ Colpos^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δcolpo/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-65 | 645 | 645 | 64181.89 | 260.56 | 3
1, CYTO-3Y, 21-70 | 689 | 44 | 64184.58 | 2.65 | 17
1, CYTO-3Y, 21-75 | 724 | 36 | 64185.93 | 1.35 | 26
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-70 | 1700 | 976 | 64194.50 | 8.58 | 114
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-75 | 1752 | 52 | 64194.93 | 0.43 | 123
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-75 | 1984 | 232 | 64196.36 | 1.43 | 163
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 202 | 64196.93 | 0.57 | 353
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 501 | 64197.01 | 0.08 | 5,972
Scenario B
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-65 | 645 | 645 | 64181.89 | 260.56 | 3
1, CYTO-3Y, 21-70 | 689 | 44 | 64184.58 | 2.65 | 17
1, CYTO-3Y, 21-75 | 724 | 36 | 64185.93 | 1.35 | 26
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 783 | 64194.18 | 8.26 | 95
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 44 | 64194.63 | 0.45 | 99
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
9, CYTO-4Y, 21 / HPV-3Y (cyto). 25-75 | 2340 | 414 | 64196.93 | 0.04 | 10,854
Scenario C
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-65 | 645 | 645 | 64181.89 | 260.56 | 3
1, CYTO-3Y, 21-70 | 689 | 44 | 64184.58 | 2.65 | 17
1, CYTO-3Y, 21-75 | 724 | 36 | 64185.93 | 1.35 | 26
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 783 | 64194.18 | 8.26 | 95
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 44 | 64194.63 | 0.45 | 99
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 762 | 64197.01 | 0.12 | 6,239
Scenario D
0, No screening | 0 | | 63921.34
1, CYTO-3Y, 21-65 | 645 | 645 | 64181.89 | 260.56 | 3
1, CYTO-3Y, 21-70 | 689 | 44 | 64184.58 | 2.65 | 17
1, CYTO-3Y, 21-75 | 724 | 36 | 64185.93 | 1.35 | 26
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-70 | 1508 | 783 | 64194.18 | 8.26 | 95
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 44 | 64194.63 | 0.45 | 99
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 64196.12 | 1.49 | 135
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 64196.89 | 0.77 | 225
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 762 | 64197.01 | 0.12 | 6,239

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos; colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 12 Efficient Cervical Cancer Screening Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age in Termsof Tests per Life-Year Gained

#, Strategy | Screening tests | Δ Tests^*^ | Life-years | Δ Life-years^*^ | Efficiency ratio (Δtests/ΔLY)
Scenario A
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | 11771 | 11771 | 64195.39 | 274.05 | 43
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 766 | 64196.47 | 1.08 | 707
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 685 | 64196.93 | 0.46 | 1,497
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063
Scenario B
0, No screening | 0 | | 63921.34
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-65 | 12042 | 12042 | 64195.35 | 274.01 | 44
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-70 | 12818 | 776 | 64196.41 | 1.06 | 731
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 13512 | 694 | 64196.89 | 0.48 | 1,444
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 19380 | 5868 | 64196.93 | 0.04 | 153,816
Scenario C
0, No screening | 0 | | 63921.34
6, CYÏO-4Y, 21 / HPV-5Y (16/18), 25-65 | 11771 | 11771 | 64195.39 | 274.05 | 43
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 766 | 64196.47 | 1.08 | 707
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 685 | 64196.93 | 0.46 | 1,497
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063
Scenario D
0, No screening | 0 | | 63921.34
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-65 | 11771 | 11771 | 64195.39 | 274.05 | 43
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-70 | 12536 | 766 | 64196.47 | 1.08 | 707
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 13222 | 685 | 64196.93 | 0.46 | 1,497
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 19018 | 5796 | 64197.01 | 0.08 | 69,063

* Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus; LY: life-year.

Appendix Table 13 Efficient Cervical Cancer Screening Strategies, Varying HPV Testing Switch Age, Interval, and Screening End Age in Terms of Colposcopies per Cervical Cancer Case Averted^*^

#, Strategy | Colpos | Δ Colpos^†^ | Cancer cases averted | Δ Cases averted^†^ | Efficiency ratio (Δcolpo/Δcases averted)
Scenario A
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-65 | 645 | 645 | 16.52 | 16.52 | 39
1, CYTO-3Y, 21-70 | 689 | 44 | 16.88 | 0.36 | 122
1, CYTO-3Y, 21-75 | 724 | 36 | 17.10 | 0.22 | 162
8, CYTO-3Y, 21 / HPV-5Y (16/18), 30-75 | 1752 | 1028 | 18.11 | 1.01 | 1,020
7, CYTO-3Y, 21 / HPV-5Y (16/18), 27-75 | 1984 | 232 | 18.28 | 0.17 | 1,333
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 202 | 18.36 | 0.08 | 2,479
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 501 | 18.38 | 0.02 | 23,138
Scenario B
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-65 | 645 | 645 | 16.52 | 16.52 | 39
1, CYTO-3Y, 21-70 | 689 | 44 | 16.88 | 0.36 | 122
1, CYTO-3Y, 21-75 | 724 | 36 | 17.10 | 0.22 | 162
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 414 | 18.37 | 0.02 | 17,110
Scenario C
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-65 | 645 | 645 | 16.52 | 16.52 | 39
1, CYTO-3Y, 21-70 | 689 | 44 | 16.88 | 0.36 | 122
1, CYTO-3Y, 21-75 | 724 | 36 | 17.10 | 0.22 | 162
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
6. CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 260 | 18.36 | 0.02 | 15,899
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 154 | 18.37 | 0.01 | 19,645
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 348 | 18.38 | 0.01 | 25,112
Scenario D
0, No screening | 0 | | 0.00
1, CYTO-3Y, 21-65 | 645 | 645 | 16.52 | 16.52 | 39
1, CYTO-3Y, 21-70 | 689 | 44 | 16.88 | 0.36 | 122
1, CYTO-3Y, 21-75 | 724 | 36 | 17.10 | 0.22 | 162
14, CYTO-3Y, 21 / HPV-5Y (cyto), 30-75 | 1552 | 827 | 18.08 | 0.98 | 847
13, CYTO-3Y, 21 / HPV-5Y (cyto), 27-75 | 1752 | 200 | 18.26 | 0.19 | 1,081
12, CYTO-4Y, 21 / HPV-5Y (cyto), 25-75 | 1926 | 174 | 18.35 | 0.08 | 2,064
6, CYTO-4Y, 21 / HPV-5Y (16/18), 25-75 | 2186 | 260 | 18.36 | 0.02 | 15,899
9, CYTO-4Y, 21 / HPV-3Y (cyto), 25-75 | 2340 | 154 | 18.37 | 0.01 | 19,645
3, CYTO-4Y, 21 / HPV-3Y (16/18), 25-75 | 2687 | 348 | 18.38 | 0.01 | 25,112

* Cervical cancer cases averted, compared to no intervention (i.e., natural history).

† Incremental values may be slightly different due to rounding.

Abbreviations: Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 14 Range of Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years) Across 50 Best-Fitting Parameter Sets

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | CIN3+ detected^†^ | False positives^‡^ | CC cases | CC deaths | Life-years
0 | No screening | 0 (0-0) | 0 (0-0) | 0 (0-0) | 0 (0-0) | 0 (0-0) | 0 (0-0) | 0 (0-0) | 18.86 (13.05-24.07) | 8.34 (5.78-10.76) | 63921.34 (63844.9-64006.01)
1 | CYTO-3Y, 21 | 13877 (13806-13939) | 786 (773-797) | 14662 (14579-14736) | 645 (593-691) | 160 (121-197) | 46 (35-57) | 484 (473-495) | 2.34 (1.75-2.84) | 0.76 (0.54-0.99) | 64181.89 (64178.07-64185.61)
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11425 (11185-11641) | 8380 (8139-8602) | 19806 (19324-20243) | 1630 (1393-1864) | 201 (150-248) | 54 (41-66) | 1429 (1243-1616) | 1.08 (0.8-1.34) | 0.3 (0.2-0.43) | 64192.97 (64191.52-64194.54)
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1905 (1798-2020) | 14807 (14432-15116) | 16712 (16230-17136) | 2530 (2159-2889) | 218 (164-269) | 57 (43-70) | 2312 (1995-2620) | 0.74 (0.52-0.93) | 0.23 (0.13-0.34) | 64195.61 (64194.38-64196.64)
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2876 (2780-2989) | 13772 (13423-14066) | 16648 (16203-17056) | 2278 (1942-2611) | 214 (161-264) | 56 (44-70) | 2063 (1781-2348) | 0.83 (0.6-1.02) | 0.25 (0.15-0.36) | 64195.08 (64193.92-64196.34)
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3824 (3740-3929) | 12428 (12124-12692) | 16252 (15865-16621) | 1978 (1688-2273) | 205 (153-252) | 54 (41-67) | 1773 (1535-2021) | 1.01 (0.76-1.26) | 0.27 (0.18-0.38) | 64193.51 (64192.11-64195.08)
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1706 (1625-1793) | 10065 (9703-10377) | 11771 (11328-12170) | 2068 (1743-2386) | 211 (159-259) | 55 (42-68) | 1857 (1585-2127) | 0.79 (0.54-1.02) | 0.25 (0.14-0.37) | 64195.39 (64194.02-64196.61)
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2697 (2626-2785) | 9290 (8947-9588) | 11987 (11573-12373) | 1861 (1568-2157) | 207 (155-255) | 55 (42-67) | 1655 (1413-1902) | 0.89 (0.63-1.12) | 0.28 (0.16-0.41) | 64194.69 (64193.29-64196.03)
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3675 (3609-3759) | 8476 (8195-8735) | 12151 (11805-12495) | 1635 (1382-1897) | 199 (149-246) | 53 (41-66) | 1435 (1233-1652) | 1.05 (0.77-1.31) | 0.29 (0.18-0.4) | 64193.38 (64191.97-64194.94)
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2277 (2085-2415) | 14790 (14425-15090) | 17067 (16510-17506) | 2209 (1855-2530) | 217 (163-267) | 56 (43-69) | 1992 (1693-2263) | 0.75 (0.53-0.94) | 0.23 (0.13-0.33) | 64195.53 (64194.5-64196.58)
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3205 (3021-3339) | 13738 (13395-14026) | 16943 (16416-17364) | 1992 (1673-2288) | 213 (160-262) | 56 (42-70) | 1779 (1513-2027) | 0.85 (0.62-1.06) | 0.25 (0.15-0.36) | 64194.82 (64193.64-64196.11)
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4102 (3931-4226) | 12397 (12097-12655) | 16499 (16029-16882) | 1734 (1459-1996) | 203 (153-251) | 54 (41-67) | 1530 (1307-1746) | 1.04 (0.78-1.3) | 0.28 (0.18-0.39) | 64193.19 (64191.76-64194.63)
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1993 (1851-2101) | 10049 (9696-10351) | 12042 (11547-12452) | 1826 (1515-2114) | 209 (157-257) | 55 (42-67) | 1617 (1358-1857) | 0.81 (0.56-1.04) | 0.25 (0.14-0.38) | 64195.35 (64194.07-64196.59)
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2950 (2810-3055) | 9273 (8938-9564) | 12223 (11748-12619) | 1648 (1368-1915) | 205 (154-253) | 54 (41-67) | 1443 (1215-1663) | 0.91 (0.64-1.15) | 0.28 (0.16-0.41) | 64194.44 (64193.09-64195.79)
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3888 (3757-3989) | 8459 (8183-8713) | 12348 (11940-12701) | 1452 (1211-1690) | 198 (148-244) | 53 (40-66) | 1254 (1063-1446) | 1.08 (0.79-1.35) | 0.29 (0.19-0.42) | 64193.07 (64191.49-64194.47)
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15723 (15411-15979) | 14693 (14383-14950) | 30416 (29794-30929) | 2535 (2188-2851) | 223 (167-275) | 57 (43-70) | 2312 (2022-2577) | 0.76 (0.54-0.95) | 0.23 (0.13-0.34) | 64195.5 (64194.52-64196.49)
16 | CYTO-3Y. 21 / COTEST-3Y, 27 | 15765 (15470-16009) | 13723 (13432-13969) | 29488 (28901-29978) | 2303 (1990-2596) | 218 (163-269) | 57 (43-70) | 2084 (1827-2327) | 0.83 (0.6-1.03) | 0.25 (0.15-0.36) | 64194.75 (64193.45-64195.79)
17 | CYTO-3Y, 21 / COTEST-3Y, 30 | 15456 (15192-15674) | 12411 (12156-12635) | 27867 (27348-28309) | 2021 (1750-2280) | 209 (156-257) | 55 (42-68) | 1812 (1595-2023) | 1.03 (0.77-1.28) | 0.27 (0.18-0.38) | 64193.17 (64191.94-64194.73)
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10944 (10638-11204) | 9914 (9609-10175) | 20859 (20247-21380) | 2029 (1723-2313) | 213 (160-263) | (42-68) | 1816 (1564-2051) | 0.82 (0.58-1.06) | 0.26 (0.14-0.39) | 64195.26 (64194.02-64196.45)
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11275 (10985-11524) | 9233 (8942-9485) | 20508 (19927-21008) | 1846 (1570-2110) | 209 (156-258) | 55 (42-68) | 1637 (1414-1853) | 0.89 (0.64-1.11) | 0.27 (0.17-0.4) | 64194.4 (64192.85-64195.58)

* Total number of tests, irrespective of primary, triage, or surveillance context.

† CIN3+ includes CIN3 and cervical cancer detected through screening (excludes clinically-detected cancer).

‡ Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 15 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years) Assuming Cytology Sensitivity of 81.5%and Specificity of 88.0%

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 14116 | 1164 | 15280 | 904 | 173 | 730 | 1.99 | 0.66 | 64185.81
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11574 | 8537 | 20111 | 1818 | 208 | 1610 | 0.99 | 0.29 | 64193.80
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1939 | 14829 | 16768 | 2585 | 221 | 2364 | 0.72 | 0.23 | 64195.66
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2934 | 13821 | 16755 | 2352 | 218 | 2134 | 0.79 | 0.24 | 64195.35
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3903 | 12504 | 16407 | 2071 | 210 | 1860 | 0.92 | 0.26 | 64194.18
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1740 | 10088 | 11828 | 2115 | 213 | 1902 | 0.77 | 0.25 | 64195.45
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2755 | 9342 | 12097 | 1930 | 211 | 1718 | 0.85 | 0.27 | 64194.97
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3754 | 8540 | 12294 | 1720 | 205 | 1515 | 0.96 | 0.28 | 64194.05
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2310 | 14812 | 17122 | 2279 | 220 | 2059 | 0.73 | 0.23 | 64195.57
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3261 | 13790 | 17051 | 2079 | 217 | 1862 | 0.80 | 0.24 | 64195.29
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4180 | 12475 | 16656 | 1838 | 209 | 1628 | 0.94 | 0.27 | 64194.00
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 2027 | 10072 | 12099 | 1884 | 212 | 1671 | 0.78 | 0.25 | 64195.42
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 3006 | 9326 | 12333 | 1726 | 210 | 1516 | 0.86 | 0.27 | 64194.93
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3966 | 8523 | 12490 | 1546 | 204 | 1342 | 0.98 | 0.28 | 64193.86
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15893 | 14859 | 30752 | 2771 | 227 | 2544 | 0.73 | 0.23 | 64195.59
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15952 | 13911 | 29864 | 2548 | 224 | 2324 | 0.78 | 0.24 | 64195.27
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15650 | 12613 | 28263 | 2268 | 215 | 2053 | 0.92 | 0.26 | 64194.05
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 11080 | 10046 | 21126 | 2196 | 217 | 1979 | 0.80 | 0.26 | 64195.34
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11439 | 9398 | 20837 | 2027 | 215 | 1812 | 0.84 | 0.27 | 64194.89

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 16 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years) Assuming Cytology Sensitivity of 51.4%and Specificity of 93.6%

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13723 | 614 | 14336 | 506 | 128 | 377 | 3.64 | 1.16 | 64166.02
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11357 | 8327 | 19684 | 1542 | 185 | 1356 | 1.39 | 0.33 | 64190.18
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1881 | 14805 | 16686 | 2505 | 213 | 2292 | 0.79 | 0.23 | 64195.32
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2835 | 13757 | 16592 | 2240 | 204 | 2036 | 0.95 | 0.26 | 64193.95
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3767 | 12400 | 16168 | 1929 | 191 | 1738 | 1.29 | 0.31 | 64190.86
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1682 | 10063 | 11745 | 2046 | 205 | 1841 | 0.84 | 0.26 | 64195.11
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2656 | 9275 | 11931 | 1828 | 197 | 1631 | 1.01 | 0.29 | 64193.55
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3619 | 8458 | 12077 | 1590 | 185 | 1405 | 1.32 | 0.32 | 64190.74
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2253 | 14792 | 17045 | 2177 | 209 | 1968 | 0.82 | 0.24 | 64195.01
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3165 | 13726 | 16891 | 1949 | 201 | 1747 | 1.01 | 0.27 | 64193.42
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4047 | 12371 | 16418 | 1681 | 188 | 1492 | 1.36 | 0.32 | 64190.10
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1970 | 10051 | 12021 | 1799 | 201 | 1598 | 0.88 | 0.26 | 64194.82
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2910 | 9262 | 12172 | 1611 | 194 | 1416 | 1.07 | 0.30 | 64193.02
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3834 | 8445 | 12280 | 1404 | 183 | 1221 | 1.39 | 0.34 | 64189.96
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15652 | 14632 | 30284 | 2431 | 214 | 2216 | 0.83 | 0.24 | 64195.03
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15680 | 13651 | 29331 | 2192 | 206 | 1986 | 0.99 | 0.26 | 64193.57
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15361 | 12332 | 27693 | 1905 | 192 | 1712 | 1.34 | 0.31 | 64190.34
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10890 | 9870 | 20760 | 1956 | 204 | 1751 | 0.88 | 0.27 | 64194.80
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11202 | 9174 | 20376 | 1764 | 197 | 1567 | 1.05 | 0.29 | 64193.24

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 17 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming Lower HPV Sensitivity (Relative Sensitivity of 1.15)

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13864 | 785 | 14649 | 632 | 158 | 473 | 2.43 | 0.79 | 64180.92
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11128 | 8088 | 19217 | 1308 | 185 | 1123 | 1.52 | 0.47 | 64189.04
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1907 | 14528 | 16435 | 2120 | 206 | 1913 | 0.91 | 0.28 | 64194.24
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2876 | 13519 | 16395 | 1915 | 203 | 1712 | 1.01 | 0.30 | 64193.56
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3820 | 12214 | 16034 | 1671 | 195 | 1476 | 1.19 | 0.33 | 64191.86
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1705 | 9769 | 11474 | 1701 | 195 | 1506 | 1.12 | 0.34 | 64192.65
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2695 | 9025 | 11719 | 1540 | 192 | 1347 | 1.21 | 0.37 | 64191.67
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3670 | 8260 | 11930 | 1362 | 186 | 1175 | 1.33 | 0.38 | 64190.44
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2280 | 14489 | 16770 | 1791 | 203 | 1588 | 0.99 | 0.30 | 64193.53
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3204 | 13466 | 16670 | 1622 | 200 | 1422 | 1.08 | 0.32 | 64192.81
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4098 | 12166 | 16264 | 1423 | 192 | 1230 | 1.26 | 0.35 | 64191.07
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1990 | 9726 | 11715 | 1452 | 190 | 1262 | 1.25 | 0.38 | 64191.17
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2943 | 8986 | 11929 | 1322 | 188 | 1133 | 1.31 | 0.40 | 64190.44
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3880 | 8222 | 12103 | 1176 | 183 | 992 | 1.44 | 0.41 | 64189.18
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15371 | 14344 | 29716 | 2069 | 208 | 1861 | 1.07 | 0.34 | 64193.27
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15447 | 13409 | 28856 | 1890 | 205 | 1684 | 1.12 | 0.35 | 64192.70
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15184 | 12144 | 27328 | 1671 | 197 | 1474 | 1.30 | 0.38 | 64190.99
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10545 | 9517 | 20062 | 1595 | 192 | 1402 | 1.36 | 0.44 | 64190.84
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 10920 | 8881 | 19801 | 1464 | 190 | 1273 | 1.39 | 0.45 | 64190.12

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 18 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming Imperfect Colposcopy/Biopsy Performance

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13912 | 793 | 14705 | 672 | 138 | 534 | 2.71 | 0.85 | 64178.64
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11331 | 8282 | 19613 | 1428 | 153 | 1275 | 1.19 | 0.31 | 64192.14
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1918 | 14520 | 16438 | 2142 | 151 | 1991 | 0.77 | 0.23 | 64195.37
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2888 | 13517 | 16405 | 1939 | 152 | 1787 | 0.89 | 0.25 | 64194.63
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3836 | 12212 | 16048 | 1698 | 149 | 1548 | 1.13 | 0.28 | 64192.79
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1715 | 9778 | 11493 | 1739 | 150 | 1589 | 0.82 | 0.26 | 64195.17
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2705 | 9041 | 11747 | 1577 | 151 | 1426 | 0.95 | 0.29 | 64194.24
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3684 | 8264 | 11949 | 1399 | 148 | 1251 | 1.16 | 0.30 | 64192.68
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2295 | 14561 | 16856 | 1859 | 153 | 1705 | 0.79 | 0.23 | 64195.24
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3221 | 13534 | 16755 | 1686 | 154 | 1533 | 0.92 | 0.26 | 64194.35
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4117 | 12225 | 16343 | 1484 | 151 | 1333 | 1.15 | 0.29 | 64192.43
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 2006 | 9818 | 11824 | 1529 | 152 | 1377 | 0.84 | 0.26 | 64195.00
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2960 | 9070 | 12031 | 1392 | 152 | 1240 | 0.97 | 0.28 | 64193.99
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3900 | 8292 | 12193 | 1242 | 150 | 1092 | 1.19 | 0.30 | 64192.31
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15594 | 14561 | 30154 | 2192 | 158 | 2034 | 0.78 | 0.23 | 64195.34
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15651 | 13606 | 29257 | 2005 | 158 | 1847 | 0.90 | 0.25 | 64194.23
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15364 | 12315 | 27679 | 1776 | 155 | 1621 | 1.13 | 0.28 | 64192.33
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10803 | 9770 | 20573 | 1739 | 155 | 1583 | 0.85 | 0.27 | 64195.08
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11146 | 9102 | 20248 | 1595 | 155 | 1440 | 0.96 | 0.28 | 64193.86

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 19 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming CIN2/CIN3 Treatment Effectiveness of 82%

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13891 | 791 | 14682 | 668 | 183 | 484 | 2.62 | 0.81 | 64179.95
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11458 | 8412 | 19870 | 1675 | 231 | 1443 | 1.24 | 0.32 | 64191.94
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1906 | 14841 | 16746 | 2584 | 252 | 2331 | 0.85 | 0.24 | 64194.91
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2877 | 13804 | 16682 | 2328 | 247 | 2081 | 0.96 | 0.26 | 64194.44
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3827 | 12457 | 16284 | 2023 | 235 | 1787 | 1.17 | 0.29 | 64192.55
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1707 | 10106 | 11813 | 2121 | 244 | 1877 | 0.91 | 0.26 | 64194.71
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2699 | 9328 | 12026 | 1911 | 238 | 1672 | 1.02 | 0.29 | 64194.07
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3679 | 8511 | 12190 | 1680 | 229 | 1450 | 1.21 | 0.30 | 64192.42
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2276 | 14823 | 17100 | 2264 | 250 | 2013 | 0.87 | 0.24 | 64194.84
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3205 | 13770 | 16975 | 2042 | 245 | 1797 | 0.99 | 0.26 | 64194.17
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4105 | 12425 | 16530 | 1780 | 234 | 1545 | 1.21 | 0.30 | 64192.14
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1994 | 10088 | 12082 | 1879 | 241 | 1637 | 0.93 | 0.27 | 64194.65
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2950 | 9309 | 12260 | 1698 | 237 | 1461 | 1.05 | 0.29 | 64193.79
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3892 | 8493 | 12385 | 1497 | 228 | 1269 | 1.24 | 0.31 | 64192.05
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15755 | 14724 | 30479 | 2589 | 257 | 2332 | 0.88 | 0.24 | 64194.91
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15796 | 13753 | 29549 | 2354 | 251 | 2102 | 0.97 | 0.26 | 64194.13
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15485 | 12438 | 27923 | 2066 | 240 | 1826 | 1.18 | 0.29 | 64192.16
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10982 | 9951 | 20934 | 2082 | 246 | 1836 | 0.95 | 0.27 | 64194.68
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11310 | 9267 | 20577 | 1896 | 241 | 1654 | 1.03 | 0.29 | 64193.76

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 20

Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming Referral to Colposcopy for LSIL or Worse Result on Cytology Triage

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13877 | 786 | 14662 | 645 | 160 | 484 | 2.34 | 0.76 | 64181.89
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11425 | 8380 | 19806 | 1630 | 201 | 1429 | 1.08 | 0.30 | 64192.97
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1905 | 14799 | 16703 | 2488 | 217 | 2271 | 0.74 | 0.23 | 64195.53
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2876 | 13761 | 16636 | 2240 | 213 | 2027 | 0.83 | 0.25 | 64195.01
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3824 | 12419 | 16242 | 1947 | 204 | 1743 | 1.02 | 0.27 | 64193.44
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1705 | 10056 | 11761 | 2036 | 209 | 1827 | 0.80 | 0.25 | 64195.30
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2697 | 9282 | 11978 | 1834 | 205 | 1629 | 0.90 | 0.28 | 64194.63
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3675 | 8469 | 12144 | 1612 | 198 | 1413 | 1.06 | 0.29 | 64193.31
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2275 | 14780 | 17056 | 2148 | 214 | 1934 | 0.77 | 0.23 | 64195.41
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3204 | 13725 | 16929 | 1938 | 210 | 1727 | 0.87 | 0.25 | 64194.65
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4101 | 12386 | 16487 | 1689 | 201 | 1487 | 1.07 | 0.28 | 64192.92
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1992 | 10038 | 12030 | 1779 | 206 | 1574 | 0.83 | 0.26 | 64195.21
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2948 | 9263 | 12211 | 1608 | 202 | 1405 | 0.93 | 0.28 | 64194.27
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3888 | 8450 | 12338 | 1419 | 196 | 1222 | 1.10 | 0.30 | 64192.79
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15723 | 14693 | 30416 | 2535 | 223 | 2312 | 0.76 | 0.23 | 64195.50
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15765 | 13723 | 29488 | 2303 | 218 | 2084 | 0.83 | 0.25 | 64194.75
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15456 | 12411 | 27867 | 2021 | 209 | 1812 | 1.03 | 0.27 | 64193.17
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10944 | 9914 | 20859 | 2029 | 213 | 1816 | 0.82 | 0.26 | 64195.26
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11275 | 9233 | 20508 | 1846 | 209 | 1637 | 0.89 | 0.27 | 64194.40

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 21 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming 6-Month Followup for HPV-Positive, Cytology-Negative Women

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13877 | 786 | 14662 | 645 | 160 | 484 | 2.34 | 0.76 | 64181.89
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11720 | 8674 | 20394 | 1865 | 203 | 1661 | 1.04 | 0.29 | 64193.28
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1909 | 15226 | 17135 | 2825 | 220 | 2604 | 0.72 | 0.23 | 64195.63
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2881 | 14176 | 17057 | 2537 | 216 | 2321 | 0.79 | 0.24 | 64195.19
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3828 | 12769 | 16596 | 2194 | 206 | 1988 | 0.98 | 0.26 | 64193.60
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1711 | 10442 | 12153 | 2297 | 213 | 2083 | 0.75 | 0.24 | 64195.47
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2700 | 9579 | 12279 | 2055 | 208 | 1847 | 0.86 | 0.27 | 64194.82
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3679 | 8755 | 12434 | 1800 | 201 | 1599 | 1.01 | 0.28 | 64193.57
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2285 | 15385 | 17670 | 2639 | 220 | 2419 | 0.73 | 0.23 | 64195.59
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3214 | 14307 | 17521 | 2372 | 215 | 2156 | 0.80 | 0.24 | 64194.96
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4109 | 12880 | 16989 | 2053 | 206 | 1847 | 0.99 | 0.26 | 64193.55
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 2004 | 10585 | 12589 | 2159 | 213 | 1946 | 0.76 | 0.24 | 64195.53
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2956 | 9694 | 12650 | 1933 | 208 | 1725 | 0.87 | 0.27 | 64194.65
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3896 | 8863 | 12759 | 1696 | 200 | 1495 | 1.02 | 0.27 | 64193.58
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 16245 | 15215 | 31460 | 2959 | 226 | 2733 | 0.72 | 0.22 | 64195.74
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 16212 | 14170 | 30382 | 2675 | 221 | 2453 | 0.79 | 0.24 | 64194.96
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 15836 | 12790 | 28626 | 2333 | 211 | 2122 | 0.98 | 0.26 | 64193.52
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 11335 | 10306 | 21641 | 2349 | 216 | 2132 | 0.78 | 0.25 | 64195.48
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 11588 | 9545 | 21133 | 2122 | 212 | 1910 | 0.86 | 0.27 | 64194.57

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 22 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years), Assuming 24-Month Followup for HPV-Positive, Cytology-Negative Women

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13878 | 786 | 14663 | 646 | 161 | 484 | 2.35 | 0.76 | 64181.83
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 11098 | 8052 | 19151 | 1343 | 196 | 1146 | 1.14 | 0.30 | 64192.47
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1894 | 14199 | 16094 | 2176 | 214 | 1962 | 0.77 | 0.24 | 64195.40
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2870 | 13319 | 16189 | 1975 | 211 | 1764 | 0.85 | 0.25 | 64194.93
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3820 | 12050 | 15870 | 1721 | 203 | 1518 | 1.03 | 0.27 | 64193.46
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1700 | 9675 | 11375 | 1797 | 207 | 1590 | 0.82 | 0.26 | 64195.21
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2693 | 8939 | 11632 | 1627 | 203 | 1424 | 0.92 | 0.28 | 64194.53
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3672 | 8199 | 11872 | 1441 | 197 | 1244 | 1.07 | 0.29 | 64193.30
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 2255 | 13905 | 16160 | 1686 | 209 | 1477 | 0.84 | 0.24 | 64195.16
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 3192 | 13060 | 16252 | 1536 | 206 | 1330 | 0.90 | 0.26 | 64194.24
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 4093 | 11834 | 15927 | 1353 | 199 | 1153 | 1.09 | 0.28 | 64192.81
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1982 | 9469 | 11451 | 1424 | 201 | 1223 | 0.89 | 0.26 | 64194.97
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2940 | 8753 | 11693 | 1299 | 198 | 1100 | 0.98 | 0.29 | 64193.87
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3883 | 8041 | 11924 | 1160 | 193 | 967 | 1.14 | 0.30 | 64192.60
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 14994 | 13964 | 28958 | 2018 | 215 | 1803 | 0.82 | 0.24 | 64195.09
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15153 | 13111 | 28264 | 1848 | 212 | 1636 | 0.89 | 0.25 | 64194.24
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 14947 | 11902 | 26849 | 1640 | 204 | 1436 | 1.08 | 0.28 | 64192.63
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10486 | 9457 | 19943 | 1636 | 205 | 1430 | 0.88 | 0.27 | 64194.76
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 10849 | 8806 | 19655 | 1501 | 203 | 1298 | 0.97 | 0.29 | 64193.82

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 23 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years) Assuming Colposcopy Referral for All HPV-Positive Women

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^*^ | Colpos | CIN2,3 detected | False positives^†^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13876 | 786 | 14662 | 645 | 160 | 484 | 2.34 | 0.76 | 64181.93
2 | CYTO-3Y, 21 / COTEST-5Y, 30^*^ | 11424 | 8379 | 19803 | 1629 | 201 | 1428 | 1.08 | 0.30 | 64192.98
20 | CYTO-3Y, 21 / HPV-3Y (colposcopy), 25 | 1145 | 15029 | 16175 | 3261 | 220 | 3041 | 0.74 | 0.23 | 64195.59
21 | CYTO-3Y, 21 / HPV-3Y (colposcopy), 27 | 2258 | 14041 | 16299 | 2923 | 216 | 2706 | 0.81 | 0.24 | 64195.10
22 | CYTO-3Y, 21 / HPV-3Y (colposcopy), 30 | 3364 | 12652 | 16016 | 2515 | 207 | 2308 | 0.98 | 0.27 | 64193.61
23 | CYTO-3Y, 21 / HPV-5Y (colposcopy), 25 | 1145 | 10353 | 11499 | 2632 | 214 | 2417 | 0.78 | 0.25 | 64195.43
24 | CYTO-3Y, 21 / HPV-5Y (colposcopy), 27 | 2258 | 9514 | 11772 | 2341 | 209 | 2132 | 0.87 | 0.28 | 64194.72
25 | CYTO-3Y, 21 / HPV-5Y (colposcopy), 30 | 3364 | 8687 | 12051 | 2037 | 201 | 1835 | 1.02 | 0.28 | 64193.50

* Total number of tests, irrespective of primary, triage, or surveillance context.

† Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.

Appendix Table 24 Outcomes for Cervical Cancer Screening Strategies Over Lifetime of Screening (Screening End Age 65 Years) in Women Vaccinated Against HPV-16/18^*^

# | Strategy | Per 1,000 women
# | Strategy | Cyto tests | HPV tests | Total tests^†^ | Colpos | CIN2,3 detected | False positives^‡^ | CC cases | CC deaths | Life-years
1 | CYTO-3Y, 21 | 13742 | 763 | 14504 | 539 | 87 | 452 | 0.89 | 0.28 | 64193.31
2 | CYTO-3Y, 21 / COTEST-5Y, 30 | 10909 | 7922 | 18831 | 1221 | 110 | 1111 | 0.34 | 0.07 | 64197.65
3 | CYTO-4Y, 21 / HPV-3Y (16/18), 25 | 1911 | 14012 | 15923 | 1549 | 116 | 1433 | 0.24 | 0.06 | 64198.41
4 | CYTO-3Y, 21 / HPV-3Y (16/18), 27 | 2852 | 13013 | 15866 | 1396 | 114 | 1282 | 0.27 | 0.07 | 64198.18
5 | CYTO-3Y, 21 / HPV-3Y (16/18), 30 | 3775 | 11783 | 15558 | 1217 | 109 | 1108 | 0.33 | 0.07 | 64197.74
6 | CYTO-4Y, 21 / HPV-5Y (16/18), 25 | 1699 | 9341 | 11041 | 1300 | 111 | 1188 | 0.25 | 0.06 | 64198.38
7 | CYTO-3Y, 21 / HPV-5Y (16/18), 27 | 2663 | 8601 | 11263 | 1173 | 109 | 1063 | 0.29 | 0.08 | 64198.08
8 | CYTO-3Y, 21 / HPV-5Y (16/18), 30 | 3620 | 7950 | 11571 | 1040 | 106 | 934 | 0.34 | 0.07 | 64197.75
9 | CYTO-4Y, 21 / HPV-3Y (cyto), 25 | 1910 | 14012 | 15923 | 1549 | 115 | 1434 | 0.24 | 0.06 | 64198.39
10 | CYTO-3Y, 21 / HPV-3Y (cyto), 27 | 2853 | 13015 | 15868 | 1398 | 113 | 1284 | 0.27 | 0.07 | 64198.19
11 | CYTO-3Y, 21 / HPV-3Y (cyto), 30 | 3775 | 11783 | 15558 | 1217 | 109 | 1108 | 0.33 | 0.07 | 64197.74
12 | CYTO-4Y, 21 / HPV-5Y (cyto), 25 | 1700 | 9342 | 11041 | 1300 | 111 | 1188 | 0.25 | 0.06 | 64198.36
13 | CYTO-3Y, 21 / HPV-5Y (cyto), 27 | 2663 | 8601 | 11264 | 1173 | 109 | 1063 | 0.29 | 0.08 | 64198.08
14 | CYTO-3Y, 21 / HPV-5Y (cyto), 30 | 3621 | 7952 | 11572 | 1041 | 106 | 935 | 0.34 | 0.07 | 64197.75
15 | CYTO-4Y, 21 / COTEST-3Y, 25 | 15019 | 14014 | 29033 | 1881 | 123 | 1759 | 0.24 | 0.06 | 64198.42
16 | CYTO-3Y, 21 / COTEST-3Y, 27 | 15097 | 13097 | 28194 | 1711 | 120 | 1591 | 0.27 | 0.06 | 64198.19
17 | CYTO-3Y, 21 / COTES T-3Y, 30 | 14868 | 11881 | 26749 | 1506 | 114 | 1392 | 0.32 | 0.07 | 64197.74
18 | CYTO-4Y, 21 / COTEST-5Y, 25 | 10282 | 9276 | 19558 | 1508 | 116 | 1391 | 0.26 | 0.07 | 64198.30
19 | CYTO-3Y, 21 / COTEST-5Y, 27 | 10634 | 8635 | 19269 | 1370 | 114 | 1256 | 0.29 | 0.07 | 64198.10

* HPV-16/18 vaccination is assumed to provide 100% protection against HPV-16/18 infections over the lifetime.

† Total number of tests, irrespective of primary, triage, or surveillance context.

‡ Total number of colposcopies that did not result in CIN2, CIN3, or cancer detection.

Abbreviations: CC: cervical cancer; CIN: cervical intraepithelial neoplasia; Colpos: colposcopies; Cyto: cytology; HPV: human papillomavirus.