# References

1 Saraiya M, Ahmed F, Krishnan S, Cervical cancer incidence in a prevaccine era in the United States, 1998-2002. Obstet Gynecol. 2007;109(2 Pt 1):360–70. PMID: 17267837. http://dx.doi.org/10.1097/01.AOG.0000254165.92653.e8 17267837
2 Abeloff MD AJ, Niederhuber JE, Kastan MB, McKenna WG (eds). Clinical Oncology. 3rd ed. Philadelphia, PA: Elsevier Churchill Livingstone; 2004.
3 McCredie MR, Sharples KJ, Paul C, Natural history of cervical neoplasia and risk of invasive cancer in women with cervical intraepithelial neoplasia 3: a retrospective cohort study. Lancet Oncol. 2008;9(5):425–34. PMID: 18407790. http://dx.doi.org/10.1016/S1470-2045(08)70103-7 18407790
4 Darragh TM, Colgan TJ, Thomas Cox J, The Lower Anogenital Squamous Terminology Standardization project for HPV-associated lesions: background and consensus recommendations from the College of American Pathologists and the American Society for Colposcopy and Cervical Pathology. Int J Gynecol Pathol. 2013;32(1):76–115. PMID: 23202792. http://dx.doi.org/10.1097/PGP.0b013e31826916c7 23202792
5 Nayar R, Wilbur DC. The Pap Test and Bethesda 2014. “The reports of my demise have been greatly exaggerated.” (after a quotation from Mark Twain). Acta Cytol. 2015;59(2):121–32. PMID: 25997404. http://dx.doi.org/10.1159/000381842 25997404
6 Solomon D, Davey D, Kurman R, The 2001 Bethesda System: terminology for reporting results of cervical cytology. JAMA. 2002;287(16):2114–9. PMID: 11966386 http://dx.doi.org/10.1001/jama.287.16.2114 11966386
7 Bosch FX, Lorincz A, Munoz N, The causal relation between human papillomavirus and cervical cancer. J Clin Pathol. 2002;55(4):244–65. PMID: 11919208. None11919208
8 Schiffman M, Castle PE, Jeronimo J, Human papillomavirus and cervical cancer. Lancet. 2007;370(9590):890–907. PMID: 17826171. http://dx.doi.org/10.1016/S0140-6736(07)61416-0 17826171
9 Ziegert C, Wentzensen N, Vinokurova S, A comprehensive analysis of HPV integration loci in anogenital lesions combining transcript and genome-based amplification techniques. Oncogene. 2003;22(25):3977–84. PMID: 12813471. http://dx.doi.org/10.1038/sj.onc.1206629 12813471
10 Dunne EF, Unger ER, Sternberg M, Prevalence of HPV infection among females in the United States. JAMA. 2007;297(8):813–9. PMID: 17327523. http://dx.doi.org/10.1001/jama.297.8.813 17327523
11 Plummer M, Schiffman M, Castle PE, A 2-year prospective study of human papillomavirus persistence among women with a cytological diagnosis of atypical squamous cells of undetermined significance or low-grade squamous intraepithelial lesion. J Infect Dis. 2007;195(11):1582–9. PMID: 17471427. http://dx.doi.org/10.1086/516784 17471427
12 Park IU, Wojtal N, Silverberg MJ, Cytology and human papillomavirus co-test results preceding incident high-grade cervical intraepithelial neoplasia. PLoS One. 2015;10(3):e0118938. PMID: 25793987. http://dx.doi.org/10.1371/journal.pone.0118938 25793987
13 Chen HC, Schiffman M, Lin CY, Persistence of type-specific human papillomavirus infection and increased long-term risk of cervical cancer. J Natl Cancer Inst. 2011;103(18):1387–96. PMID: 21900119. http://dx.doi.org/10.1093/jnci/djr283 21900119
14 Schiffman M, Kjaer SK. Chapter 2: Natural history of anogenital human papillomavirus infection and neoplasia. J Natl Cancer Inst Monogr. 2003(31):14–9. PMID: 12807940. None12807940
15 Li N, Franceschi S, Howell-Jones R, Human papillomavirus type distribution in 30,848 invasive cervical cancers worldwide: Variation by geographical region, histological type and year of publication. Int J Cancer. 2011;128(4):927–35. PMID: 20473886. http://dx.doi.org/10.1002/ijc.25396 20473886
16 de Sanjose S, Quint WG, Alemany L, Human papillomavirus genotype attribution in invasive cervical cancer: a retrospective cross-sectional worldwide study. Lancet Oncol. 2010;11(11):1048–56. PMID: 20952254. http://dx.doi.org/10.1016/S1470-2045(10)70230-8 20952254
17 Hopenhayn C, Christian A, Christian WJ, Prevalence of human papillomavirus types in invasive cervical cancers from 7 US cancer registries before vaccine introduction. J Low Genit Tract Dis. 2014;18(2):182–9. PMID: 24477171. http://dx.doi.org/10.1097/LGT.0b013e3182a577c7 24477171
18 Khan MJ, Castle PE, Lorincz AT, The elevated 10-year risk of cervical precancer and cancer in women with human papillomavirus (HPV) type 16 or 18 and the possible utility of type-specific HPV testing in clinical practice. J Natl Cancer Inst. 2005;97(14):1072–9. PMID: 16030305. http://dx.doi.org/10.1093/jnci/dji187 16030305
19 Insinga RP, Dasbach EJ, Elbasha EH, Incidence and duration of cervical human papillomavirus 6, 11, 16, and 18 infections in young women: an evaluation from multiple analytic perspectives. Cancer Epidemiol Biomarkers Prev. 2007;16(4):709–15. PMID: 17416761. http://dx.doi.org/10.1158/1055-9965.EPI-06-0846 17416761
20 Doorbar J. Molecular biology of human papillomavirus infection and cervical cancer. Clin Sci (Lond). 2006;110(5):525–41. PMID: 16597322. http://dx.doi.org/10.1042/CS20050369 16597322
21 Cox JT. The development of cervical cancer and its precursors: what is the role of human papillomavirus infection? Curr Opin Obstet Gynecol. 2006;18 Suppl 1:s5–s13. PMID: 16520683. http://dx.doi.org/10.1097/01.gco.0000216315.72572.fb 16520683
22 De Vuyst H, Lillo F, Broutet N, HIV, human papillomavirus, and cervical neoplasia and cancer in the era of highly active antiretroviral therapy. Eur J Cancer Prev. 2008;17(6):545–54. PMID: 18941376. http://dx.doi.org/10.1097/CEJ.0b013e3282f75ea1 18941376
23 Schiffman M, Wentzensen N, Wacholder S, Human papillomavirus testing in the prevention of cervical cancer. J Natl Cancer Inst. 2011;103(5):368–83. PMID: 21282563. http://dx.doi.org/10.1093/jnci/djq562 21282563
24 Chang AR. Carcinoma in situ of the cervix and its malignant potential. A lesson from New Zealand. Cytopathology. 1990;1(6):321–8. PMID: 2101679. http://dx.doi.org/10.1111/j.1365-2303.1990.tb00369.x 2101679
25 Kinlen LJ, Spriggs AI. Women with positive cervical smears but without surgical intervention. A follow-up study. Lancet. 1978;2(8087):463–5. PMID: 79818. https://doi.org/10.1016/S0140-6736(78)91457-5 79818
26 Holowaty P, Miller AB, Rohan T, Natural history of dysplasia of the uterine cervix. J Natl Cancer Inst. 1999;91(3):252–8. PMID: 10037103. None
27 Ostor AG. Natural history of cervical intraepithelial neoplasia: a critical review. Int J Gynecol Pathol. 1993;12(2):186–92. PMID: 8463044. None8463044
28 Cox JT, Schiffman M, Solomon D, Prospective follow-up suggests similar risk of subsequent cervical intraepithelial neoplasia grade 2 or 3 among women with cervical intraepithelial neoplasia grade 1 or negative colposcopy and directed biopsy. Am J Obstet Gynecol. 2003;188(6):1406–12. PMID: 12824970. https://doi.org/10.1067/mob.2003.461 12824970
29 Dalla Palma P, Giorgi Rossi P, Collina G, The reproducibility of CIN diagnoses among different pathologists: data from histology reviews from a multicenter randomized study. Am J Clin Pathol. 2009;132(1):125–32. PMID: 19864243. http://dx.doi.org/10.1309/AJCPBRK7D1YIUWFP 19864243
30 Carreon JD, Sherman ME, Guillen D, CIN2 is a much less reproducible and less valid diagnosis than CIN3: results from a histological review of population-based cervical samples. Int J Gynecol Pathol. 2007;26(4):441–6. PMID: 17885496. http://dx.doi.org/10.1097/pgp.0b013e31805152ab 17885496
31 Castle PE, Schiffman M, Wheeler CM, Evidence for frequent regression of cervical intraepithelial neoplasia-grade 2. Obstet Gynecol. 2009;113(1):18–25. PMID: 19104355. http://dx.doi.org/10.1097/AOG.0b013e31818f5008 19104355
32 SEER Cancer Statistics Factsheets: Cervix Uteri Cancer. https://seer.cancer.gov/statfacts/html/ld/cervix.html. Accessed.
33 American Cancer Society. American Cancer Society: Cancer Facts & Figures 2016. https://www.cancer.org/research/cancer-facts-statistics/all-cancer-facts-figures/cancer-facts-figures-2016.html. Accessed: June 27, 2017.
34 Beavis AL, Gravitt PE, Rositch AF. Hysterectomy-corrected cervical cancer mortality rates reveal a larger racial disparity in the United States. Cancer. 2017;123(6). PMID: 28112816. http://dx.doi.org/10.1002/cncr.30507 28112816
35 National Institutes of Health. Cervical cancer. http://consensus.nih.gov/1996/1996CervicalCancer102html.htm. Accessed: June 27, 2017.
36 Decker K, Demers A, Chateau D, Papanicolaou test utilization and frequency of screening opportunities among women diagnosed with cervical cancer. Open Med. 2009;3(3):e140–7. PMID: 21603052. None21603052
37 Subramaniam A, Fauci JM, Schneider KE, Invasive cervical cancer and screening: what are the rates of unscreened and underscreened women in the modern era? J Low Genit Tract Dis. 2011;15(2):110–3. PMID: 21263352. http://dx.doi.org/10.1097/LGT.0b013e3181f515a2 21263352
38 Sawaya GF, Sung HY, Kearney KA, Advancing age and cervical cancer screening and prognosis. J Am Geriatr Soc. 2001;49(11):1499–504. PMID: 11890589. http://dx.doi.org/10.1046/j.1532-5415.2001.4911243.x 11890589
39 Mokdad AH, Dwyer-Lindgren L, Fitzmaurice C, Trends and Patterns of Disparities in Cancer Mortality Among US Counties, 1980-2014. JAMA. 2017;317(4):388–406. PMID: 28118455. http://dx.doi.org/10.1001/jama.2016.20324 28118455
40 McQuillan G, Kruszon-Moran D, Markowitz LE, Prevalence of HPV in Adults Aged 18-69: United States, 2011-2014. NCHS Data Brief. 2017(280):1–8.
41 Shi R, Devarakonda S, Liu L, Factors associated with genital human papillomavirus infection among adult females in the United States, NHANES 2007-2010. BMC Res Notes. 2014;7:544. 10.1186/1756-0500-7-544
42 Chesson HW, Ekwueme DU, Saraiya M, Estimates of the annual direct medical costs of the prevention and treatment of disease associated with human papillomavirus in the United States. Vaccine. 2012;30(42):6016–9. PMID: 22867718. http://dx.doi.org/10.1016/j.vaccine.2012.07.056 22867718
43 Panatto D, Amicizia D, Bianchi S, Chlamydia trachomatis prevalence and chlamydial/HPV co-infection among HPV-unvaccinated young Italian females with normal cytology. Hum Vaccin Immunother. 2015;11(1):270–6. PMID: 25483545. http://dx.doi.org/10.4161/hv.36163 25483545
44 Vriend HJ, Bogaards JA, van Bergen JE, Incidence and persistence of carcinogenic genital human papillomavirus infections in young women with or without Chlamydia trachomatis co-infection. Cancer Med. 2015. PMID: 26194784. http://dx.doi.org/10.1002/cam4.496 26194784
45 Munoz N, Franceschi S, Bosetti C, Role of parity and human papillomavirus in cervical cancer: the IARC multicentric case-control study. Lancet. 2002;359(9312):1093–101. PMID: 11943256. http://dx.doi.org/10.1016/S0140-6736(02)08151-5 11943256
46 Louie KS, Castellsague X, de Sanjose S, Smoking and passive smoking in cervical cancer risk: pooled analysis of couples from the IARC multicentric case-control studies. Cancer Epidemiol Biomarkers Prev. 2011;20(7):1379–90. PMID: 21610224. http://dx.doi.org/10.1158/1055-9965.EPI-11-0284 21610224
47 Plummer M, Herrero R, Franceschi S, Smoking and cervical cancer: pooled analysis of the IARC multi-centric case-control study. Cancer Causes Control. 2003;14(9):805–14. PMID: 1468243814682438. None
48 International Collaboration of Epidemiological Studies of Cervical C, Appleby P, Beral V, Carcinoma of the cervix and tobacco smoking: collaborative reanalysis of individual data on 13,541 women with carcinoma of the cervix and 23,017 women without carcinoma of the cervix from 23 epidemiological studies. Int J Cancer. 2006;118(6):1481–95. PMID: 16206285. http://dx.doi.org/10.1002/ijc.21493 16206285
49 Singh GK, Williams SD, Siahpush M, Socioeconomic, Rural-Urban, and Racial Inequalities in US Cancer Mortality: Part I-All Cancers and Lung Cancer and Part II-Colorectal, Prostate, Breast, and Cervical Cancers. J Cancer Epidemiol. 2011;2011:107497. PMID: 2249668822496688. http://dx.doi.org/10.1155/2011/107497
50 Rositch AF, Burke AE, Viscidi RP, Contributions of recent and past sexual partnerships on incident human papillomavirus detection: acquisition and reactivation in older women. Cancer Res. 2012;72(23):6183–90. PMID: 23019223. http://dx.doi.org/10.1158/0008-5472.CAN-12-2635 23019223
51 Yang Z, Cuzick J, Hunt WC, Concurrence of multiple human papillomavirus infections in a large US population-based cohort. Am J Epidemiol. 2014;180(11):1066–75. PMID: 25355446. http://dx.doi.org/10.1093/aje/kwu267 25355446
52 Cytyc Corporation. ThinPrep Pap test quick reference guide: endocervical brush/spatula protocol. https://www.cmmc.org/cmmclab/specimenfiles/ThinPrep_Collection_Guide.pdf. Accessed: April 6, 2015.
53 TriPath Imaging. SurePath technology is changing cervical cancer screening for the better. http://www.bmpath.com/documents/Surepath%20Visual%20Sheet.pdf. Accessed: June 28, 2017.
54 Vesco KK, Whitlock EP, Eder M, Screening for Cervical Cancer: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2011.
55 Food and Drug Administration. Approval Letter: Digene Hybrid Capture 2 High-Risk HPV DNA Test. https://www.accessdata.fda.gov/cdrh_docs/pdf/p890064s009b.pdf. Accessed: June 27, 2017.
56 Food and Drug Administration. Approval Letter: Cobas HPV Test-P100020. http://www.accessdata.fda.gov/cdrh_docs/pdf10/p100020a.pdf Accessed: June 27, 2017.
57 Food and Drug Administration. Approval Letter: APTIMA HPV Assay. https://www.accessdata.fda.gov/cdrh_docs/pdf10/p100042a.pdf. Accessed: June 27, 2017.
58 Food and Drug Administration. Approval Letter: Cervista HPV 16/18-P080015. http://www.accessdata.fda.gov/cdrh_docs/pdf8/P080015a.pdf. Accessed: June 27, 2017.
59 Food and Drug Administration. Approval Letter: Cervista HPV HR and GenfindT DNA Extraction Kit - P080014. https://www.accessdata.fda.gov/cdrh_docs/pdf8/P080014a.pdf. Accessed: June 27, 2017.
60 Food and Drug Administration. FDA approves first human papillomaviru test for primary cervical cancer screening. https://wayback.archive-it.org/7993/20161023125534/http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm394773.htm. Accessed: June 27, 2017.
61 Arbyn M, Snijders PJ, Meijer CJ, Which high-risk HPV assays fulfil criteria for use in primary cervical cancer screening? Clin Microbiol Infect. 2015. PMID: 2593658125936581. http://dx.doi.org/10.1016/j.cmi.2015.04.015
62 Hariri S, Unger ER, Sternberg M, Prevalence of genital human papillomavirus among females in the United States, the National Health And Nutrition Examination Survey, 2003-2006. J Infect Dis. 2011;204(4):566–73. PMID: 21791659. http://dx.doi.org/10.1093/infdis/jir341 21791659
63 Practice Bulletin No. 168: Cervical Cancer Screening and Prevention. Obstet Gynecol. 2016;128(4):e111–30. PMID: 27661651. http://dx.doi.org/10.1097/aog.0000000000001708 27661651
64 Saslow D, Solomon D, Lawson HW, American Cancer Society, American Society for Colposcopy and Cervical Pathology, and American Society for Clinical Pathology screening guidelines for the prevention and early detection of cervical cancer. J Low Genit Tract Dis. 2012;16(3):175–204. PMID: 22418039. http://dx.doi.org/10.1097/LGT.0b013e31824ca9d5 22418039
65 (ASCCP) TASfCaCP. ASCCP Guidelines. http://www.asccp.org/asccp-guidelines. Accessed: June 29, 2017.
66 Huh WK, Ault KA, Chelmow D, Use of primary high-risk human papillomavirus testing for cervical cancer screening: interim clinical guidance. Obstet Gynecol. 2015;125(2):330–7. PMID: 25569009. http://dx.doi.org/10.1097/AOG.0000000000000669 25569009
67 Schiller JT, Castellsague X, Garland SM. A review of clinical trials of human papillomavirus prophylactic vaccines. Vaccine. 2012;30 Suppl 5:F123–38. PMID: 23199956. http://dx.doi.org/10.1016/j.vaccine.2012.04.108 23199956
68 Kjaer SK, Sigurdsson K, Iversen OE, A pooled analysis of continued prophylactic efficacy of quadrivalent human papillomavirus (Types 6/11/16/18) vaccine against high-grade cervical and external genital lesions. Cancer Prev Res (Phila). 2009;2(10):868–78. PMID: 19789295. http://dx.doi.org/10.1158/1940-6207.CAPR-09-0031 19789295
69 Meites E, Kempe A, Markowitz LE. Use of a 2-Dose Schedule for Human Papillomavirus Vaccination - Updated Recommendations of the Advisory Committee on Immunization Practices. MMWR Morb Mortal Wkly Rep. 2016;65(49):1405–8. PMID: 27977643. http://dx.doi.org/10.15585/mmwr.mm6549a5 27977643
70 Centers for Disease C, Prevention. FDA licensure of bivalent human papillomavirus vaccine (HPV2, Cervarix) for use in females and updated HPV vaccination recommendations from the Advisory Committee on Immunization Practices (ACIP). MMWR Morb Mortal Wkly Rep. 2010;59(20):626–9. PMID: 20508593. None20508593
71 Giuliano AR, Palefsky JM, Goldstone S, Efficacy of quadrivalent HPV vaccine against HPV Infection and disease in males. N Engl J Med. 2011;364(5):401–11. PMID: 21288094. http://dx.doi.org/10.1056/NEJMoa0909537 21288094
72 Villa LL, Costa RL, Petta CA, Prophylactic quadrivalent human papillomavirus (types 6, 11, 16, and 18) L1 virus-like particle vaccine in young women: a randomised double-blind placebo-controlled multicentre phase II efficacy trial. Lancet Oncol. 2005;6(5):271–8. PMID: 15863374. http://dx.doi.org/10.1016/S1470-2045(05)70101-7 15863374
73 Garland SM, Hernandez-Avila M, Wheeler CM, Quadrivalent vaccine against human papillomavirus to prevent anogenital diseases. N Engl J Med. 2007;356(19):1928–43. PMID: 17494926. http://dx.doi.org/10.1056/NEJMoa061760 17494926
74 Group FIS. Quadrivalent vaccine against human papillomavirus to prevent high-grade cervical lesions. N Engl J Med. 2007;356(19):1915–27. PMID: 17494925. http://dx.doi.org/10.1056/NEJMoa061741 17494925
75 Hillman RJ, Giuliano AR, Palefsky JM, Immunogenicity of the quadrivalent human papillomavirus (type 6/11/16/18) vaccine in males 16 to 26 years old. Clin Vaccine Immunol. 2012;19(2):261–7. PMID: 22155768 http://dx.doi.org/10.1128/CVI.05208-11 22155768
76 Villa LL, Costa RL, Petta CA, High sustained efficacy of a prophylactic quadrivalent human papillomavirus types 6/11/16/18 L1 virus-like particle vaccine through 5 years of follow-up. Br J Cancer. 2006;95(11):1459–66. PMID: 17117182. http://dx.doi.org/10.1038/sj.bjc.6603469 17117182
77 Block SL, Nolan T, Sattler C, Comparison of the immunogenicity and reactogenicity of a prophylactic quadrivalent human papillomavirus (types 6, 11, 16, and 18) L1 virus-like particle vaccine in male and female adolescents and young adult women. Pediatrics. 2006;118(5):2135–45. PMID: 17079588. http://dx.doi.org/10.1542/peds.2006-0461 17079588
78 Giuliano AR, Lazcano-Ponce E, Villa L, Impact of baseline covariates on the immunogenicity of a quadrivalent (types 6, 11, 16, and 18) human papillomavirus virus-like-particle vaccine. J Infect Dis. 2007;196(8):1153–62. PMID: 17955433. http://dx.doi.org/10.1086/521679 17955433
79 Petrosky E, Bocchini JA, Jr., Hariri S, Use of 9-Valent Human Papillomavirus (HPV) Vaccine: Updated HPV Vaccination Recommendations of the Advisory Committee on Immunization Practices. MMWR Morb Mortal Wkly Rep. 2015;64(11):300–4. PMID: 25811679. None25811679
80 Markowitz L. 2-dose human papillomavirus (HPV) vaccination schedules. http://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2014-06/HPV-04-Markowitz.pdf. Accessed: April 22, 2015.
81 Dobson SR, McNeil S, Dionne M, Immunogenicity of 2 doses of HPV vaccine in younger adolescents vs. 3 doses in young women: a randomized clinical trial. JAMA. 2013;309(17):1793–802. PMID: 23632723. http://dx.doi.org/10.1001/jama.2013.1625 23632723
82 Hariri S, Bennett NM, Niccolai LM, Reduction in HPV 16/18-associated high grade cervical lesions following HPV vaccine introduction in the United States - 2008-2015. Vaccine. 2015;33:1608–13. PMID: 25681664. http://dx.doi.org/10.1016/j.vaccine.2015.01.084 25681664
83 Drolet M, Benard E, Boily MC, Population-level impact and herd effects following human papillomavirus vaccination programmes: a systematic review and meta-analysis. Lancet Infect Dis. 2015. PMID: 25744474. http://dx.doi.org/10.1016/S1473-3099(14)71073-4 25744474
84 Giorgi Rossi P, Carozzi F, Federici A, Cervical cancer screening in women vaccinated against human papillomavirus infection: Recommendations from a consensus conference. Prev Med. 2016. PMID: 27894910. https://dx.doi.org/10.1016/j.ypmed.2016.11.020 27894910
85 Centers for Disease Control and Prevention. HPV-Associated Cancer Statistics. http://www.cdc.gov/cancer/hpv/statistics/. Accessed: June 27, 2017.
86 Viens LJ, Henley SJ, Watson M, Human Papillomavirus-Associated Cancers - United States, 2008-2012. MMWR Morb Mortal Wkly Rep. 2016;65(26):661–6. PMID: 27387669. http://dx.doi.org/10.15585/mmwr.mm6526a1 27387669
87 Markowitz LE, Liu G, Hariri S, Prevalence of HPV After Introduction of the Vaccination Program in the United States. Pediatrics. 2016;137(3):e20151968. PMID: 26908697. http://dx.doi.org/10.1542/peds.2015-1968 26908697
88 Stokley S, Jeyarajah J, Yankey D, Human papillomavirus vaccination coverage among adolescents, 2007-2013, and postlicensure vaccine safety monitoring, 2006-2014-United States. MMWR Morb Mortal Wkly Rep. 2014;63(29):620–4. PMID: 25055185. None25055185
89 Reagan-Steiner S, Yankey D, Jeyarajah J, National, Regional, State, and Selected Local Area Vaccination Coverage Among Adolescents Aged 13-17 Years - United States, 2015. MMWR Morb Mortal Wkly Rep. 2016;65(33):850–8. PMID: 27561081. http://dx.doi.org/10.15585/mmwr.mm6533a4 27561081
90 Moyer VA, U. S. Preventive Services Task Force. Screening for cervical cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;156(12):880–91, W312. PMID: 22711081 http://dx.doi.org/10.7326/0003-4819-156-12-201206190-00424 22711081
91 Wright TC, Stoler MH, Behrens CM, Primary cervical cancer screening with human papillomavirus: End of study results from the ATHENA study using HPV as the first-line screening test. Gynecol Oncol. 2015;136(2):189–97. PMID: 25579108. http://dx.doi.org/10.1016/j.ygyno.2014.11.076 25579108
92 Benard VB, Thomas CC, King J, Vital Signs: Cervical cancer incidence, mortality and screening - United States, 2007-2012. MMWR Morb Mortal Wkly Rep. 2014;63:1–6. PMID: 25375072 None24402465
93 Benard VB, Lawson HW, Eheman CR, Adherence to guidelines for follow-up of low-grade cytologic abnormalities among medically underserved women. Obstet Gynecol. 2005;105(6):1323–8. PMID: 15932824. http://dx.doi.org/10.1097/01.AOG.0000159549.56601.75
94 Teoh DG, Marriott AE, Isaksson Vogel R, Adherence to the 2012 national cervical cancer screening guidelines: a pilot study. Am J Obstet Gynecol. 2015;212(1):62 e1–9. PMID: 24992692. http://dx.doi.org/10.1016/j.ajog.2014.06.057 24992692
95 King NR, Kasper KM, Daggy JK, Current practice patterns in cervical cancer screening in Indiana. Am J Obstet Gynecol. 2014;210(3):265 e1–8. PMID: 24412744. http://dx.doi.org/10.1016/j.ajog.2014.01.001 24184183
96 Verrilli L, Winer RL, Mao C. Adherence to cervical cancer screening guidelines by gynecologists in the Pacific Northwest. J Low Genit Tract Dis. 2014;18(3):228–34. PMID: 24633168. http://dx.doi.org/10.1097/LGT.0000000000000008 24633168
97 Corbelli J, Borrero S, Bonnema R, Differences among primary care physicians’ adherence to 2009 ACOG guidelines for cervical cancer screening. J Womens Health (Larchmt). 2014;23(5):397–403. PMID: 24380500. http://dx.doi.org/10.1089/jwh.2013.4475 24380500
98 Perkins RB, Anderson BL, Gorin SS, Challenges in cervical cancer prevention: a survey of U.S. obstetrician-gynecologists. Am J Prev Med. 2013;45(2):175–81. PMID: 23867024. http://dx.doi.org/10.1016/j.amepre.2013.03.019 23867024
99 Roland KB, Benard VB, Soman A, Cervical cancer screening among young adult women in the United States. Cancer Epidemiol Biomarkers Prev. 2013;22(4):580–8. PMID: 23355601. http://dx.doi.org/10.1158/1055-9965.EPI-12-1266 23355601
100 Henderson JT, Saraiya M, Martinez G, Changes to cervical cancer prevention guidelines: effects on screening among U.S. women ages 15-29. Prev Med. 2013;56(1):25–9. PMID: 23137444. http://dx.doi.org/10.1016/j.ypmed.2012.10.025 23137444
101 Hawkins NA, Benard VB, Greek A, Patient knowledge and beliefs as barriers to extending cervical cancer screening intervals in Federally Qualified Health Centers. Prev Med. 2013;57(5):641–5. PMID: 24012831. http://dx.doi.org/10.1016/j.ypmed.2013.08.021 24012831
102 Schneider A, Henderson JT, Harper CC, Obstetrician-gynecologists’ beliefs about performing less cervical cancer screening: the pendulum swings. Am J Obstet Gynecol. 2015;213(5):744–5. PMID: 26184779. http://dx.doi.org/10.1016/j.ajog.2015.07.003 26184779
103 U.S. Preventive Services Task Force. Screening for Cervical Cancer: Recommendations and Rationale. Rockville, MD: Agency for Healthcare Research and Quality; 2003.
104 Canfell K, Caruana M, Gebski V, Cervical screening with primary HPV testing or cytology in a population of women in which those aged 33 years or younger had previously been offered HPV vaccination: Results of the Compass pilot randomised trial. PLoS Med. 2017;14(9):e1002388. 10.1371/journal.pmed.1002388 28926579
105 Wallace BC, Small K, Brodely CE, editors. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium; 2012. PMID: None.
106 Programme; UND. Human Development Report 2014: Sustaining Human Progress: Reducing Vulnerabilities and Building Resilience. http://hdr.undp.org/en/content/human-development-report-2014. Accessed: June 27, 2017.
107 Force USPST. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: Agency for Healthcare Research and Quality; 2015.
108 Arbyn M, Ronco G, Cuzick J, How to evaluate emerging technologies in cervical cancer screening? Int J Cancer. 2009;125(11):2489–96. PMID: 19626591. http://dx.doi.org/10.1002/ijc.24774 19626591
109 Darragh TM, Colgan TJ, Cox JT, The Lower Anogenital Squamous Terminology Standardization Project for HPV-Associated Lesions: background and consensus recommendations from the College of American Pathologists and the American Society for Colposcopy and Cervical Pathology. J Low Genit Tract Dis. 2012;16(3):205–42. PMID: 22820980. http://dx.doi.org/10.1097/LGT.0b013e31825c31dd 22820980
110 Harris RP, Helfand M, Woolf SH, Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21–35. PMID: 1130622911306229. http://dx.doi.org/10.1016/S0749-3797(01)00261-6
111 Wells GA, Shea BJ, O’Connell DP, J., The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: June 27, 2017.
112 Massad LS, Jeronimo J, Katki HA, The accuracy of colposcopic grading for detection of high-grade cervical intraepithelial neoplasia. J Low Genit Tract Dis. 2009;13(3):137–44. PMID: 19550210. http://dx.doi.org/10.1097/LGT.0b013e31819308d4 19550210
113 Berkman ND, Lohr KN, Ansari MT, Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015;68(11):1312–24. PMID: 25721570. http://dx.doi.org/10.1016/j.jclinepi.2014.11.023 25721570
114 Atkins D, Eccles M, Flottorp S, Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. http://dx.doi.org/10.1186/1472-6963-4-38 15615589
115 Demarco M, Lorey TS, Fetterman B, Risks of CIN 2+, CIN 3+, and Cancer by Cytology and Human Papillomavirus Status: The Foundation of Risk-Based Cervical Screening Guidelines. J Low Genit Tract Dis. 2017;21(4):261–7. 10.1097/LGT.0000000000000343
116 Kitchener HC, Almonte M, Gilham C, ARTISTIC: a randomised trial of human papillomavirus (HPV) testing in primary cervical screening. Health Technol Assess. 2009;13(51):1–150, iii–iv. PMID: 19891902. http://dx.doi.org/10.3310/hta13510 19891902
117 McCaffery K, Waller J, Forrest S, Testing positive for human papillomavirus in routine cervical screening: examination of psychosocial impact. BJOG. 2004;111(12):1437–43. PMID: 15663132. http://dx.doi.org/10.1111/j.1471-0528.2004.00279.x 15663132
118 Naucler P, Ryd W, Tornberg S, Human papillomavirus and Papanicolaou tests to screen for cervical cancer. N Engl J Med. 2007;357(16):1589–97. PMID: 17942872. http://dx.doi.org/10.1056/NEJMoa073204 17942872
119 Ronco G, Giorgi-Rossi P, Carozzi F, Efficacy of human papillomavirus testing for the detection of invasive cervical cancers and cervical intraepithelial neoplasia: a randomised controlled trial. Lancet Oncol. 2010;11(3):249–57. PMID: 20089449. http://dx.doi.org/10.1016/S1470-2045(09)70360-2 20089449
120 Rijkaart DC, Berkhof J, Rozendaal L, Human papillomavirus testing for the detection of high-grade cervical intraepithelial neoplasia and cancer: final results of the POBASCAM randomised controlled trial. Lancet Oncol. 2012;13(1):78–88. PMID: 22177579. http://dx.doi.org/10.1016/S1470-2045(11)70296-0 22177579
121 Ibanez R, Autonell J, Sarda M, Protecting the underscreened women in developed countries: the value of HPV test. BMC Cancer. 2014;14:574. PMID: 25102758. http://dx.doi.org/10.1186/1471-2407-14-574 25102758
122 Katki HA, Kinney WK, Fetterman B, Cervical cancer risk for women undergoing concurrent testing for human papillomavirus and cervical cytology: a population-based study in routine clinical practice.[Erratum appears in Lancet Oncol. 2011 Aug;12(8):722]. Lancet Oncol. 2011;12(7):663–72. PMID: 21684207. http://dx.doi.org/10.1016/S1470-2045(11)70145-0 21684207
123 Luyten A, Buttmann-Schweiger N, Luyten K, Early detection of CIN3 and cervical cancer during long-term follow-up using HPV/Pap smear co-testing and risk-adapted follow-up in a locally organised screening programme. Int J Cancer. 2014;135(6):1408–16. PMID: 24519782. http://dx.doi.org/10.1002/ijc.28783 24519782
124 Leinonen MK, Nieminen P, Lonnberg S, Detection rates of precancerous and cancerous cervical lesions within one screening round of primary human papillomavirus DNA testing: prospective randomised trial in Finland. BMJ. 2012;345:e7789. PMID: 23197596. http://dx.doi.org/10.1136/bmj.e7789 23197596
125 Coldman A. Preliminary 48 month exit results from HPV FOCAL cervical cancer screening trial: outcomes in subjects negative at baseline. 2016. PMID: None. None
126 Zorzi M, Frayle H, Rizzi M, A 3-year interval is too short for re-screening HPV negative women: a population-based cohort study. BJOG. 2017. PMID: 2812038228120382. https://dx.doi.org/10.1111/1471-0528.14575
127 Ronco G, Giorgi-Rossi P, Carozzi F, Results at recruitment from a randomized controlled trial comparing human papillomavirus testing alone with conventional cytology as the primary cervical cancer screening test. J Natl Cancer Inst. 2008;100(7):492–501. PMID: 18364502. http://dx.doi.org/10.1093/jnci/djn065 18364502
128 Cook DA, Mei W, Smith LW, Comparison of the Roche cobas 4800 and Digene Hybrid Capture 2 HPV tests for primary cervical cancer screening in the HPV FOCAL trial. BMC Cancer. 2015;15:968. PMID: 26674353. http://dx.doi.org/10.1186/s12885-015-1959-5 26674353
129 Ogilvie G, Krajden M, van Niekerk D, HPV for cervical cancer screening (HPV FOCAL): complete Round 1 results of a randomized trial comparing HPV-based primary screenign to liquid-based cytology for cervical cancer. Int J Cancer. 2017;140(2):440–8. PMID: 27685757 http://dx.doi.org/10.1002/ijc.30454 27685757
130 Ogilvie GS, van Niekerk DJ, Krajden M, A randomized controlled trial of Human Papillomavirus (HPV) testing for cervical cancer screening: trial design and preliminary results (HPV FOCAL Trial). BMC Cancer. 2010;10:111. PMID: 20334685. http://dx.doi.org/10.1186/1471-2407-10-111 20334685
131 Ronco G, Giorgi-Rossi P, Carozzi F, Human papillomavirus testing and liquid-based cytology in primary screening of women younger than 35 years: results at recruitment for a randomised controlled trial. Lancet Oncol. 2006;7(7):547–55. PMID: 16814206. http://dx.doi.org/10.1016/S1470-2045(06)70731-8 16814206
132 Ronco G, Segnan N, Giorgi-Rossi P, Human papillomavirus testing and liquid-based cytology: results at recruitment from the new technologies for cervical cancer randomized controlled trial. J Natl Cancer Inst. 2006;98(11):765–74. PMID: 16757701. http://dx.doi.org/10.1093/jnci/djj209 16757701
133 Bulkmans NW, Rozendaal L, Snijders PJ, POBASCAM, a population-based randomized controlled trial for implementation of high-risk HPV testing in cervical screening: design, methods and baseline data of 44,102 women. Int J Cancer. 2004;110(1):94–101. PMID: 15054873. http://dx.doi.org/10.1002/ijc.20076 15054873
134 Dijkstra MG, van Zummeren M, Rozendaal L, Safety of extending screening intervals beyond five years in cervical screening programmes with testing for high risk human papillomavirus: 14 year follow-up of population based randomised cohort in the Netherlands. BMJ. 2016;355:i4924. PMID: 27702796. http://dx.doi.org/10.1136/bmj.i4924 27702796
135 Elfstrom KM, Smelov V, Johansson AL, Long term duration of protective effect for HPV negative women: follow-up of primary HPV screening randomised controlled trial. BMJ. 2014;348:g130. PMID: 24435414. http://dx.doi.org/10.1136/bmj.g130 24435414
136 Kitchener HC, Almonte M, Thomson C, HPV testing in combination with liquid-based cytology in primary cervical screening (ARTISTIC): a randomised controlled trial. Lancet Oncol. 2009;10(7):672–82. PMID: 19540162. http://dx.doi.org/10.1016/S1470-2045(09)70156-1 19540162
137 Kitchener HC, Canfell K, Gilham C, The clinical effectiveness and cost-effectiveness of primary human papillomavirus cervical screening in England: extended follow-up of the ARTISTIC randomised trial cohort through three screening rounds. Health Technol Assess. 2014;18(22):1–196. PMID: 24762804. http://dx.doi.org/10.3310/hta18230 24762804
138 Kitchener HC, Fletcher I, Roberts C, The psychosocial impact of human papillomavirus testing in primary cervical screening-a study within a randomized trial. Int J Gynecol Cancer. 2008;18(4):743–8. PMID: 17944916. http://dx.doi.org/10.1111/j.1525-1438.2007.01113.x 17944916
139 Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252. http://dx.doi.org/10.1016/S0140-6736(13)62218-7 24192252
140 Petry KU, Luyten A, Scherbring S. Accuracy of colposcopy management to detect CIN3 and invasive cancer in women with abnormal screening tests: results from a primary HPV screening project from 2006 to 2011 in Wolfsburg, Germany. Gynecol Oncol. 2013;128(2):282–7. PMID: 23088926. http://dx.doi.org/10.1016/j.ygyno.2012.10.017 23088926
141 Gage JC, Hunt WC, Schiffman M, Similar risk patters after cervical screening in two large U.S. populations. 2016;128(6):1248–57. PMID: 27824767. http://dx.doi.org/10.1097/AOG.0000000000001721 27824767
142 Katki HA, Schiffman M, Castle PE, Five-year risks of CIN 3+ and cervical cancer among women who test Pap-negative but are HPV-positive. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S56–63. PMID: 23519306. http://dx.doi.org/10.1097/LGT.0b013e318285437b 23519306
143 Gage JC, Schiffman M, Katki HA, Reassurance against future risk of precancer and cancer conferred by a negative human papillomavirus test. J Natl Cancer Inst. 2014;106(8). PMID: 25038467. http://dx.doi.org/10.1093/jnci/dju153 25038467
144 Coldman AJ, Gondara L, Smith LW, Disease detection and resource use in the safety and control arms of the HPV FOCAL cervical cancer screening trial. Br J Cancer. 2016;115(12):1487–94. PMID: 27855441. https://dx.doi.org/10.1038/bjc.2016.368 27855441
145 American College of Obstetricians Gynecologists. Practice Bulletin No. 140: management of abnormal cervical cancer screening test results and cervical cancer precursors. Obstet Gynecol. 2013;122(6):1338–67. PMID: 24264713. http://dx.doi.org/10.1097/01.AOG.0000438960.31355.9e 24264713
146 Sawaya GF, Smith-McCune K. Cervical Cancer Screening. Obstet Gynecol. 2016;127(3):459–67. PMID: 26855089. http://dx.doi.org/10.1097/AOG.0000000000001136 26855089
147 Frederiksen ME, Njor S, Lynge E, Psychological effects of diagnosis and treatment of cervical intraepithelial neoplasia: a systematic review. Sex Transm Infect. 2015;91(4):248–56. PMID: 25512668. http://dx.doi.org/10.1136/sextrans-2014-051754 25512668
148 Sankaranarayanan R, Nene BM, Shastri SS, HPV screening for cervical cancer in rural India. N Engl J Med. 2009;360(14):1385–94. PMID: 19339719. http://dx.doi.org/10.1056/NEJMoa0808516 19339719
149 Adegoke O, Kulasingam S, Virnig B. Cervical cancer trends in the United States: a 35-year population-based analysis. J Womens Health. 2012;21(10):1031–7. PMID: 22816437. http://dx.doi.org/10.1089/jwh.2011.3385 22816437
150 van der Horst J, Siebers AG, Bulten J, Increasing incidence of invasive and in situ cervical adenocarcinoma in the Netherlands during 2004-2013. Cancer Med. 2017. PMID: 28102052. https://dx.doi.org/10.1002/cam4.971 28102052
151 Zheng B, Li Z, Griffith CC, Prior high-risk HPV testing and Pap test results for 427 invasive cervical cancers in China’s largest CAP-certified laboratory. Cancer Cytopathol. 2015;123(7):428–34. PMID: 25954852. http://dx.doi.org/10.1002/cncy.21557 25954852
152 Lonnberg S, Hansen BT, Haldorsen T, Cervical cancer prevented by screening: Long-term incidence trends by morphology in Norway. Int J Cancer. 2015;137(7):1758–64. PMID: 25833121. http://dx.doi.org/10.1002/ijc.29541 25833121
153 Kim JJB, E.A.; Regan, C.; Sy, S. Decision Analysis on Screening for Cervical Cancer in Primary Care (in process). Rockville, MD: Agency for Healthcare Research and Quality; 2017.
154 Martin-Hirsch PP, Paraskevaidis E, Bryant A, Surgery for cervical intraepithelial neoplasia. Cochrane Database Syst Rev. 2010(6):CD001318. PMID: 20556751. http://dx.doi.org/10.1002/14651858.CD001318.pub2 20556751
155 Nuovo J, Melnikow J, Willan AR, Treatment outcomes for squamous intraepithelial lesions. Int J Gynaecol Obstet. 2000;68(1):25–33. PMID: 10687833. http://dx.doi.org/10.1016/S0020-7292(99)00162-9 10687833
156 Bjorge T, Skare GB, Bjorge L, Adverse Pregnancy Outcomes After Treatment for Cervical Intraepithelial Neoplasia. Obstet Gynecol. 2016;128(6):1265–73. PMID: 27824756. http://dx.doi.org/10.1097/AOG.0000000000001777 27824756
157 Kyrgiou M, Koliopoulos G, Martin-Hirsch P, Obstetric outcomes after conservative treatment for intraepithelial or early invasive cervical lesions: systematic review and meta-analysis. Lancet. 2006;367(9509):489–98. PMID: 16773126. http://dx.doi.org/10.1016/S0140-6736(06)68181-6 16473126
158 Arbyn M, Kyrgiou M, Simoens C, Perinatal mortality and other severe adverse pregnancy outcomes associated with treatment of cervical intraepithelial neoplasia: meta-analysis. BMJ. 2008;337:a1284. PMID: 18801868. http://dx.doi.org/10.1136/bmj.a1284 18801868
159 Kyrgiou M, Mitra A, Arbyn M, Fertility and early pregnancy outcomes after conservative treatment for cervical intraepithelial neoplasia. Cochrane Database Syst Rev. 2015(9):CD008478. PMID: 26417855. http://dx.doi.org/10.1002/14651858.CD008478.pub2 26417855
160 Conner SN, Frey HA, Cahill AG, Loop electrosurgical excision procedure and risk of preterm birth: a systematic review and meta-analysis. Obstet Gynecol. 2014;123(4):752–61. PMID: 24785601. http://dx.doi.org/10.1097/AOG.0000000000000174 24785601
161 Herweijer E, Feldman AL, Ploner A, The Participation of HPV-Vaccinated Women in a National Cervical Screening Program: Population-Based Cohort Study. PLoS ONE [Electronic Resource]. 2015;10(7):e0134185. PMID: 26218492. http://dx.doi.org/10.1371/journal.pone.0134185 26218492
162 Dorton BJ, Vitonis AF, Feldman S. Comparing Cervical Cytology and Histology Among Human Papillomavirus-Vaccinated and -Unvaccinated Women in an Academic Colposcopy Clinic. Obstet Gynecol. 2015;126(4):785–91. PMID: 26348184. http://dx.doi.org/10.1097/aog.0000000000001011 26348184
163 Rositch AF, Nowak RG, Gravitt PE. Increased age and race-specific incidence of cervical cancer after correction for hysterectomy prevalence in the United States from 2000 to 2009. Cancer. 2014;120(13):2032–8. PMID: 24821088. http://dx.doi.org/10.1002/cncr.28548 24821088
164 Rodriguez-Carunchio L, Soveral I, Steenbergen RD, HPV-negative carcinoma of the uterine cervix: a distinct type of cervical cancer with poor prognosis. BJOG. 2015;122(1):119–27. PMID: 25229645. http://dx.doi.org/10.1111/1471-0528.13071 25229645
165 Mesher D, Soldan K, Lehtinen M, Population-Level Effects of Human Papillomavirus Vaccination Programs on Infections with Nonvaccine Genotypes. Emerg Infect Dis. 2016;22(10):1732–40. 10.3201/eid2210.160675 27648688
166 Snijders PJ, Verhoef VM, Arbyn M, High-risk HPV testing on self-sampled versus clinician-collected specimens: a review on the clinical accuracy and impact on population attendance in cervical cancer screening. Int J Cancer. 2013;132(10):2223–36. PMID: 22907569. http://dx.doi.org/10.1002/ijc.27790 22907569
167 Racey CS, Withrow DR, Gesink D. Self-collected HPV testing improves participation in cervical cancer screening: a systematic review and meta-analysis. Can J Public Health. 2013;104(2):e159–66. PMID: 23618210. None23618210
168 Huynh J, Howard M, Lytwyn A. Self-collection for vaginal human papillomavirus testing: systematic review of studies asking women their perceptions. J Low Genit Tract Dis. 2010;14(4):356–62. PMID: 20885165. http://dx.doi.org/10.1097/LGT.0b013e3181dc115b 20885165
169 Arbyn M, Verdoodt F, Snijders PJ, Accuracy of human papillomavirus testing on self-collected versus clinician-collected samples: a meta-analysis. Lancet Oncol. 2014;15(2):172–83. PMID: 24433684. http://dx.doi.org/10.1016/S1470-2045(13)70570-9 24433684
170 Giorgi Rossi P, Fortunato C, Barbarino P, Self-sampling to increase participation in cervical cancer screening: An RCT comparing home mailing, distribution in pharmacies, and recall letter. Br J Cancer. 2015;112(4):667–75. PMID: 25633037. http://dx.doi.org/10.1038/bjc.2015.11 25633037
171 Cadman L, Wilkes S, Mansour D, A randomized controlled trial in non-responders from Newcastle upon Tyne invited to return a self-sample for Human Papillomavirus testing versus repeat invitation for cervical screening. J Med Screen. 2015;22(1):28–37. PMID: 25403717. http://dx.doi.org/10.1177/0969141314558785 25403717
172 Broberg G, Jonasson JM, Ellis J, Increasing participation in cervical cancer screening: telephone contact with long-term non-attendees in Sweden. Results from RACOMIP, a randomized controlled trial. International journal of cancer Journal international du cancer. 2013;133(1):164–71. PMID: 23233356. http://dx.doi.org/10.1002/ijc.27985 23233356
173 Darlin L, Borgfeldt C, Forslund O, Comparison of use of vaginal HPV self-sampling and offering flexible appointments as strategies to reach long-term non-attending women in organized cervical screening. Journal of clinical virology: the official publication of the Pan American Society for Clinical Virology [serial on the Internet]. 2013 [cited Search 1 CENTRAL 20150806; 58(1): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/776/CN-00918776/frame.html http://ac.els-cdn.com/S1386653213002618/1-s2.0-S1386653213002618-main.pdf?_tid=d6a18a10-a8d0-11e5-9af7-00000aab0f02&acdnat=1450805241_1369673b4c2d76ca0eccd7c946ba5da0.
174 Sancho-Garnier H, Tamalet C, Halfon P, HPV self-sampling or the Pap-smear: a randomized study among cervical screening nonattenders from lower socioeconomic groups in France. International journal of cancer Journal international du cancer [serial on the Internet]. 2013 [cited Search 1 CENTRAL 20150806; 133(11): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/669/CN-00963669/frame.html http://onlinelibrary.wiley.com/store/10.1002/ijc.28283/asset/ijc28283.pdf?v=1&t=iihnxwbr&s=9cc8923bd455830b95f8eedfe11a6322e49b1647.
175 Sultana F, English DR, Simpson JA, Home-based HPV self-sampling improves participation by never-screened and under-screened women: Results from a large randomized trial (iPap) in Australia. Int J Cancer. 2016;139(2):281–90. PMID: 26850941. http://dx.doi.org/10.1002/ijc.30031 26850941
176 Sultana F, English DR, Simpson JA, editors. Randomized controlled trial of home-based HPV self-sampling for improving participation in cervical screening by never- and underscreened women in Australia. 15th Biennial Meeting of the International Gynecologic Cancer Society; 2014; Melbourne, VIC Australia. PMID: None.
177 Enerly E, Bonde J, Schee K, Self-Sampling for Human Papillomavirus Testing among Non-Attenders Increases Attendance to the Norwegian Cervical Cancer Screening Programme. PLoS ONE [Electronic Resource]. 2016;11(4):e0151978. PMID: 27073929. http://dx.doi.org/10.1371/journal.pone.0151978 27073929
178 Carrasquillo O, Kobetz-Kerman EN, Alonzo Y, editors. A randomized trial of self-sampling for human papilloma virus among minority immigrant women in need of cervical cancer screening: Findings from the South Florida center for reducing cancer disparities. Journal of general internal medicine; 2015 2015 Apr 25; Toronto, ON Canada. PMID: None.
179 Castle PE, Fetterman B, Poitras N, Variable risk of cervical precancer and cancer after a human papillomavirus-positive test. Obstet Gynecol. 2011;117(3):650–6. PMID: 21343769. http://dx.doi.org/10.1097/AOG.0b013e318209da59 21343769
180 Gage JC, Katki HA, Schiffman M, Age-stratified 5-year risks of cervical precancer among women with enrollment and newly detected HPV infection. Int J Cancer. 2015;136(7):1665–71. PMID: 25136967. http://dx.doi.org/10.1002/ijc.29143 25136967
181 Katki HA, Schiffman M, Castle PE, Benchmarking CIN 3+ risk as the basis for incorporating HPV and Pap cotesting into cervical screening and management guidelines. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S28–35. PMID: 23519302. http://dx.doi.org/10.1097/LGT.0b013e318285423c 23519302
182 Jeronimo J, Castle PE, Temin S, Secondary Prevention of Cervical Cancer: American Society of Clinical Oncology Resource-Stratified Clinical Practice Guideline Summary. J Oncol Pract. 2017;13(2):129–33. 10.1200/JOP.2016.017889 27845871
183 Sawaya GF, Kulasingam S, Denberg T, Cervical cancer screening in average-risk women: best practice advice from the clinical guidelines committee of the American College of Physicians. Ann Intern Med. 2015. PMID: 25928075. 10.7326/M14-2426 25928075
184 Partridge EE, Abu-Rustum N, Giuliano A, Cervical cancer screening. J Natl Comp Canc Netw. 2014;12(3):333–41; quiz 41. PMID: 24616539.24616539
185 Partridge EE, Abu-Rustum NR, Campos SM, Cervical cancer screening. J Natl Comp Canc Netw. 2010;8(12):1358–86. PMID: 21147902.21147902
186 Canadian Task Force on Preventive Health C, Dickinson J, Tsakonas E, Recommendations on screening for cervical cancer. CMAJ. 2013;185(1):35–45. PMID: 23297138. http://dx.doi.org/10.1503/cmaj.121505 23297138
187 Wilkinson J, Bass C, Diem S, Preventive services for adults. Bloomington, MI: Institute for Clinical Systems Improvement; 2013.
188 WHO Guidelines for Screening and Treatment of Precancerous Lesions for Cervical Cancer Prevention. Geneva: World Health Organization 2013.; 2013.
189 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Cervical Cancer. http://www.aafp.org/patient-care/clinical-recommendations/all/cervical-cancer.html. Accessed: June 27, 2017.
190 Committee on Practice Bulletins-Gynecology. ACOG Practice Bulletin Number 131: Screening for cervical cancer. Obstet Gynecol. 2012;120(5):1222–38. PMID: 23090560. http://dx.doi.org/10.1097/AOG.0b013e318277c92a 23090560
191 Aoki D. CervIcal Cancer Screening Trial by Randomization of HPV Testing Intervention for Upcoming Screening (CITRUS Study). https://clinicaltrials.gov/ct2/show/NCT01895517?term=NCT01895517&rank=1. Accessed: June 27, 2017.
192 Cantfell K, Darlington-Brown JB. Compass - Randomized Controlled Trial of Primary HPV Testing for Cervical Screening in Australia. https://clinicaltrials.gov/ct2/show/NCT02328872?term=NCT02328872&rank=1. Accessed: June 27, 2017.
193 Murphy JK. Pap Smear Research Study. https://clinicaltrials.gov/ct2/show/NCT00743626?term=NCT00743626&rank=1. Accessed: June 27, 2017.
194 Ngan HYS. HPT-cytology Testing Versus Cytology Testing for the Detection of High Grade CIN (COCY). https://clinicaltrials.gov/ct2/results?term=NCT01058460&Search=Search. Accessed: June 27, 2017.
195 Haguenoer K, Giraudeau B, Gaudy-Graffin C, Accuracy of dry vaginal self-sampling for detecting high-risk human papillomavirus infection in cervical cancer screening: a cross-sectional study. Gynecol Oncol. 2014;134(2):302–8. PMID: 24905772. 10.1016/j.ygyno.2014.05.026 24905772
196 Haguenoer K, Sengchanh S, Gaudy-Graffin C, Vaginal self-sampling is a cost-effective way to increase participation in a cervical cancer screening programme: a randomised trial. Br J Cancer. 2014;111(11):2187–96. PMID: 25247320. 10.1038/bjc.2014.510 25247320
197 Haguenoer K. Self-sampling and human papillomavirus (HPV)-testing for unscreened women in cervical cancer prevention (APACHE-2). https://clinicaltrials.gov/ct2/show/NCT01588301?term=NCT01588301&rank=1. Accessed: June 27, 2017.
198 Haguenoer K, Foulon C. Vaginal self-sampling and human papillomavirus testing in unscreened women (APACHE-3). https://clinicaltrials.gov/ct2/show/NCT02255084?term=NCT02255084&rank=1. Accessed: June 27, 2017.
199 Kiviat N. Home-based or clinic-based human papillomavrius (HPV) screening. https://clinicaltrials.gov/ct2/show/NCT01550783?term=NCT01550783&rank=1. Accessed: June 27, 2017.
200 Lytwyn A. Randomized trial of vaginal self-sampling for human papillomavirus (HPV). https://clinicaltrials.gov/ct2/show/NCT01095198?term=NCT01095198&rank=1. Accessed: June 27, 2017.
201 Svanholm H. Cervix cytological screening-comparison of tampon self-test and routine smear. https://clinicaltrials.gov/ct2/show/NCT00377845?term=NCT00377845&rank=1. Accessed: June 27, 2017.
202 Szarewski A, Cadman L, Mesher D, HPV self-sampling as an alternative strategy in non-attenders for cervical screening - a randomised controlled trial. Br J Cancer. 2011;104(6):915–20. PMID: 2134393721343937. 10.1038/bjc.2011.48
203 Virtanen A, Nieminen P, Luostarinen T, Self-sample HPV tests as an intervention for nonattendees of cervical cancer screening in Finland: a randomized trial. Cancer Epidemiol Biomarkers Prev. 2011;20(9):1960–9. PMID: 21752985. 10.1158/1055-9965.EPI-11-0307 21752985
204 Winer RL. Randomized trial of in-home cervical cancer screening in underscreened women. https://clinicaltrials.gov/ct2/show/NCT02005510?term=NCT02005510&rank=1. Accessed: June 27, 2017.
205 Maar M, Wakewich P, Wood B, Strategies for Increasing Cervical Cancer Screening Amongst First Nations Communities in Northwest Ontario, Canada. Health Care Women Int. 2014:1–18. PMID: 2537566125375661. 10.1080/07399332.2014.959168
206 Wood B, Burchell AN, Escott N, Using community engagement to inform and implement a community-randomized controlled trial in the anishinaabek cervical cancer screening study. Front Oncol. 2014;4:27. PMID: 24600584. 10.3389/fonc.2014.00027 24600584
207 Zorzi M, Del Mistro A, Farruggio A, Use of a high-risk human papillomavirus DNA test as the primary test in a cervical cancer screening programme: a population-based cohort study. BJOG. 2013;120(10):1260–7; discussion 7-8. PMID: 23786222. http://dx.doi.org/10.1111/1471-0528.12272 23786222
208 Ogilvie GS, Krajden M, van Niekerk DJ, Primary cervical cancer screening with HPV testing compared with liquid-based cytology: results of round 1 of a randomised controlled trial - the HPV FOCAL Study. Br J Cancer. 2012;107(12):1917–24. PMID: 23169286. http://dx.doi.org/10.1038/bjc.2012.489 23169286