# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Evelyn P. Whitlock, MD, MPH, for mentoring and project oversight; Jamie Thompson, MPH, for assistance with scoping; and Smyth Lai, MLS, and Katherine Essick, BS, for technical and editorial assistance at the Kaiser Permanente Center for Health Research. We also thank David Chelmo, MD, Sarah Feldman, MD, MPH, Robert Goulart, MD, Herschel Lawson, MD, L. Stewart Massad, MD, Diana Petitti, MD, MPH, Mona Saraiya, MD, MPH, Debbie Saslow, PhD, Mark Schiffman, MD, MPH, and Alan Waxman, MD, MPH, who provided expert review; Elizabeth Unger, MD, PhD, Lauri Markowitz, MD, and Elissa Meites, MD, MPH, at the Centers for Disease Control and Prevention, Carolyn Aoyama, CNM, MPH, at the Indian Health Service, Nahida Chakhtoura, MD, at the National Institute of Child Health and Human Development, and Sung Sug Yoon, PhD, RN, at the National Institute of Nursing Research, who provided federal partner review. We also thank Tracy Wolff, MD, MPH, and Elisabeth Kato, MD, at AHRQ; as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.