# [Front Matter]

The literature search conducted for this systematic review report was completed in February 2017, with ongoing literature surveillance through December 2017. While preparing the manuscript based on this report, the review team was informed that the final 48-month results of the HPV-FOCAL trial (described in this report as pending final results) would be published in JAMA on July 3, 2018.^1^ The JAMA manuscript based on this systematic review was therefore updated to include final results of the HPV-FOCAL trial, which are summarized in this memo. The conclusions of this report were unchanged, with the addition of the findings of the completed trial. The evidence for hrHPV primary screening remained consistent and is more robust when the final results of HPV FOCAL are considered.

The following paragraphs summarize the HPV FOCAL trial findings, including the 48-month exit round results.^1^ The manuscript derived from this report has fully incorporated these results and was published in JAMA on August 21, 2018.

The HPV FOCAL trial was a randomized, controlled trial of 19,009 women ages 25 to 65 years. The study compared hrHPV screening with liquid-based cytology triage of abnormal hrHPV results every 4 years (intervention group) with liquid-based cytology screening every 2 years (control group). During the first round of screening, CIN3+ detection was 0.7 percent in the intervention group and 0.4 percent in the control group; the RR for CIN3+ detection was 1.61 (95% CI, 1.09 to 2.37). In the 48-month round of screening, in which both groups received cotesting, CIN3+ detection was 0.2 percent in the intervention group and 0.6 percent in the control group; the RR for CIN3+ detection was 0.42 (95% CI, 0.25 to 0.69). Cumulative CIN3+ detection over both rounds was 0.9 percent in the intervention group and 1.0 percent in the control group (relative risk [RR], 0.94 [95% CI, 0.71 to 1.26]). Among women younger than age 30 years, overall rates of CIN3+ were consistent with the overall results but not statistically significant. CIN3+ rates were higher in the first round of screening: 2.4 percent in the intervention group vs. 1.7 percent in the control group (RR, 1.43 [95% CI, 0.73 to 2.82]), and lower in the 48-month round: CIN 3+ detection was 0.7 percent in the intervention group vs. 1.8 percent in the control group (RR, 0.4 [95 % CI, 0.16 to 1.02]). Cumulative CIN3+ detection over both rounds was 3.1 percent in the intervention group and 3.5 percent in the control group (RR, 0.90 [95% CI, 0.53 to 1.51]). A similar and statistically significant pattern was found in women age 30 years and older, but CIN3+ rates were lower. In the first screening round, CIN3+ was 0.5 percent in the intervention group and 0.3 percent in the control group (RR, 1.71 [95% CI, 1.07 to 2.74]). At the 48-month screening round, rates were 0.2 percent in the intervention group vs. 0.4 percent in the control group (RR, 0.43 [95% CI, 0.24 to 0.76]). Cumulative CIN3+ detection was 0.7 percent in both intervention and control groups (RR, 0.97 [95% CI, 0.69 to 1.37]).

Consistent with the majority of studies of primary hrHPV screening, referrals to colposcopy were higher in the first screening round for women in the intervention group (5.7% vs. 3.1%). At the 48-month screening round, with cotesting of both groups, colposcopy referrals were somewhat lower in the intervention group (4.9% vs. 7.0%).

Overall, the trial findings provide evidence that primary hrHPV screening at a 4-year interval is at least as good as liquid-based cytology screening every 2 years for detecting CIN3+.

## Reference

1 Ogilvie GS, van Niekerk D, Krajden M, Effect of screening with primary cervical HPV testing vs. cytology testing on high-grade cervical intraepithelial neoplasia at 48 months: the HPV FOCAL randomized clinical trial. JAMA. 2018;320(1):43–52.29971397