# Chapter 4 Discussion

## Summary of Evidence

### hrHPV Screening Effectiveness

Eight randomized trials, four of primary hrHPV testing and four of hrHPV cotesting, contributed to the evidence comparing use of hrHPV testing for cervical cancer screening to cytology alone for detection of CIN3+ (Table 20). All trials were conducted in the context of organized screening programs, with heterogeneous screening strategies and followup protocols. Interpretation of trial findings was limited by the fact that only one trial (ARTISTIC) maintained the same strategy over two rounds of screening. The trial evidence was supplemented with results of large cohort studies of hrHPV primary testing or cotesting over two screening rounds; however, none of the cohort studies had a comparison group screened with cytology only.

Table 20 Summary of Evidence on hrHPV Testing Alone (Primary Screening) or With Cytology (Cotesting) for Cervical Cancer Screening

Testing method | # of Studies (k), # of Observations (n) Study Designs | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence for That KQ | Applicability
Benefits
KQ 1: Effectiveness of hrHPV testing or cotesting vs. cytology alone for reducing cervical cancer incidence and mortality
hrHPV primary screening | k=4 RCTs n=282,839 1 cohort study n=48,736 | In 4 RCTs reporting results over 1 to 2 rounds of screening spanning 4 to 7 years, hrHPV testing found more CIN3+ in the initial screening round; cumulative rates of CIN3+ were higher in the intervention group in the single completed study with 2 rounds of screening. Overall, CIN3+ detection ranged from 0.3% to 0.8% across studies. The HPV FOCAL and Compass trials have not published complete results. Invasive cancers were only reported in 1 RCT, but numbers were very small (<0.1%), so statistical comparisons were not meaningful. Mortality data were not reported. | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence | Not detected | RCTs: 1 good, 3 fair Cohort: 1 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocols; insufficient power to assess cervical cancer incidence and mortality. | We are moderately confident that the estimate of higher detection of CIN3+ in the initial screening round for primary hrHPV-based screening strategies vs. cytology lies close to the true effect; with considerable heterogeneity in study design, testing protocols, and followup, some uncertainty remains. We have limited confidence that the estimate of the effect of primary hrHPV screening on cumulative CIN3+ detection or ICC incidence lies close to the true effect for this outcome. The body of evidence has numerous deficiencies. Evidence is insufficient to determine the effect of primary hrHPV testing on cervical cancer incidence and mortality in unscreened and underscreened women. | All trials were in organized screening programs in European countries with nationalized health systems. Applicability may be lower for women in the United States without access to health care or to organized screening programs, and higher for U.S. women with access to care in health systems with organized cervical cancer screening programs.
hrHPV cotesting with cytology | k=4 RCTs, 2 cohort studies n= 127,717 (RCTs) n=351,613 (cohorts) | In 4 RCTs reporting results over 1 to 2 rounds of screening spanning 4.5 to 9 years, cotesting found no significant increase in CIN3+ detection at Round 1 and similar cumulative rates of CIN3+ between treatment groups. 13-year followup in 1 trial did not detect a difference between arms. A large single cohort study (n=331,818) found 0.7% of women screened with cotesting had CIN3+ over 6 years. Among women who screened negative and were rescreened after 3 years, 0.05% were found to have CIN3+. Another cohort study (n=19,795) found decreasing rates of CIN3+ detected over 2 screening rounds (0.57% in round 1, 0.05% in round 2). | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence | Not detected | RCTs: 2 good, 2 fair Cohorts: 2 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocol; trials underpowered to assess cervical cancer incidence and mortality Single cohort study with no comparison group. | We are moderately confident that the estimate of no difference in the initial screening round or cumulative difference in CIN3+ detection for hrHPV cotesting screening strategies vs. cytology lies close to the true effect; with considerable heterogeneity in study design, testing protocols, and followup, some uncertainty remains. Evidence is insufficient to determine the effect of hrHPV testing on cervical cancer incidence and mortality in unscreened and underscreened women. | All trials were in organized screening programs in European countries with nationalized health systems. Applicability may be lower for women in the United States without access to health care or to organized screening programs, and higher for U.S. women with access to care in health systems with organized cervical cancer screening programs.
hrHPV primary screening or cotesting with cytology | k=1 (IPD meta-analysis) n=176,464 | An IPD meta-analysis combined 5 trials (1 primary screening trial and 4 cotesting trials) with different populations, hrHPV test types, and screening protocols. A total of 107 cases of ICC among 176,464 women were identified in the trials. The pooled RR for ICC was 0.60 (95% CI, 0.40 to 0.89) for hrHPV testing. | For the IPD meta-analysis, findings were reasonably statistically consistent and precise for ICC detection over 1 to 2 rounds of screening | Not detected | | Pooled outcomes of primary hrHPV testing and cotesting trials with marked heterogeneity in study design, testing protocols, followup, and ICC ascertainment | We have limited confidence that the estimate of the effect of hrHPV screening on cumulative CIN3+ detection or ICC incidence lies close to the true effect for this outcome. Evidence is insufficient to determine the effect of hrHPV testing on cervical cancer incidence and mortality in unscreened and underscreened women. | All trials were in organized screening programs in European countries with nationalized health systems. Applicability may be lower for women in the United States without access to health care or to organized screening programs, and higher for U.S. women with access to care in health systems with organized cervical cancer screening programs.
KQ 1a: Subpopulation differences in screening for reducing cervical cancer incidence and mortality
hrHPV primary screening in women age <30–35 years | k=4 RCTs, 1 cohort study n=41,914 | 4 RCTs report absolute detection of CIN3+; 3 trials reported only 1 round of screening, 1 trial reported on 2 rounds. Women age <35 years had higher rates of cumulative CIN3+ detection across studies. Cumulative CIN3+ remained higher in the study with 2 screening rounds (RR, 2.19 [95% CI, 1.31–3.66]). Across trials, CIN3+ rates ranged from 0.3% to 2.4%. Findings from the cohort study, with higher rates of CIN2+ in women ages 25–29 years, were consistent with the trials. Mortality data were not reported. | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence | Not detected | RCTs: 1 good, 3 fair Cohort: 1 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocol; trials underpowered to assess cervical cancer incidence and mortality. | We are moderately confident based on strong evidence that CIN3+ rates were highest in women ages <30–35 years but comparative performance of hrHPV primary testing vs. cytology was similar to the overall trial results | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV cotesting with cytology in women ages <30–35 years | k=3 RCTs n=23,243 | 3 cotesting trials reported on women age <30–35 years; 2 reported on 2 rounds of screening. CIN3+ detection rates were higher in women age <30–35 years, rates were comparable between the IG and CG for both rounds, with no significant differences in cumulative CIN3+; detection rates ranged from 0.1% to 3.3% across trials. Mortality data were not reported. | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence or mortality | Not detected | RCTs: 2 good, 1 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocol; trials underpowered to assess cervical cancer incidence and mortality. | We are moderately confident based on strong evidence that CIN3+ rates were highest in women age <30–35 years but comparative performance of hrHPV cotesting vs. cytology was similar to the overall trial results | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV primary screening or cotesting with cytology in women age <30–35 years | k=1 IPD meta-analysis n=176,464 all age groups n not broken down by age group | The IPD meta-analysis reported ICC rate ratios by age. The lowest RR was for ages 30–34 years (0.36 [95% CI, 0.14 to 0.94]), but this RR did not differ significantly from the RR for women age ≥35 years. Mortality data were not reported. | | Not detected | | Pooled outcomes of primary hrHPV testing and cotesting trials with marked heterogeneity in study design, testing protocols, followup, and ICC ascertainment
hrHPV primary screening in women age ≥30–35 years | k=4 RCTs n=169,714 1 cohort study n=43,647 | 4 RCTs report findings from a single screening round (2 to 3.5 years) and 1 reported results from 2 rounds of screening. CIN3+ outcomes were similar to the overall group results. Only 1 reported cumulative detection over 2 rounds of screening, with an RR of 1.57 (95% CI, 1.03 to 2.40). CIN3+ detection rates ranged from 0.2% to 0.5%. The cohort study found lower rates of CIN2+ in women ages 30–64 years over 2 rounds of primary hrHPV screening. Mortality data were not reported. | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence or mortality | Not detected | RCTs: 1 good, 3 fair Cohort: 1 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocol; trials underpowered to assess cervical cancer incidence and mortality. | We are moderately confident based on strong evidence that for women age ≥35 years, comparative performance of hrHPV primary screening vs. cytology was similar to the overall trial results
hrHPV cotesting with cytology in women age ≥30–35 years | k=4 RCTs n=99,073 1 cohort study n=1,022,588 | 4 RCTs report findings from a single screening round (2.2 to 4 years) and 3 report results from 2 rounds of screening. CIN3+ outcomes were similar to the overall group results, with no significant differences in cumulative CIN3+ detection in any trial. CIN3+ detection rates ranged from 0.03% to 1.4%. A large cohort study found the 5-year risk of CIN3+ with cotesting in this age group was 0.59 (95% CI, 0.57 to 0.61) compared to 1.12 (95% CI, 1.05 to 1.19) in women age <30 years, but cotesting in the younger group was performed for ASC-US triage. Mortality data were not reported. | Reasonably consistent and precise for CIN3+ detection over 1 to 2 rounds of screening Imprecise/NA for cervical cancer incidence or mortality | Not detected | RCTs: 2 good, 2 fair | Randomization not maintained for more than 1 or 2 rounds of screening; heterogeneity in screening and followup tests and protocol; trials underpowered to assess cervical cancer incidence and mortality. Single cohort study with no comparison group and different screening approaches limit age comparisons | We are moderately confident based on strong evidence that CIN3+ rates were highest in women age <30–35 years but comparative performance of hrHPV cotesting vs. cytology was similar to the overall trial results | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV primary screening or cotesting with cytology in women ages ≥30–35 years | 1 IPD meta-analysis n=176,464 | As noted above, the IPD meta-analysis did not find statistical differences in the pooled rate ratio by age groups. Mortality data were not reported. | | Not detected | | | | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV primary screening in unscreened women | k=0 | NA | NA | NA | NA | NA | NA | NA
hrHPV cotesting with cytology in unscreened women | k=1 cohort study n=1,832 | 1 single cohort study of underscreened women of 1-time hrHPV cotesting; of 9 CIN3+ cases, all were hrHPV+ and 6 had positive cytology. | Imprecise Consistency NA | Not detected | 1 Fair | Lack of a comparison group, substantial loss to followup | We have low confidence, based on limited evidence from 1 small cohort study, that the CIN3+ detection rate among unscreened women is improved with hrHPV testing | Only 1 study conducted in Spain
KQ 1b and 1c: Relationship of rescreening intervals to future cancer incidence or progression
HPV primary screening or cotesting compared to cytology | No comparative studies | No completed trials compared screening intervals with use of hrHPV testing. Trials comparing hrHPV testing to cytology used 2- to 5-year intervals, but given variability of screening protocols, comparison between trials was not meaningful. No evidence on subpopulations | NA | NA | NA | NA | Evidence is insufficient for comparison of rescreening intervals with hrHPV testing on cancer-related outcomes. No evidence on subpopulations and rescreening intervals was identified. | NA
Harms
KQ 2: Adverse effects of hrHPV testing or cotesting vs. cytology
hrHPV primary screening | Colposcopy, biopsy, false positives, and false negatives k=4 RCTs n=282,839 1 cohort study n=48736 | False-positive rates were consistently higher in the IG. 3 trials had more referrals to colposcopy among women in the IG vs. CG in round 1 of screening. 1 trial had similar rates of referral to colposcopy at round 1 in both trial arms. The highest rates of colposcopy referral were in the trial, which referred all HPV+ women to colposcopy. Data from an Italian cohort had similar round 1 false-positive rates (6.4%) and colposcopy referrals (4.4%), with both approximately halved at the second screening round. None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN. Cases of ICC among screen-negative women (false negatives) were not consistently reported, but were rare with numbers too small to draw comparisons. | Reasonably consistent Reasonably Precise | Not detected | RCTs: 1 good, 3 fair Cohort: 1 fair | Heterogeneity in screening followup protocols make it difficult to draw conclusions about relative harms of different hrHPV screening strategies compared to cytology alone. Limited data on harms of screening and diagnostic procedures. Not all trials reported colposcopy and biopsy rates. | We are moderately confident that the estimates for colposcopy referrals and false-positive rates of HPV-based screening strategies vs. cytology lie close to the true effects. We have insufficient evidence for estimating differences in the false-negative rates, and no evidence on complications of screening. | All trials were in organized screening programs in European countries with nationalized health systems. Applicability may be lower for women in the United States without access to health care or to organized screening programs, and higher for U.S. women with access to care in health systems with organized cervical cancer screening programs.
hrHPV cotesting with cytology | Colposcopy, biopsy, false positives, and false negatives k=4 RCTs, 2 cohort studies n=127,717 (RCTs) n=351,613 (cohorts) | False-positive rates were consistently higher in the IG. 2 trials reported higher rates of referrals to colposcopy at round 1. Round 2 results, reported only in one trial, were similar between treatment groups (IG: 2.7% vs. CG: 2.1%). 2 trials reported colposcopy referrals in the first round, which were higher in the IG than in the CG. (10.9% vs. 3.3% and 6.9% vs. 5.2%). One study reported colposcopy referrals in the second round, referrals were higher in the IG (2.7% vs. 2.1%). Cohort data from screened women in Germany (WOLPHSCREEN) found colposcopy referral rates of 3.9% after 1 round of screening with cotesting, and an additional 1.0% at the second round. None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN. Cases of ICC among screen-negative women (false negatives) were not consistently reported, but were rare with numbers too small to draw comparisons. | Reasonably consistent Reasonably Precise | Not detected | RCTs: 2 good, 2 fair Cohort: 1 fair | Heterogeneity in screening followup protocols make it difficult to draw conclusions about relative harms of different hrHPV screening strategies compared to cytology alone Limited data on harms of screening and diagnostic procedures. Not all trials reported colposcopy and biopsy rates. | We are moderately confident that the estimates for colposcopy referrals and false-positive rates of HPV-based screening strategies vs. cytology lie close to the true effects. We have insufficient evidence for estimating differences in the false-negative rates, and no evidence on complications of screening. | All trials were in organized screening programs in European countries with nationalized health systems. Applicability may be lower for women in the United States without access to health care or to organized screening programs, and higher for U.S. women with access to care in health systems with organized cervical cancer screening programs
hrHPV primary screening or cotesting with cytology | Colposcopy, biopsy, false positives, and false negatives 1 IPD meta-analysis n=176,464 | The IPD meta-analysis did not report colposcopy rates but reported biopsy rates. Pooled biopsy rates had very high heterogeneity explained by the 2-fold difference in biopsy rates in one trial. Biopsy rates were similar between arms for the other trials. False-positive rates for CIN2+ detection were higher in the IG for 5 trials reporting sufficient data for this outcome at round 1. In 2 trials with data on round 2 false-positive rates, they were similar in the trial with the most complete followup, and remained higher in the IG for the other. Fewer ICC cases were reported among women who screened negative at entry with hrHPV-based screening (n=12) compared to control (n=35). | | Not detected | | Pooled outcomes of primary hrHPV testing and cotesting trials with marked heterogeneity in study design, testing protocols, followup, and ICC ascertainment High statistical heterogeneity in pooled estimate of biopsy rates | We have limited confidence that the pooled estimate for biopsy rate and false-negative rate for ICC lies close to the true effect. | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV primary screening | Psychological harms k=0 | NA | NA | NA | NA | NA | NA | NA
hrHPV cotesting with cytology | Psychological harms k=1 RCT, 1 cross-sectional study n=2,508 (RCT) n=428 (cross-sectional) | 2 studies reported psychological effects of HPV cotesting; positive hrHPV test results were associated with higher anxiety and distress and lower satisfaction with current and past sexual partnerships, particularly when cytology findings are normal. | Reasonably consistent Reasonably Precise | Undetected | 2 Fair | Limited data: one trial reporting psychological harms of screening, one cross-sectional study | We are moderately confident that the estimates for psychological effects of screening lie close to the true effect. | Psychological harms assessed in women enrolled in organized screening in the United Kingdom, findings may not be fully applicable to U.S. women
KQ 2a: Subpopulations (adverse effect differences by age)
hrHPV primary screening in women age <30–35 years | Colposcopy, biopsy, false positives, and false negatives k=4 RCTs n=41,914 | Colposcopy referral rate differences varied by study but were consistently higher in the IG than in the CG with 1 round of screening. 1 trial reported colposcopy referrals for the youngest women, ages 25 to 29 years; these were the highest observed for any trial group (19.9% [95% CI, 17.9% to 22.1%]). One study reported false-positive rates in women age <30–35 years; rates in the IG were higher (12.2%) than in the CG (3.7%). None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN by age. Psychological harms also were not reported. None of the trials with more than 1 round of screening data available reported colposcopy rates at round 2 by age. False negatives by age were not reported. | Reasonably consistent Reasonably precise | Undetected | RCTs: 1 good, 2 fair | | We are moderately confident that the estimates for colposcopy referrals and false-positive rates of HPV-primary screening vs. cytology lie close to the true effects for women age <35 years. We identified no evidence on psychological harms by age group or on complications related to biopsies and subsequent treatments. | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV cotesting with cytology in women age <30–35 years | Colposcopy, biopsy, false positives, and false negatives k=1 RCT n=11,810 | Colposcopy referrals were reported by age for Round 1, rates were higher in younger women in the IG vs. CG (11.6% vs. 4.1%). The most pronounced group differences in false-positive rates were seen among younger women; 20% among IG women and 4% among CG women ages 25 to 34 years. None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN by age. Psychological harms were not reported by age. None of the trials with more than 1 round of screening data available reported colposcopy rates at round 2 by age. False negatives by age were not reported. | Reasonably consistent Reasonably precise | Undetected | 1 good, | | We are moderately confident that the estimates for colposcopy referrals and false-positive rates of HPV-cotesting vs. cytology lie close to the true effects for women age <35 years. We identified no evidence on psychological harms by age group or on complications related to biopsies and subsequent treatments. | All trials were in organized screening programs in European countries with nationalized health systems. .
hrHPV primary screening in women age ≥30–35 years | Colposcopy, biopsy, false positives, and false negatives k=4 RCTs n=169,714 | All four trials reported colposcopy referrals for women age >30 or >35 years at round 1. Rates tended to be higher in the IG, similar to the overall findings for KQ 2, but were slightly lower in magnitude. One trial reported false-positive rates by age; they were higher in the IG (5.4%) compared with the CG (2.9%). None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN by age. Psychological harms also were not reported by age. | Reasonably consistent Reasonably precise | Undetected | 1 good, 2 fair | | We are moderately confident that a single round of HPV-based screening in women age >30–35 years will result in higher rates of colposcopy compared to cytology-based screening. We have no evidence to estimate the effect of HPV-based screening on other potential harms of screening. | All trials were in organized screening programs in European countries with nationalized health systems.
hrHPV cotesting with cytology in women age ≥30–35 years | Colposcopy, biopsy, false positives, and false negatives k=1 RCT, 1 cohort n=33,364 (RCT) n=331,818 (cohort) | Only one trial reported colposcopy referrals; it found higher referral rates in the IG vs. CG group (10.6% vs. 3.0%). This trial also found higher false-positive rates in the IG vs. CG (10.4% vs. 3.3%) among women ages 35 to 60 years; this was lower magnitude and less discrepant than among younger women. None of the included studies reported adverse events associated with screening, diagnostic testing, or treatment of CIN by age. Psychological harms were not reported by age. | Reasonably consistent Reasonably precise | Undetected | 1 good | | We are moderately confident that a single round of HPV-based screening in women age >30 or 35 years will result in higher rates of colposcopy compared to cytology-based screening. We have no evidence to estimate the effect of HPV-based screening on other potential harms of screening. | All trials were in organized screening programs in European countries with nationalized health systems.
KQ 2b and 2c: Relationship of rescreening intervals to future cancer incidence or progression
HPV primary screening or cotesting compared to cytology | No comparative studies | No completed trials compared screening intervals with use of hrHPV testing. Trials comparing hrHPV testing to cytology used 2- to 5-year intervals, but given variability of screening protocols, comparison between trials was not meaningful. No evidence on subpopulations. | NA | NA | NA | NA | Evidence is insufficient for comparison of rescreening intervals with hrHPV testing on cancer-related outcomes. No evidence on subpopulations and rescreening intervals was identified. | NA

The evidence was generally consistent across trials with variable protocols and hrHPV test types in demonstrating that primary hrHPV testing increased detection of CIN3+ in the initial round of screening by as much as 2- to 3-fold. Only the NTCC Phase II trial of primary hrHPV testing, where all women with a positive hrHPV test were referred to colposcopy, had complete results from two rounds of screening (all women received cytology testing in the second round).^119,^ ^127^ In that study, CIN3+ detection in the first round was 3-fold higher in the hrHPV testing arm, and cumulative detection was 1.8-fold higher after the second round of screening.

Among four trials of hrHPV cotesting, the first round CIN3+ detection was higher in the intervention group in two trials (though not significant) and equal in two trials. Cumulative CIN3+ detection over two rounds of screening ranged from 0.3 to 1.6 percent across studies. The relative risk for cumulative CIN3+ detection ranged from 0.91 to 1.13; none were significantly different from 1. Because no trial sustained the intervention and control group protocols beyond two screening rounds, evidence comparing the long-term outcomes of hrHPV primary testing or cotesting with cytology is lacking.

Evidence on subgroups was limited to age and a single cohort study focused on previously inadequately screened or unscreened women. Women younger than age 35 years had consistently higher rates of hrHPV positivity and of CIN3+. Outcomes of hrHPV primary testing or cotesting between screening strategies by age were not notably different from the results of the overall study populations. In the relatively small single-cohort study of hrHPV cotesting for women in Spain not screened for at least 5 years, CIN3+ was detected in nine women; all were hrHPV positive but three women diagnosed with CIN3 on biopsy had normal cytology findings.

The primary purpose of screening for cervical cancer is to reduce ICC morbidity and mortality. Because ICC is a rare outcome in countries with organized screening programs, no trial had sufficient power to examine cervical cancer incidence rates, and no trials reported on cervical cancer mortality. The IPD meta-analysis performed by Ronco et al pooled patients from five trials (combining one primary and four cotesting trials) and found a 40 percent lower incidence of ICC among patients screened with some form of hrHPV screening compared to cytology screening.^139^ Each of these trials included different patient populations and employed different screening test and followup protocols, adding uncertainty to interpretation of pooled findings.

### hrHPV Screening Harms

The same four hrHPV primary screening trials and four trials of hrHPV cotesting were the primary source of evidence for the comparative harms of cervical cytology screening relative to hrHPV testing. False-negative rates (which lead to ICC that could have potentially been prevented had precursors of ICC been discovered sooner) are approximated by assessing the proportion of women with invasive cancer in the screening interval or at subsequent screening rounds. There were few missed cases of ICC for any of the screening protocols evaluated, and rates of ICC did not statistically differ between control and intervention groups during the trials. Cumulative incidence rates also did not differ in the long-term followup in the POBASCAM trial, although the comparison was based on few cases (10 ICC cases among women who screened hrHPV-, regardless of cytology grouping, and 27 cases among cytology-negative cases in the control group, regardless of hrHPV results). While evidence is limited due to the rarity of ICC and differences among trials, there is some evidence that a negative hrHPV screening result may confer greater confidence that ICC is unlikely to occur. Long-term followup in two trials and the large U.S. cohort study of cotesting suggest that women who test hrHPV negative have very low rates of subsequent CIN3+ regardless of cytology results. In the IPD meta-analysis, rates of ICC after a negative test were lower in the pooled intervention group (12 cases) compared to the pooled cytology-only control group (35 cases) (RR, 0.30 [95% CI, 0.15 to 0.60]).

False-positive results can lead to unnecessary investigations with colposcopy and biopsy, and can result in women with CIN1 or CIN2 undergoing treatments and risking associated complications when these cervical changes might have regressed spontaneously. For primary hrHPV screening, FPRs during the first round of screening could not be calculated for two of the trials, were similar between arms in another trial, and 2- to 3-fold higher for the other. For hrHPV cotesting, FPRs were reported in three of four trials, and were 2 to 3 times higher in the intervention groups compared to cytology alone. Only two trials (of cotesting) reported false-positive results from a second round of screening; in one the rates equalized and in the other they remained elevated in the intervention group.

Rates of treatment or treatment harms were not reported in the screening trials, and few reported biopsy rates. Colposcopies rates provide an indication of potential differences in patient experienced interventions undertaken on the basis of screening. The trial-specific protocols for followup of positive screening results can also influence colposcopy rates. Rates of colposcopy were similar in the hrHPV and cytology arms in two of the primary hrHPV screening trials in the first round of screening. The other two primary hrHPV trials reported higher colposcopy rates for hrHPV screening relative to cytology alone. Of the four cotesting trials, only two reported colposcopy rates, and there were more colposcopies in the cotesting arms relative to women screened with cytology alone. Biopsy rates available from the IPD meta-analysis of cotesting suggest that these higher colposcopy rates led to higher rates of biopsy with cotesting compared to cytology alone.

Once CIN2+ cervical abnormalities are identified, treatment generally follows, although the level of CIN for which treatment is recommended and the type of treatment may vary depending on the clinical setting. Recommendations for treatment from the ASCCP and ACOG outline management algorithms depending on screening test results and abnormalities detected.^64,^ ^145^ A simplified description of these management strategies identifies women as having low, moderate, or high levels of CIN2+ risk based on initial colposcopy results, hrHPV type test results, and patient age.^146^ Generally, for women at low risk, retesting in 3 years is recommended; for women at moderate risk, retesting in 12 months is recommended; and for women at high risk, treatment is recommended. Harms resulting from overtreatment can also be a consequence of screening, but the studies included in the review did not report on subsequent treatments or treatment harms.

Our review included evidence on comparative psychological harms of screening strategies from two studies. Findings of these studies suggested that women undergoing hrHPV screening strategies had lower sexual satisfaction and greater psychological distress related to positive hrHPV test results compared to women with abnormal cytology. It is possible that women find it more distressing to be informed that they have a sexually transmitted virus than to be told that they have abnormal cells on their cervix; the connection to a sexually transmitted infection may not always be communicated or apparent to patients receiving cytology results. Increased education of patients about the cause of abnormal cytology could reduce the observed differences by increasing the distress level for abnormal cytology. A recent systematic review on the psychological consequences of CIN diagnosis and treatment also reported worse psychological and sexual function outcomes for women with CIN diagnosis and treatment compared with women with normal test results and for longitudinal comparisons of women before and after diagnosis and treatment.^147^

Evidence on potential harms of test positivity, diagnosis, and treatment are important to consider when evaluating the differences in detection rates of hrHPV screening strategies. Overall, the evidence from eight RCTs was consistent that hrHPV primary testing or cotesting will detect more CIN3+ in a single screening round compared to cytology. In most trials where these outcomes were reported, hrHPV primary testing or cotesting led to higher test positivity rates and higher FPRs. The evidence on these outcomes is strengthened by the studies’ high subject enrollment numbers and randomized design. Although not fully documented, it is likely that hrHPV testing led to higher rates of diagnostic testing and subsequent treatments.

## Limitations of the Evidence

### Limited Data on Cervical Cancer Incidence and Mortality

Important limitations of the evidence include lack of data on the primary outcome of cervical cancer mortality and limited data on cervical cancer incidence. Since cervical cancer is generally slow to develop and progress, and mortality from cervical cancer is a very rare outcome in countries with organized screening, the required size and duration of trials to study this outcome are impractical. A cluster RCT conducted in India did find a reduction in cervical cancer mortality after a single round of hrHPV testing compared with cytology, visual inspection with acetic acid, or a nonscreening control group.^148^ This trial was excluded from this review as it was not conducted in a highly developed country.

As cervical cancer screening has become more widespread, the proportion of adenocarcinoma of the cervix appears to have increased.^149,^ ^150^ Some have proposed that hrHPV testing may improve early detection of adenocarcinoma and its precursors,^150^ which is suggested by a lower RR for adenocarcinoma in the IPD meta-analysis,^130^ while others have suggested that cytology may be more effective.^151^ Due to the low incidence of cervical cancer in the included studies, it was not possible to evaluate any differences in detection of squamous cell versus adenocarcinoma of the cervix. The overall incidence of adenocarcinoma and its relative proportion among cervical cancers has increased concurrently with the advent of more widespread cervical cancer screening.^152^ Whether early detection of adenocarcinoma will be reduced by increased use of hrHPV testing for cervical cancer screening remains unclear.

### Screening Trial Heterogeneity

Heterogeneity of trial screening strategies and followup protocols prevented quantitative synthesis of the trial outcomes, including harms. In addition to screening strategies, followup protocols for abnormal results have important influence on rates of false-positive results and colposcopies. Comparative studies are needed of alternative followup protocols for abnormal screening results, which may influence the frequency of false-positive and false-negative results from screening.

Because evidence on comparative outcomes of screening strategies over more than two rounds of screening is lacking, conclusions based on the existing trial data do not provide insight into the effects of regular hrHPV testing as an ongoing screening strategy on outcomes in women screened at consistent intervals over many years. Whether one-time or intermittent hrHPV testing as a supplement to cytology screening could improve CIN3+ detection and reduce overall false-positive results and unnecessary followup testing is unknown. Additional data on extended followup from trials in which subjects returned to regular screening cytology at the end of the trial could help to inform this question.

### Limited Data on Screening Intervals

Evidence on the effects of screening at longer intervals (≥5 years) is limited to a single trial (POBASCAM). Only the FOCAL trial directly compared screening outcomes of hrHPV testing at different screening intervals (2 vs. 4 years), but final results of this trial have not been published. All other trials of primary testing or cotesting screened at 2- to 3-year intervals. CIN3+ rates in these trials were low (highest cumulative detection rate was 1.6%), with marked declines in detection in the second round of screening, supporting the clinical consensus on screening with hrHPV primary testing or cotesting no more frequently than every 3 to 5 years. A modeling study conducted for the USPSTF provides additional information on projected outcomes based on screening tests used, screening age range, and screening intervals.^153^

### hrHPV Test Types

All trials and cohort studies included in this review used either the HC2 hrHPV assay or the GP5+6/6+ PCR-EIA assay (not approved in the United States). HC2 is approved for cotesting but not primary testing in the United States, although all four RCTs evaluating primary hrHPV testing used HC2. Several currently FDA-approved hrHPV assays in the United States have not been evaluated in RCTs and have only partially met 2009 international expert clinical equivalency criteria, limiting the applicability of review findings to current clinical use of those assays.^61^

### Limited Data on Treatment Harms

Treatment of CIN diagnosed through screening may result in both benefits and harms, and screening strategies with higher test positivity rates may increase both. The included trials and cohort studies provided no data on subsequent treatment and any resultant harms. In the United States, there is clinical variation in the treatment of CIN2+ lesions, but excisional treatments are most common for CIN2 and CIN3, primarily with loop electrosurgical excision procedure (LEEP) to remove lesions and obtain biopsies during colposcopic examination. Harms of treatment include pain and bleeding, which rarely requires vaginal packing or transfusion,^154,^ ^155^ and harms related to subsequent pregnancies. Cold knife conization was common before LEEP became available and remains in practice to a lesser extent. This procedure has been most clearly associated with perinatal mortality, preterm birth, low birth weight, and higher Caesarean delivery rates.^156,^ ^157^ While LEEP treatment was not significantly associated with adverse pregnancy outcomes in one comprehensive systematic review, the possibility of an association was not ruled out.^158^ A recent Cochrane systematic review that included 15 studies (n=2,223,592) analyzed the effects of CIN treatment on fertility and early pregnancy outcomes. This review found significant associations between CIN treatment and later second-trimester miscarriage (RR, 2.60 [95% CI, 1.45 to 4.67]), ectopic pregnancy (RR, 1.89 [95% CI, 1.50 to 2.39]), and elective terminations (RR, 1.71 [95% CI, 1.31 to 2.22]). Notably, the authors of the review rated the evidence available to estimate these relationships as very low or low quality.^159^ Authors of another systematic review have suggested that women with a history of CIN have a greater risk of preterm birth regardless of treatment type.^160^

A recent population-based cohort study in Norway estimated rates of preterm birth and spontaneous abortion associated with prior excisional procedures for cervical lesions.^156^ In a cohort of women with at least one singleton birth between 1998 and 2014, (n=545,243; births=943,321), the majority of treatments were excisional (99%), in women younger than age 30 years (72%), and performed for grade CIN2 or CIN3 (95%). Preterm birth was more common among women who had treatment before childbirth (9.7%) compared with those without treatment (5.3%), with an adjusted hazard ratio (HR) of 1.8 (95% CI, 1.7 to 2.0). The HR for LEEP was 1.5 (95% CI, 1.3 to 1.7), and was higher for laser conization (HR, 2.3 [95% CI, 2.0 to 2.5]) and cold knife conization (HR, 2.6 [95% CI, 1.3 to 5.3]).

### Impact of Screening on Subpopulations

Finally, none of the trials or cohort studies included in this review provided outcomes for subgroups of women who had previously received the HPV vaccine. Applicability of these studies is limited for well-vaccinated populations of women who have only recently entered the age group for screening. Limited data from comparative registry studies of younger women (who had the opportunity for vaccination) suggest lower rates of CIN2+ in women previously vaccinated.^161,^ ^162^

## Limitations of the Review

This review was restricted by protocol to studies from highly developed countries (to increase applicability to the U.S. population) and to studies published in English. All of the RCTs included in this review were conducted in countries with robust, organized screening programs. Although screening history was not provided in any of the trials, it is likely that women enrolled in the trials were previously regularly screened with cytology. Organized screening programs are well suited for comparative trials of screening strategies; however, the generalizability of findings from this review to women in the United States is limited by the lack of organized screening programs for the majority of women in the United States. For women in the United States participating in organized screening programs, the findings of this review are applicable; however, more than 50 percent of women diagnosed with cervical cancer in the United States have not been screened in the prior 3 to 5 years. The higher detection of CIN3+ in an initial screening round with hrHPV testing may provide a more important benefit to women not able to participate in organized screening programs, since without such programs women may be less likely to return at regular intervals for screening. Mortality from cervical cancer in the United States is highest among black women and women of low socioeconomic status.^49,^ ^163^ Studies included in this review did not provide evidence on race/ethnicity or socioeconomic status of participants, so we were not able to examine any relevant subgroup effects other than those based on age.

## Future Research Needs

The performance of hrHPV testing alone or with cytology cotesting over multiple screening rounds is not clear. Research is needed to further define the use of hrHPV testing alone and as cotesting at longer screening intervals over several rounds of screening, and to evaluate the effectiveness of intermittent cotesting combined with regular cytology screening. A potential risk of hrHPV testing alone for cervical cancer screening is failure of early detection of HPV-negative cancers.^164^ Such cancers appear to be very rare, and a large observational study of women with negative hrHPV tests documented a lower risk of future cervical cancer compared to women who were cytology negative,^122^ but ongoing research on the outcomes of hrHPV primary screening in large populations over multiple screening rounds will further clarify this risk. Modeling will also be useful to project outcomes of hrHPV screening strategies at varying intervals over longer time frames. As new hrHPV tests become available, head-to-head comparisons with tests used in the large RCTs and cohort studies will be helpful for extrapolation of effectiveness. Additional research comparing alternative followup protocols is needed to define the followup protocols most effective for maximizing detection of high-grade abnormalities while minimizing harms from unnecessary testing. More recently recommended biomarkers, including p16 staining of cervical biopsies to clarify the level of CIN, deserve evaluation in population-based screening studies.^4^

Ongoing research has led to modifications in cervical cancer screening guidelines. These shifts in recommendations may lead to confusion among both women and clinicians, resulting in potential harms from overuse of screening and diagnostic tests, or harms from failure to recognize and follow up important abnormal findings. Studies are needed to define optimal strategies for dissemination and implementation of guideline modifications.

We found very limited evidence on how vaccination against specific hrHPV types is affecting outcomes of screening with hrHPV primary testing or cotesting in age groups recommended for screening. As HPV vaccination coverage increases, it is unknown whether shifts in hrHPV type prevalence will occur over time. Studies to date have not supported substitution of nonvaccine hrHPV types,^165^ and newer vaccines cover additional hrHPV types. An overall reduction in hrHPV prevalence would affect the positive predictive value of hrHPV testing. Ongoing studies of hrHPV prevalence and outcomes of screening in vaccinated populations are needed. If vaccination results in an overall lower incidence of cervical cancer precursors and incidence, studies will be needed of screening strategies that have been modified to maintain screening efficiency and reduce harms from investigation of false-positive results. Final results of the Compass trial,^104^ which includes younger women drawn from a population with relative high vaccination rates, will be helpful in addressing these questions.

Because of the predominance of cervical cancer among underscreened women, any substantial impact on cervical cancer incidence and mortality requires the identification of effective strategies to reach poorly screened and unscreened women in the United States. Very limited evidence from a single cohort study of poorly screened women in Spain suggests that the increased sensitivity of hrHPV testing may offer particular advantages in this population. Rigorous comparative studies are needed to evaluate both the impact of hrHPV testing in this population and to identify and disseminate effective strategies to increase screening coverage and followup of abnormal results. Such strategies could include population-based screening programs with registries, outreach programs, low- or no-cost access to screening and followup evaluation, and options for self-collected samples.

There is evidence that hrHPV testing via self-collection may be an acceptable and important strategy to reach underscreened and unscreened populations.^166–168^ A number of ongoing studies of hrHPV self-sampling were identified in ClinicalTrials.gov (Appendix E). A 2014 meta-analysis of 36 studies comparing the accuracy of hrHPV testing via self-collected samples to clinician-collected samples suggested slightly lower sensitivity and specificity for self-collection regardless of threshold (CIN2+ or CIN3+) (compared to clinician-collected samples, sensitivity was 0.88 [95% CI, 0.85 to 0.91] for CIN2+ and 0.89 [95% CI, 0.83 to 0.96] for CIN3+; specificity was 0.96 [95% CI, 0.95 to 0.97] for CIN2+ and 0.96 [95% CI, 0.93 to 0.99] for CIN3+).^169^ The implications of slightly lower test performance, particularly for sensitivity, might be different for a self-collection option among underscreened women.

Several systematic reviews summarize evidence on the effects of self-collection on screening participation. Most trials to date have been conducted in European countries, and usually randomize women with persistent missed screening to a control condition, such as a mailed reminder letter or telephone call, or the intervention (a mailed self-collection kit). Self-collection kits in these settings are consistently associated with higher screening rates. A 2013 systematic review of 10 trials examined the use of hrHPV self-testing on cervical cancer screening participation compared to a clinician letter. The overall RR of participation in screening using self-testing was 2.14 (95% CI, 1.30 to 3.52), with substantial heterogeneity observed between the studies (I^2^=99.5%); reported use of hrHPV self-testing ranged from 10.2 to 98.2 percent among those invited to hrHPV self-test.^167^ Similar significant beneficial effects on screening compliance have been observed in trials published since the 2013 review.^170–178^

One trial (n=601) of self-sampling to increase screening has been completed in the United States. The trial focused on low-income, uninsured Latina immigrants and Haitian women, and had three study arms. Culturally-tailored health education materials were compared to a community health navigator or to a third intervention where the community health worker also offered a self-collection option. Rates of screening were highest when self-collection was offered, and the involvement of community health workers strengthened linkages to followup of abnormal self-collection screening results (>90%). At 6-month followup, the proportion of women presenting for screening significantly differed across the groups: 29 percent in the health education materials group, 38 percent in the health navigation only group, and 73 percent in the health navigation with self-collection option. Studies are needed to examine the effect of self-collection on overall screening rates and on adherence to followup of abnormal screening results among underscreened women.

## Conclusions

Four RCTs offer consistent evidence that primary hrHPV testing will detect higher rates of CIN3+ at an initial screening round. Two of four RCTs of cotesting also found higher CIN3+ detection. This higher detection is accompanied by increased false-positive results and higher colposcopy rates. These higher rates of colposcopy are likely to lead to more treatments, which are associated with harms. Over two rounds of screening with hrHPV cotesting, most trials show similar rates of CIN3+ detection between strategies. Whether additional rounds of screening would result in a subsequent decline of CIN3+ with primary hrHPV testing strategies is unclear, since only one trial has reported on more than two rounds of screening. In most trials and a large U.S.-based observational study, women younger than ages 30 to 35 years had higher rates of hrHPV positivity and CIN3+, accompanied by higher rates of colposcopy. No completed studies compared screening intervals. An IPD meta-analysis suggested a lower rate of ICC with hrHPV screening strategies, but this analysis pooled data from trials with distinctly different screening strategies and hrHPV test types, which contributed uncertainty to interpretation of the findings. All of the evidence from RCTs on primary hrHPV testing and cotesting is from countries with organized screening programs, which are not available to most women in the United States. Rigorous comparative research is needed in U.S.-based screening settings to examine longer-term outcomes and screening intervals, and to identify effective strategies for outreach, screening, and followup of poorly screened and unscreened women. The higher sensitivity of hrHPV testing in a single round of screening may have particular potential to improve outcomes in this high-risk population.