# Chapter 3 Results

## Literature Search

We screened 2,972 abstracts and 164 full-text articles for inclusion (Appendix A Figure 1). We included 13 studies^104,^ ^116–126^ that reported results in 33 publications (Appendix D). Five studies were included for the effectiveness of hrHPV primary screening strategy,^104,^ ^119,^ ^124,^ ^125,^ ^127–130^ seven studies were included for screening with cotesting,^116,^ ^118–120,^ ^131–138^ and an IPD meta-analysis that pooled results from studies of both primary hrHPV screening and cotesting (KQ1) and 13 studies^116–126^ of harms (KQ2) were included.^139^

## KQ1 What Is the Effectiveness of hrHPV Testing, With or Without Cytology, as a Primary Screening Strategy for Reducing Cervical Cancer Mortality and Incidence Compared With Currently Recommended Screening Strategies for Women in the United States?

### Summary of Results

The primary outcome of KQ1 was cervical cancer mortality, but this is a rare outcome in countries with organized cervical cancer screening programs. Although large numbers of women were recruited, none of the seven included trials reported on or were powered to assess mortality. Trials were heterogeneous with regard to type of cytology (conventional vs. LBC), type of hrHPV test (PCR vs. HC2), screening interval (2 to 5 years), followup protocols for abnormal results, number of screening rounds, and protocols for screening beyond the first screening round. No trials directly compared primary hrHPV testing with hrHPV cotesting; in all cases, comparisons were made to cytology screening. Trials reported outcomes after one or two rounds comparing alternative screening strategies.

The evidence was generally consistent across trials with variable protocols and hrHPV test types in demonstrating that primary hrHPV testing increased detection of CIN3+ in the initial round of screening (RR range, 1.61 [95% CI, 1.09 to 2.37]^125,^ ^128–130^ to 7.46 [95% CI, 1.02 to 54.66]).^104^ Only the NTCC Phase II trial of primary hrHPV testing, where all women with a positive hrHPV test were referred to colposcopy, had complete results from two rounds of screening (at Round 2 screening all women received cytology testing).^119,^ ^127^ In that study, CIN3+ detection in Round 1 was 3-fold higher in the hrHPV testing arm, and cumulative detection was 1.8-fold higher after the second round of screening. Results of a large, single-arm, fair-quality cohort study of primary hrHPV testing at 3-year intervals were consistent with trial findings. CIN3+ detection in the second screening round was significantly lower: the RR for CIN3+ detection at Round 2 compared to Round 1 was 0.14 (95% CI, 0.06 to 0.32).

None of the cotesting trials demonstrated significantly higher detection of CIN3+ in the first round of screening, with the RR ranging from 1.04 to 1.31. By the second round of screening 3 to 5 years later, in two trials, CIN3+ detection in the second round of screening was significantly lower, with RRs ranging from 0.53^118,^ ^135^ to 0.73.^120,^ ^133,^ ^134^

The large, single-group cohort studies of cotesting were consistent with the pattern of higher detection of CIN3+ in the first screening round relative to a followup round.^122,^ ^126,^ ^140^ Without a comparison group, it is unknown how these cohort study findings would compare to screening with cytology alone.

Findings of the IPD meta-analysis suggested lower incidence of ICC in the hrHPV testing arms beyond the first 2.5 years from the initial screening round.^139^ While this finding is encouraging, it was based on pooling studies of both primary hrHPV testing and cotesting, using different test protocols and screening intervals with a cumulative total of only 107 ICC cases. Because no trial sustained the intervention and control group protocols beyond two screening rounds, evidence comparing the long-term outcomes of hrHPV primary testing or cotesting with cytology only is lacking. The evidence was not sufficient to draw conclusions about the outcomes of strategies including hrHPV testing compared with strategies involving cytology repeated multiple times at regular intervals over the recommended screening age range.

Evidence on subpopulation outcomes from the RCTs and cohort studies described above focused on outcomes by age group. Studies reported variable age groups, with break points at age 25 years, 29 to 30 years, or 34 to 35 years. Women younger than age 35 years had consistently higher rates of hrHPV positivity and of CIN3+. Outcome differences between screening strategies by age group were not notably different from the results in the study populations overall. No included studies reported on outcomes by race/ethnicity, hrHPV immunization status, or socioeconomic status. Neither trials nor the Kaiser Permanente Northern California (KPNC) cohort study reported on outcomes related to screening history, and all but one included study were based in organized screening programs, suggesting that most subjects were offered regular screening prior to study participation. For underscreened women, a single cohort study of cotesting from Spain of women not screened in the previous 5 years, overall CIN3+ was detected in 0.5 percent of women (nine women), but loss to followup was nearly 50 percent.^121^ Three women with CIN3 were detected only through hrHPV testing.

Data from trials were not adequate to compare outcomes of different rescreening intervals, due to lack of direct comparisons of intervals or consistent application of initial screening strategies for more than one screening round. Similarly, no data were available to address rescreening intervals by subpopulation.

### Study Characteristics

We identified eight RCTs that used hrHPV testing as part of cervical cancer screening (Table 5); four trials^104,^ ^119,^ ^124,^ ^129^ evaluated primary hrHPV testing and four trials^116,^ ^118–120^ evaluated cotesting with cytology. Additionally, we included four cohort studies (one of primary screening and three of cotesting) and an IPD meta-analysis of five screening trials. Additional details on baseline population characteristics and screening protocols are described in detail in Appendix F Tables 1–3.

Table 5 Study Design Characteristics of Included Trials, Ordered by Screening Approach

Author, Year Quality | Country | N Rand | Inclusion Criteria | Exclusion Criteria | Recruitment | Follow up (years) | HPV Screening Strategy | # of Rounds (Interval)
Ronco, 2010^120,^ ^129^ NTCC Phase II Good | Italy | 49,196 | Women ages 25–60 years attending a new routine cervical cancer screening episode | Pregnant, had undergone a hysterectomy, been treated for CIN in the last 5 years | Population-based screening March 2002 to December 2004, two recruitment phases as part of nine population-based cervical cancer screening programs | 7 (max) | HPV alone Hybrid Capture 2 (Digene) | 2 (3 years)
Ogilivie, 2017^126,^ ^130–132^ HPV FOCAL Fair | Canada | 25,223 | Women ages 25–65 years, registered with Medical Services Plan in British Columbia, who receive care from a participating family physician for routine cervical screening | History of histologically confirmed proven CIN2+ requiring treatment in the last 5 years, history of histologically proven invasive cervical cancer, a Pap smear within the preceding 12 months, no cervix, pregnant at the time of enrollment, HIV positive or on immunosuppressive treatments | Population-based screening January 2008 to January 2011; women invited to participate when they present for cervical cancer screening and deemed eligible by family physician or preidentified as being due for screening from the centralized provincial cytology database (invitation requests woman schedule a cervical cancer screening appointment) | 4 (max) | HPV w/LBC triage Hybrid Capture 2 (Digene) and ThinPrep PreservCyt (Hologic Inc) | 1 (2–4 years) 2 (2 year “safety round”, 4 years)^*^
Leinonen, 2012^125^ FINNISH Fair | Finland | 203,425 | Women ages 25–65 years invited for cervical cancer screening between 2003 and 2007 drawn from the Population Information System by birth year | NR | Population-based screening Women invited for screening between 2003 and 2007 from the Population Information System by personal letter; from eight municipalities | 5 (max) | HPV w/CC triage Hybrid Capture 2 (Digene) and CC | 1 (5 years)
Canfell, 2017^128^ Compass Fair | Australia | 4,995 | Women ages 25–64 years attending routine cervical cancer screening or followup of a prior unsatisfactory smear for routine screening | Previous total hysterectomy, presence of symptoms for which cervical cancer is excluded, currently undergoing treatment for cervical precancer or cancer, attending followup of a previously-identified cervical abnormality, pregnancy | Population-based screening Women recruited from 47 primary health care practices across Victoria, Australia when presenting for routine screening in line with national screening program recommendations. This pilot recruitment is part 1 of a two-phase recruitment process. | 5 (max) | HPV w/LBC triage | 1 (5 years) 1 (2.5 year screening with CC)
Ronco, 2010^120,^ ^133,^ ^134^ NTCC Phase I Good | Italy | 45,174 | Women ages 25–60 years attending a new routine cervical cancer screening episode | Pregnant, had undergone a hysterectomy, been treated for CIN in the last 5 years | Population-based screening March 2002 to December 2004, two recruitment phases as part of nine population-based cervical cancer screening programs | 7 (max) | HPV cotesting Hybrid Capture 2 (Digene) and ThinPrep PreservCyt (Hologic Inc) | 2 (3 years)
Naucler, 2007^119,^ ^137^ SWEDESCREEN Fair | Sweden | 12,527 | Women ages 32–38 years who participated in the screening program from May 1997 through November 2000 in five cities | Women who are recorded in cytologic test registries as having had a recent Pap smear outside the screening program were not invited to participate in the screening program | Population-based screening Screening program recruited women ages 23–50 years to undergo cervical cancer screening at 3-year intervals and women ages 51–60 years to be screened at 5-year intervals; women chosen from the population registry, which lists all women in Sweden | 4.1 | HPV cotesting PCR/GP5+/6+ and CC | 1 (3 years)^†^
Kitchener, 2009^117,^ ^138–140^ ARTISTIC Fair | United Kingdom | 25,078 | Women ages 20–64 years undergoing routine cervical cancer screening in the NHS program in Greater Manchester | NR | Population-based screening Invitations to attend routine screening contained trial information leaflet; enrolled between July 2001 and September 2003 | 4.5 (max) | HPV cotesting Hybrid Capture 2 (Digene) and ThinPrep T3000 (Hologic Inc) | 2 (3 years)
Rijkaart, 2012^121,^ ^135,^ ^136^ POBASCAM Good | Netherlands | 44,938 | Women ages 30–60 years invited every 5 years to population-based screening program; eligible if they lived in a defined semiurbanized region demarcated according to the District Health Authority SW of Amsterdam, having a uterus in situ | Women who had a history of CIN2+, had abnormal cytology in the preceding 2 years, or who had had a hysterectomy; women age 57 years or older at baseline (not be routinely screened at second round); if HPV sample taken at baseline was lost | Population-based screening Enrolled between January 1999 and September 2002 as part of a nationwide screening program; women invited to screening every 5 years starting at age 30 and ending at age 60. Invited by GP or directly by District Health Authority (if no GP) | 9 (max) | HPV cotesting PCR/GP5+/6+ and CC | 2 (5 years)

* Results are preliminary; publication of 2nd round results are pending

† Registry followup in an organized screening program

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; btwn = between; CIN = cervical intraepithelial neoplasia; GP = general practitioner; HIV = human immunodeficiency virus; NHS = National Health Service; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening; POBASCAM = Population Based Screening Study Amsterdam Program; SW = southwest; w/ = with

Since each trial had a distinct screening protocol, with different hrHPV and cytology test types, intervals, and followup protocols, we did not pool study outcomes with meta-analysis. We focused primarily on detection of CIN3+ as the outcome of interest; all included studies reported this outcome. Although reducing cervical cancer morbidity and mortality is the target of cervical cancer screening, ICC is a rare outcome in countries where most women are regularly screened for cervical cancer by any method. Although reported separately in some studies, these outcomes were too rare for meaningful comparisons. Cervical cancer mortality is even less frequent and was not reported in any trial. CIN3+ includes all ICC and in situ precancerous changes with a high-risk of progression to invasive cancer over time.

Three of the included trials were rated good quality (NTCC Phase I and Phase II, POBASCAM) and the other five were rated fair quality. Problems with blinding of outcome assessors, adherence to study protocols, and maintenance of the randomization scheme over multiple rounds of screening contributed to risk of bias in this evidence base. Attrition and changes to the screening protocol over time limited the extent to which results from later rounds of screening could inform the KQs of this review.

#### Screening With Primary hrHPV Testing

##### RCTs

Ronco and colleagues compared primary hrHPV with HC2 to conventional cytology in the good-quality NTCC Phase II trial (Tables 6–8).^119,^ ^127^ This trial, conducted in Italy, randomized 49,196 women ages 25 to 60 years invited for routine screening to either hrHPV testing with HC2 or conventional cytology. Subjects were followed for a maximum of 7 years over two rounds of screening at 3-year intervals. The second round of screening for both intervention and control groups used cytology only. Women in the intervention group were referred to colposcopy for any positive hrHPV test. Women with CIN2+ were treated, while women with CIN1 were followed with repeat colposcopy according to standard protocols, and received annual hrHPV and cytology testing. Abnormal cytology results were managed according to standard center protocols.

Table 6 Results for Trials of hrHPV Primary Screening Strategies, All Participants

Parameter | Round | NTCC Phase II^120,^ ^129^ | HPV FOCAL^¶^,^126,^ ^130–132^ | FINNISH^125^ | Compass^128^
Quality | -- | Good | Fair | Fair | Fair
N Randomized | -- | 49,196 | 25,223 | 203,425 | 4,995
Ages Recruited | -- | 25–60 years | 25–65 years | 25–65 years | 25–64 years
# of Rounds (Interval) | -- | 2 (3 years) | 1 (2–4 years)^§^ | 1 (5 years) | 1 (5 years)
Screening Approach (IG vs. CG) | 1 | hrHPV alone vs. CC | hrHPV w/LBC triage vs. LBC w/hrHPV triage | hrHPV w/CC triage vs. CC | HPV w/LBC triage vs. LBC
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | LBC w/hrHPV triage vs. LBC w/hrHPV triage (both arms received same testing strategy) | -- | --
Followup | 1 | 3.5 years (maximum) | 2–4 years (maximum)^§^ | 5 years (maximum) registry followup | 5 years (maximum)
Followup | 2 | 3.5 years (maximum) | 2 years (maximum)^§^ | -- | --
Followup | C | 7 years (maximum) | 4 years (maximum) | -- | --
Test Positivity | 1 | IG (hrHPV+): 1,936/24,661 (7.9%) CG (ASC-US+): 825/24,353 (3.4%) | IG (hrHPV+): 1,290/15,744 (8.2%) CG (ASC-US+): 334/9,408 (3.6%) | IG (hrHPV+): 4,971/62,106 (8.0%)^*^ CG (ASC-US+): 4,506/65,747 (6.9%)^*^ | IG (hrHPV+): 277/4000 (6.9%) CG (ASC-US+): 67/995 (6.7%)
Test Positivity | 2 | NR | -- | -- | --
Colposcopy Referrals | 1 | IG: 1,936/24,661 (7.9%) CG: 679/25,435 (2.8%) | IG: 5.9% (95% CI, 5.5 to 6.3)^‖^ CG: 3.1% (95% CI, 2.8 to 3.5)^‖^ | IG: 796/66,410 (1.2%) CG: 755/65,784 (1.1%) | IG: 154/4000 (3.8%) CG: 27/995 (2.7%)
Colposcopy Referrals | 2 | NR | -- | -- | --
False-Positive Rate for CIN2+ | 1 | IG: 1,799/24,428 (7.4%) CG: 770/24,038 (3.2%) | NR | IG: 4,462/61,597 (7.2%) CG: 4,239/65,480 (6.5%) | NR
False-Positive Rate for CIN2+ | 2 | NR | -- | -- | --
Absolute Detection for CIN3+ | 1 | IG: 97/24,661 (0.4%)^*^ CG: 33/24,535 (0.1%)^*^ | IG: 67/9,540 (0.7%) CG: 41/9,408 (0.4%) | IG: 195/66,410 (0.3%) CG: 118/65,784 (0.2%) | IG: 30/4,000 (0.8%) CG: 1/995 (0.1%)
Absolute Detection for CIN3+ | 2 | IG: 5/23,978 (0.02%)^*^ CG: 23/24,372 (0.09%)^*^ | -- | -- | --
Absolute Detection for CIN3+ | C | IG: 102/24,661 (0.4%)^*^ CG: 56/24,535 (0.2%)^*^ | -- | -- | --
Relative Risk for CIN3+ | 1 | 2.92 (95% CI, 1.97 to 4.34)^†^ | 1.61 (95% CI, 1.09 to 2.37) | 1.64 (95% CI, 1.30 to 2.06)^†^ | 7.46 (95% CI, 1.02 to 54.66)
Relative Risk for CIN3+ | 2 | 0.22 (95% CI, 0.08 to 0.58)^†^ | -- | -- | --
Relative Risk for CIN3+ | C | 1.81 (95% CI, 1.31 to 2.51)^†^ | -- | -- | --
Absolute Detection for CIN2+ | 1 | IG: 218/24,661 (0.8%)^*^ CG: 73/24,535 (0.3%)^*^ | IG: 147/9,540 (1.5%) CG: 90/9,408 (1.0%) | IG: 540/66,410 (0.8%) CG: 319/65,784 (0.5%) | IG: 44/4,000 (1.1%) CG:1/995 (0.1%)
Absolute Detection for CIN2+ | 2 | IG: 12/23,978 (0.05%)^*^ CG: 38/24,372 (0.2%)^*^ | -- | -- | --
Absolute Detection for CIN2+ | C | IG: 230/24,661 (0.9%)^*^ CG: 111/24,535 (0.5%)^*^ | -- | -- | --
Relative Risk for CIN2+ | 1 | 2.97 (95% CI, 2.28 to 3.87)^†^ | 1.63 (95% CI, NR)^†^ | 1.68 (95% CI, 1.46 to 1.92)^†^ | 10.94 (95% CI, 1.51 to 79.34)
Relative Risk for CIN2+ | 2 | 0.32 (95% CI, 0.17 to 0.61)^†^ | -- | -- | --
Relative Risk for CIN2+ | C | 2.06 (95% CI, 1.64 to 2.58)^†^ | -- | -- | --
Invasive Cervical Cancer | 1 | NR | NR | IG: 17/66,410 (0.03%) CG: 9/65,784 (0.01%) | IG: 0/4,000 (0%) CG: 0/995 (0%)
Invasive Cervical Cancer | 2 | NR | -- | -- | --
Invasive Cervical Cancer | C | NR | -- | -- | --

* From author inquiry

† Calculated (unadjusted)

§ HPV FOCAL had two randomized hrHPV arms: safety arm (screening every 2 years) and intervention arm (screening every 4 years); control arm screened every 2 years

‖ Percent of women; converted from rate per 1,000 participants

¶ Results are preliminary; publication of 2nd round results are pending

Abbreviations: C = cumulative; CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV = high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening

Table 7 Results for Trials of hrHPV Primary Screening Strategies, Women Age ≥35 Years Screening

Parameter | Round | NTCC Phase II^120,^ ^129^ | HPV FOCAL^¶^,^126,^ ^130–132^ | FINNISH^125^ | Compass^128^
Quality | -- | Good | Fair | Fair | Fair
N Randomized | -- | 35,471 | 20,394 | 109,932 | 3,917
Ages Recruited | -- | 35–60 years | 35–65 years | 35–65 years | 34–64 years
# of Rounds (Interval) | -- | 2 (3 years) | 1 (2–4 years)^§^ | 1 (5 years) | 1 (5 years)
Screening Approach (IG vs. CG) | 1 | hrHPV alone vs. CC | hrHPV w/LBC triage vs. LBC w/hrHPV triage | hrHPV w/CC triage vs. CC | HPV w/LBC triage vs. LBC^**^
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | LBC w/hrHPV triage vs. LBC w/hrHPV triage (both arms received same testing strategy) | -- | --
Followup | 1 | 3.5 years (maximum) | 2–4 years (maximum)^§^ | 5 years (maximum) registry followup | 5 years (maximum)
Followup | 2 | 3.5 years (maximum) | 2 years (maximum)^§^ | -- | --
Followup | C | 7 years (maximum) | 4 years (maximum) | -- | --
Test Positivity | 1 | IG (hrHPV+): 1,029/17,724 (5.8%) CG (ASC-US+): 555/17,747 (3.1%) | NR | NR | NR
Test Positivity | 2 | NR | -- | -- | --
Colposcopy Referrals | 1 | IG: 1,029/17,724 (5.8%) CG: 435/17,747 (2.5%) | IG: 3.8 (95% CI, 3.5 to 4.2)^‖^ CG: 2.1 (95% CI, 1.8 to 2.4)^‖^ | IG: 506/55,219 (0.9%) CG: 544/54,713 (1.0%) | IG: 80/3133 (2.6%) CG: 17/784 (2.2%)
Colposcopy Referrals | 2 | NR | -- | -- | --
False-Positive Rate for CIN2+ | 1 | IG: 960/17,655 (5.4%) CG: 519/17,711 (2.9%) | NR | NR | NR
False-Positive Rate for CIN2+ | 2 | NR | -- | -- | --
Absolute Detection for CIN3+ | 1 | IG: 52/17,724 (0.3%)^*^ CG: 22/17,747 (0.1%)^*^ | IG: 47/8,714 (0.5%) CG: 27/8,580 (0.3%) | IG: 132/55,219 (0.2%) CG: 84/54,713 (0.2%) | IG: 12/3133 (0.4%) CG: 0/784 (0%)
Absolute Detection for CIN3+ | 2 | IG: 3/17,401 (0.02%)^*^ CG: 13/17,658 (0.07%)^*^ | -- | -- | --
Absolute Detection for CIN3+ | C | IG: 55/17,724 (0.3%)^*^ CG: 35/17,747 (0.2%)^*^ | -- | -- | --
Relative Risk for CIN3+ | 1 | 2.37 (95% CI, 1.44 to 3.89)^*^ | 1.71 (95% CI, 1.07 to 2.75)^†^ | 1.56 (95% CI, 1.18 to 2.04)^†^ | 6.26 (95% CI, 0.37 to 105.6)
Relative Risk for CIN3+ | 2 | 0.23 (95% CI, 0.07 to 0.82)^*^ | -- | -- | --
Relative Risk for CIN3+ | C | 1.57 (95% CI, 1.03 to 2.40)^*^ | -- | -- | --
Absolute Detection for CIN2+ | 1 | IG: 102/17,724 (0.6%)^*^ CG: 48/17,747 (0.3%)^*^ | IG: 102/8,714 (1.2%) CG: 64/8,580 (0.8%) | IG: 322/55,219 (0.6%) CG: 200/54,713 (0.4%) | IG: 20/3133 (0.6%) CG: 0/784 (0%)
Absolute Detection for CIN2+ | 2 | IG: 5/17,401 (0.03%)^*^ CG: 20/17,658 (0.1%)^*^ | -- | -- | --
Absolute Detection for CIN2+ | C | IG: 107/17,724 (0.6%)^*^ CG: 68/17,747 (0.4%)^*^ | -- | -- | --
Relative Risk for CIN2+ | 1 | 2.13 (95% CI, 1.51 to 3.00)^*^ | 1.57 (95% CI, 1.15 to 2.14)^†^ | 1.59 (95% CI, 1.34 to 1.90)^†^ | 10.27 (95% CI, 0.62 to 169.61)
Relative Risk for CIN2+ | 2 | 0.25 (95% CI, 0.10 to 0.68)^*^ | -- | -- | --
Relative Risk for CIN2+ | C | 1.58 (95% CI, 1.16 to 2.13)^*^ | -- | -- | --
Invasive Cervical Cancer | 1 | NR | NR | IG: 16/55,219 (0.03%) CG: 7/54,713 (0.01%) | NR
Invasive Cervical Cancer | 2 | NR | -- | -- | --
Invasive Cervical Cancer | C | NR | -- | -- | --

* From author inquiry

† Calculated (unadjusted)

§ HPV FOCAL had two randomized hrHPV arms: safety arm (screening every 2 years) and intervention arm (screening every 4 years); control arm screened every 2 years. Results above are from the safety and control arms.

‖ Percent of women; converted from rate per 1,000 participants

¶ Results are preliminary; publication of 2^nd^ round results are pending

** Triage could be done via LBC or dual-stained cytology

Abbreviations: CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV = high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening

Table 8 Results for Trials of hrHPV Primary Screening Strategies, Women Aged <35 Years

Parameter | Round | NTCC Phase II^120,^ ^129^ | HPV FOCAL^¶^,^126,^ ^130–132^ | FINNISH^125^ | Compass^128^
Quality | -- | Good | Fair | Fair | Fair
N Randomized | -- | 13,725 | 4,849 25–29 years: 2,188 30–34 years: 2,661 | 22,262 | 1,078
Ages Recruited | -- | 25–34 years | 25–34 years | 25–34 years | 25–33 years
# of Rounds (Interval) | -- | 2 (3 years) | 1 (2–4 years)^§^ | 1 (5 years) | 1 (5 years)
Screening Approach (IG vs. CG) | 1 | hrHPV alone vs. CC | hrHPV w/LBC triage vs. LBC w/hrHPV triage | hrHPV w/CC triage vs. CC | HPV w/LBC triage vs. LBC^**^
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | LBC w/hrHPV triage vs. LBC w/hrHPV triage (both arms received same testing strategy) | -- | --
Followup | 1 | 3.5 years (maximum) | 2–4 years (maximum)^§^ | 5 years (maximum) registry followup | 5 years (maximum)
Followup | 2 | 3.5 years (maximum) | 2 years (maximum)^§^ | -- | --
Followup | C | 7 years (maximum) | 4 years (maximum) | -- | --
Test Positivity | 1 | IG (hrHPV+): 907/6,937 (13.1%) CG (ASC-US+): 270/6,788 (4.0%) | NR | NR | NR
Test Positivity | 2 | NR | -- | -- | --
Colposcopy Referrals | 1 | IG: 970/6,937 (13.1%) CG: 244/6,788 (3.6%) | 25–29 years: IG: 19.9 (95% CI, 17.9 to 22.1)^‖^ CG: 8.1 (95% CI, 6.4 to 10.2)^‖^ 30–34 years: IG: 10.8 (95% CI, 9.3 to 12.4)^‖^ CG: 6.2 (95% CI, 4.9 to 7.9)^‖^ | IG: 290/11,191 (2.3%) CG: 211/11,071 (1.9%) | IG: 76/867 (8.5%) CG: 10/211 (4.7%)
Colposcopy Referrals | 2 | NR | -- | -- | --
False-Positive Rate for CIN2+ | 1 | IG: 839/6,869 (12.2%) CG: 251/6,769 (3.7%) | NR | NR | NR
False-Positive Rate for CIN2+ | 2 | NR | -- | -- | --
Absolute Detection for CIN3+ | 1 | IG: 45/6,937 (0.6%)^*^ CG: 11/6,788 (0.2%)^*^ | IG: 20/826 (2.4%) CG: 14/828 (1.7%) | IG: 63/11,191 (0.6%) CG: 34/11,071 (0.3%) | IG: 18/867 (2.1%) CG: 1/211 (0.5%)
Absolute Detection for CIN3+ | 2 | IG: 2/6,577 (0.03%)^*^ CG: 10/6,714 (0.15%)^*^ | -- | -- | --
Absolute Detection for CIN3+ | C | IG: 47/6,937 (0.7%)^*^ CG: 21/6,788 (0.3%)^*^ | -- | -- | --
Relative Risk for CIN3+ | 1 | 4.00 (95% CI, 2.07 to 7.73)^*^ | 1.43 (95% CI, 0.73 to 2.82)^†^ | 1.83 (95% CI, 1.21 to 2.78)^†^ | 4.38 (95% CI, 0.59 to 32.6)
Relative Risk for CIN3+ | 2 | 0.20 (95% CI, 0.05 to 0.93)^*^ | -- | -- | --
Relative Risk for CIN3+ | C | 2.19 (95% CI, 1.31 to 3.66)^*^ | -- | -- | --
Absolute Detection for CIN2+ | 1 | IG: 116/6,937 (1.7%)^*^ CG: 25/6,788 (0.4%)^*^ | IG: 45/826 (5.5%) CG: 26/828 (3.1%) | IG: 218/11,191 (1.9%) CG: 119/11,071 (1.1%) | IG: 24/867 (2.8%) CG: 1/211 (0.5%)
Absolute Detection for CIN2+ | 2 | IG: 7/6,577 (0.1%)^*^ CG: 18/6,714 (0.3%)^*^ | -- | -- | --
Absolute Detection for CIN2+ | C | IG: 123/6,937 (1.8%)^*^ CG: 43/6,788 (0.6%)^*^ | -- | -- | --
Relative Risk for CIN2+ | 1 | 4.54 (95% CI, 2.95 to 6.99)^*^ | 1.73 (95% CI, 1.08 to 2.78)^†^ | 1.81 (95% CI, 1.45 to 2.26)^†^ | 5.84 (95% CI, 0.79 to 42.93)
Relative Risk for CIN2+ | 2 | 0.40 (95% CI, 0.17 to 0.95)^*^ | -- | -- | --
Relative Risk for CIN2+ | C | 2.80 (95% CI, 1.98 to 3.95)^*^ | -- | -- | --
Invasive Cervical Cancer | 1 | NR | NR | IG: 1/11,191 (0.01%) CG: 2/11,071 (0.02%) | NR
Invasive Cervical Cancer | 2 | NR | -- | -- | --
Invasive Cervical Cancer | C | NR | -- | -- | --

* From author inquiry

† Calculated (unadjusted)

‖ Percent of women; converted from rate per 1,000 participants

§ HPV FOCAL had two randomized hrHPV arms: safety arm (screening every 2 years) and intervention arm (screening every 4 years); control arm screened every 2 years. Results shown above are safety arm and control arm.

¶ Results are preliminary; publication of 2^nd^ round results are pending

** Triage could be done via LBC or dual-stained cytology

Abbreviations: CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV =high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NSD = no significant difference; NTCC = New Technologies for Cervical Cancer Screening

The fair-quality HPV FOCAL trial, conducted in Canada, evaluated HC2 hrHPV testing with LBC triage.^125,^ ^128,^ ^129^ This trial randomized 25,223 women ages 25 to 65 years who were eligible for routine screening determined by the centralized British Columbia cytology database. Women were randomized to three arms: a control group of 9,457 women screened with LBC every 2 years with cotesting at the 4-year exit screen, an intervention group of 9,552 women screened with hrHPV testing (HC2) at entry and with cotesting 4 years later, and a safety arm of 6,214 women screened with primary hrHPV testing at entry and screened 2 years later with LBC. In the intervention arm, women who had hrHPV positive results then had LBC done on the specimen and if cytology was abnormal they were referred for colposcopy. Women with normal cytology had repeat testing at 12 months. The control group received LBC followup according to standard protocols, including triage of ASC-US cytology results with hrHPV testing. At two years the safety arm received followup according to the same protocols.

In the fair-quality FINNISH trial, Leinonen and colleagues randomized women in Finland ages 25 to 65 years invited to participate in population-based cervical cancer screening between 2003 and 2007 for a single round of primary HC2 hrHPV testing compared with conventional cytology.^7^ Followup for a positive hrHPV screening test was with cytology. A total of 203,425 women were invited for screening, and of these about 65 percent attended screening in each arm: 66,410 women in the hrHPV arm and 65,785 women in the cytology group. Women with abnormal cytology other than ASC-US were referred for colposcopy in both arms. Women with ASC-US and women with hrHPV+ test results were followed with rescreening at 12 to 24 months. After the single round of randomized screening, followup through population based registries (Mass Screening Registry, Finnish Cancer Registry) continued for a maximum of 5 years and ended in December 2008.

The fair-quality Australian Compass trial has reported preliminary results in an RCT in which 4,995 women ages 25 to 64 years were randomized to LBC every 2.5 years or hrHPV primary screening with either HC2 or Cobas 4800 every 5 years.^104^ Women in the LBC screening arm with results showing HSIL and those with ASC-US/LSIL positive for hrHPV 16-18 were referred to colposcopy. Women in the primary hrHPV screening arms were referred to colposcopy for hrHPV 16-18, and the rest were triaged with either LBC or p16/K67 testing in a secondary randomization. Twenty two percent of enrolled women were younger than age 33 years, an age group that would have been offered hrHPV vaccination in Australia. Investigators estimated that 70 percent would be vaccinated in that age group, based on population uptake. Recruitment and followup in the trial are ongoing.

##### Cohort Studies

A large, single-arm fair-quality cohort study conducted in two population-based cervical cancer screening programs in Italy reported on the results of primary hrHPV testing with HC2 and cytology triage of positive hrHPV tests, with two rounds of screening at a 3-year interval (Tables 9 and 10).^126^ The study included 93,381 women invited for screening; 48,751 participated with completion of 48,736 hrHPV tests. Conventional cytology smears were obtained simultaneously, and processed only for positive test results. Among those with positive hrHPV screening results, women with abnormal cytology were referred to colposcopy; women with normal cytology had repeat hrHPV testing at one year. Women with negative hrHPV testing were invited for a second round of screening at three years. At the time of publication, 29,694 were invited to screening, 22,000 (74.5%) participated, and 21,827 completed HPV tests.

Table 9 Study Design Characteristics of Included Observational Studies

Author, Year & Quality | Design | Country | N | Inclusion Criteria | Exclusion Criteria | Recruitment
Katki, 2011^123,^ ^144,^ ^145,^ ^181–183^ KPNC Fair | Prospective Single Group Cohort | United States | 331,818 | Women age ≥30 years | NR | Primary Care Women enrolled in KP between 2003 and 2005
Ibanez, 2014^122^ Fair | Prospective Single Group Cohort | Spain | 1832 | Women age >39 years who had no evidence of cervical cytology in the public primary health registries in the previous 5 years | NR | Population-based screening Women identified in eight public primary health areas of Catalonia during 2007 and 2008
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Prospective Comparative Cohort | Germany | 19,795 | Women age ≥30 years who were voluntarily attending routine cervical cancer screening at one of the gynecological partners in private practice | History of hysterectomy | Population-based screening Between February 2006 and January 2011, female members of the Deutsche BKK age ≥30 years who were voluntarily attending routine cervical cancer screening at one of the gynecological partners in private practice invited to participate
McCaffery, 2004^118^ Fair | Cross-sectional study | United Kingdom | 428 | Women attended a NHS well-woman clinic for routine cervical cancer screening | NR | Primary care Women attended a NHS well-woman clinic for routine cervical cancer screening
Zorzi, 2017^127^ Fair | Prospective Single Group Cohort | Italy | Round 1: 48,736 Round 2: 21,827 | Women ages 25–64 years living in two areas of the Veneto region | NR | Population-based screening Women living in the two areas of interest were invited to screening from April 2009 to April 2011

Abbreviations: btwn = between; CIN = cervical intraepithelial neoplasia; hrHPV = high risk human papillomavirus; KP = Kaiser Permanente; NHS = National Health Service; NR = not reported

Table 10 Results for Italian Population-Based Cohort of Primary hrHPV Testing Over Two Rounds at a 3-year interval,^127^ All Participants and Results by Age

Parameter | Round | All Participants | Women Aged 25–29 | Women Aged 30–64
N Analyzed | -- | 48,736 | 5,103 | 43,647
Ages Recruited | -- | 25–64 | -- | --
# of Rounds (Interval) | -- | 2 (3 years) | -- | --
Screening Approach^*^ | -- | hrHPV Primary (HC2) | -- | --
Test Positivity | 1 | 3,133/48,736 (6.4%) | 754/5,103 (14.8%) | 2379/43,647 (5.5%)
Test Positivity | 2 | 777/21,827 (3.5%) | 140/1,723 (8.1%) | 637/20,104 (3.1%)
Test Positivity | C | 3,910/48,736 (8.0%) | 894/5,103 (17.5%) | 3,016/43,647 (6.9%)
Colposcopy Referrals | 1 | 2,136/48,736 (4.4%) | -- | --
Colposcopy Referrals | 2 | 472/21,827 (2.2%) | -- | --
Colposcopy Referrals | C | 2,608/48,736 (5.4%) | -- | --
Absolute Detection for CIN3+ | 1 | 95/48,736 (0.2%) | -- | --
Absolute Detection for CIN3+ | 2 | 6/21,827 (0.03%) | -- | --
Absolute Detection for CIN3+ | C | 101/48,736 (0.2%) | -- | --
Relative Risk for CIN3+ (Round 2 vs. Round 1) | 1 | -- | -- | --
Relative Risk for CIN3+ (Round 2 vs. Round 1) | 2 | 0.14 (95% CI, 0.06 to 0.32) | -- | --
Absolute Detection for CIN2+ | 1 | 215/48,736 (0.4%) | 53/5,103 (1.0%) | 162/43,647 (0.4%)
Absolute Detection for CIN2+ | 2 | 23/21,827 (0.1%) | 7/1,723 (0.4%) | 16/20,104 (0.1%)
Absolute Detection for CIN2+ | C | 238/48,736 (0.5%) | 60/5,103 (1.2%) | 178/43,647 (0.4%)
Relative Risk for CIN2+ (Round 2 vs. Round 1) | 1 | -- | -- | --
Relative Risk for CIN2+ (Round 2 vs. Round 1) | 2 | 0.24 (95% CI, 0.16 to 0.37) | 0.39 (95% CI, 0.18 to 0.86) | 0.21 (95% CI, 0.13 to 0.36)

* Women with +hrHPV had conventional cytology triage: ASC-US+ were referred to colposcopy; normal cytology were rescreened at 1 year (those who remained HPV+ were referred to colposcopy); HPV- were rescreened at 3 years

Abbreviations: C = cumulative; CIN = cervical intraepithelial neoplasia; hrHPV = high risk human papillomavirus; Vs = versus

The ATHENA study was a single-arm observational cohort study of 47,208 women age 21 years and older (no upper age or age range is given) recruited for a single cross-sectional screening with three hrHPV test types, the HPV Amplicor and Linear Array HPV genotyping test, Hybrid Capture II, and cobas HPV test.^91^ LBC was also performed on all subjects. Although initial results from the cross-sectional sample were reported for women 25 years and older (41,995), 77 percent of these women had no further followup. Subsequent followup was reported only on women with abnormal cytology (ASC-US or worse), women positive for HPV with Amplicor or linear array, and the group of women with normal results who were randomly selected and agreed to colposcopy (total n=9353). Of the 9353 women who were invited to that initial colposcopy, 2685 (35%) were lost to followup after the initial colposcopy. Due to exclusion of most of the study population after cross-sectional screening, as well as high loss to followup over 3 years, this study was rated as poor quality and not included in the review.

#### Screening With hrHPV Cotesting

##### RCTs

The good-quality NTCC Phase I trial by Ronco and colleagues compared HC2 hrHPV and LBC cotesting to conventional cytology (Tables 11–13).^119,^ ^131,^ ^132^ In this trial, 45,174 Italian women ages 25 to 60 years attending a routine cervical cancer screening visit from March 2002 through December 2004 were randomized to cotesting or conventional cytology. Data from Phase II, which used hrHPV testing alone, are reported separately in the section on primary hrHPV testing above. At the 3-year followup round, all participants were screened with conventional cytology. Maximum total followup was 7 years. Women were referred to colposcopy for ASC-US+ on cytology, and women ages 35 to 60 years with a positive hrHPV test were referred to colposcopy. Women ages 24 to 35 years with a positive hrHPV test result were referred to colposcopy only if hrHPV remained positive at the 1-year followup testing.

Table 11 Results for Trials of hrHPV Cotesting, All Participants

Parameter | Round | NTCC Phase I^120,^ ^133,^ ^134^ | POBASCAM^121,^ ^135,^ ^136^ | SWEDESCREEN^119,^ ^137^ | ARTISTIC^117,^ ^138–140^
Quality | -- | Good | Good | Fair | Fair
N Randomized | -- | 45,174 | 44,938 | 12,527 | 25,078
Ages Recruited | -- | 25–60 years | 29–61 years | 32–38 years | 20–64 years
Number of Rounds (Interval) | -- | 2 (3 years) | 2 (5 years) | 1 (3 years) Registry followup in organized screening program | 2 (3 years)
Screening Approach (IG vs. CG) | 1 | hrHPV cotesting vs. CC | hrHPV cotesting vs. CC | hrHPV cotesting vs. CC | hrHPV cotesting vs. LBC
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | hrHPV cotesting vs. hrHPV cotesting (both arms received same testing strategy) | CC vs. CC (both arms received same testing strategy in organized screening program) | hrHPV cotesting vs. LBC
Followup | 1 | 3.5 years (maximum) | 4 years (maximum) | 3 years (maximum) | 2.2 years (maximum)
Followup | 2 | 3.5 years (maximum) | 5 years (maximum) | NR | 2.3 years (maximum)
Followup | C | 7 years (maximum) | 9 years (maximum) | 4.1 years (average) | 4.5 years (maximum)
Test Positivity | 1 | IG (hrHPV+ or ASC-US+): 2,830/22,708 (12.5%) CG (ASC-US+): 855/22,466 (3.8%) | IG (hrHPV+ or ASC-US+): 1,406/19,999 (7.0%) CG (ASC-US+): 706/20,106 (3.5%) | IG (hrHPV+): 433/6,257 (6.9%) IG (ASC-US+): 146/6,257 (6.9%) CG (ASC-US+): 150/6,270 (2.4%) | IG (hrHPV+ or ASC-US+): 4,019/18,386 (21.9%) CG (ASC-US+): 786/6,124 (12.8%)
Test Positivity | 2 | NR | IG (hrHPV+ or ASC-US+): 742/19,579 (3.8%) CG (hrHPV+ or ASC-US+): 774/19,731 (3.9%) | NR | IG (hrHPV+ or ASC-US+): 1,258/11,862 (10.6%)^‡^ CG (ASC-US+): 210/3,928 (5.3%)^‡^
Colposcopy Referrals | 1 | IG: 2,470/22,708 (10.9%)^§^ CG: 738/22,466 (3.3%) | NR | NR | IG: 1,247/18,386 (6.8%) CG: 320/6,124 (5.2%)
Colposcopy Referrals | 2 | NR | NR | NR | IG: 284/10,716 (2.7%)^‡^ CG: 74/3,514 (2.1%)^‡^
False-Positive Rate for CIN2+ | 1 | IG: 2,702/22,042 (12.3%) CG: 771/21,972 (3.5%) | IG: 1,149/19,742 (5.8%) CG: 513/19,913 (2.6%) | IG: NR CG: 72/6,192 (1.2%) | IG: 3,566/17,933 (19.9%) CG: 653/5,991 (10.9%)
False-Positive Rate for CIN2+ | 2 | NR | IG: 610/9,572 (6.4%) CG: 612/9,450 (6.5%) | NR | IG: 1,178/10,512 (11.2%)^‡^ CG: 176/3,832 (4.6%)^‡^
Absolute Detection for CIN3+ | 1 | IG: 75/22,708 (0.3%)^*^ CG: 58/22,466 (0.3%)^*^ | IG: 171/19,999 (0.9%) CG: 150/20,106 (0.7%) | IG: 72/6,257 (1.2%) CG: 55/6,270 (0.9%) | IG: 233/18,386 (1.3%) CG: 81/6,124 (1.3%)
Absolute Detection for CIN3+ | 2 | IG: 13/22,093 (0.06%)^*^ CG: 19/22,330 (0.08%)^*^ | IG: 88/19,579 (0.4%) CG: 122/19,731 (0.6%) | IG: 16/6,257 (0.3%) CG: 30/6,270 (0.5%) | IG: 36/11,862 (0.3%)^‡^ CG: 17/3,928 (0.4%)^‡^
Absolute Detection for CIN3+ | C | IG: 88/22,708 (0.4%)^*^ CG: 77/22,466 (0.3%)^*^ | IG: 259/19,999 (1.3%) CG: 272/20,106 (1.3%) | IG: 88/6,257 (1.4%) CG: 85/6,270 (1.4%) | IG: 269/18,386 (1.5%)^‡^ CG: 98/6,124 (1.6%)^‡^
Relative Risk for CIN3+ | 1 | 1.28 (95% CI, 0.91 to 1.80)^†^ | 1.15 (95% CI, 0.92 to 1.43) | 1.31 (95% CI, 0.92 to 1.87) | 0.96 (95% CI, 0.74 to 1.23)^†^
Relative Risk for CIN3+ | 2 | 0.96 (95% CI, 0.34 to 1.40)^†^ | 0.73 (95% CI, 0.55 to 0.96) | 0.53 (95% CI, 0.29 to 0.98) | 0.76 (95% CI, 0.43 to 1.34)^†^
Relative Risk for CIN3+ | C | 1.13 (95% CI, 0.83 to 1.53)^†^ | 0.96 (95% CI, 0.81 to 1.13) | 1.04 (95% CI, 0.77 to 1.39)^†^ | 0.91 (95% CI, 0.73 to 1.15)^†^
Absolute Detection for CIN2+ | 1 | IG: 187/22,708 (0.8%)^*^ CG: 99/22,466 (0.4%)^*^ | IG: 267/19,999 (1.3%) CG: 215/20,106 (1.1%) | IG: 144/6,257 (1.8%) CG: 76/6,270 (1.2%) | IG: 453/18,386 (2.5%) CG: 134/6,124 (2.2%)
Absolute Detection for CIN2+ | 2 | IG: 22/22,093 (0.1%)^*^ CG: 34/22,330 (0.1%)^*^ | IG: 160/19,579 (0.8%) CG: 184/19,731 (0.9%) | IG: 25/6,257 (0.4%) CG: 43/6,270 (0.7%) | IG: 88/11,862 (0.7%)^‡^ CG: 35/3,928 (0.9%)^‡^
Absolute Detection for CIN2+ | C | IG: 209/22,708 (0.9%)^*^ CG: 133/22,466 (0.6%)^*^ | IG: 427/19,999 (2.1%) CG: 399/20,106 (2.0%) | IG: 139/6,257 (2.2%) CG: 119/6,270 (1.9%) | IG: 541/18,386 (2.9%)^‡^ CG: 169/6,124 (2.8%)^‡^
Relative Risk for CIN2+ | 1 | 1.87 (95% CI, 1.46 to 2.38)^†^ | 1.25 (95% CI, 1.05 to 1.50) | 1.51 (95% CI, 1.13 to 2.02) | 1.34 (95% CI, 1.11 to 1.62)^†^
Relative Risk for CIN2+ | 2 | 0.65 (95% CI, 0.38 to 1.12)^†^ | 0.88 (95% CI, 0.71 to 1.08) | 0.58 (95% CI, 0.36 to 0.96) | 0.83 (95% CI, 0.56 to 1.23)^†^
Relative Risk for CIN2+ | C | 1.55 (95% CI, 1.25 to 1.93)^†^ | 1.08 (95% CI, 0.94 to 1.24) | 1.17 (95% CI, 0.92 to 1.49)^†^ | 1.07 (95% CI, 0.90 to 1.26)^†^
Invasive Cervical Cancer | 1 | NR | IG: 12/19,999 (0.06%) CG: 6/20,109 (0.03%) | NR | IG: 5/18,386 (0.03%) CG: 4/6,124 (0.07%)
Invasive Cervical Cancer | 2 | NR | IG: 4/19,579 (0.02%) CG: 14/19,731 (0.07%) | NR | IG: 3/10,716 (0.03%)^‡^ CG: 0/3,514 (0%)^‡^
Invasive Cervical Cancer | C | NR | IG: 16/19,999 (0.08%) CG: 20/20,106 (0.10%) | IG: 1/6,257 (0.02%) CG: 5/6,270 (0.08%) | IG: 8/18,386 (0.04%)^‡^ CG: 4/6,124 (0.07%)^‡^

* From author inquiry

† Calculated (unadjusted)

‡ Preliminary or incomplete results

§ Estimated data from figure

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; ASC-US = Atypical squamous cells of undetermined significance; CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV = high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening; POBASCAM = Population Based Screening Study Amsterdam Program

Table 12 Results for Trials of hrHPV Cotesting, Women Age ≥30–35 Years

Parameter | Round | NTCC Phase I^120,^ ^133,^ ^134^ | POBASCAM^121,^ ^135,^ ^136^ | SWEDESCREEN^119,^ ^137^ | ARTISTIC^117,^ ^138–140^
Quality | -- | Good | Good | Fair | Fair
N Randomized | -- | 33,364 | 33,838 | 12,527 | 19,344
Ages Recruited | -- | 35–60 years | 34–56 years | 32–38 years | 30–64 years
Number of Rounds (Interval) | -- | 2 (3 years) | 2 (5 years) | 1 (3 years)Registry followup in organized screening program | 2 (3 years)
Screening Approach (IG vs. CG) | 1 | hrHPV cotesting vs. CC | hrHPV cotesting vs. CC | hrHPV cotesting vs. CC | hrHPV cotesting vs. LBC
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | hrHPV cotesting vs. hrHPV cotesting (both arms received same testing strategy) | CC vs. CC (both arms received same testing strategy in organized screening program) | hrHPV cotesting vs. LBC
Followup | 1 | 3.5 years (maximum) | 4 years (maximum) | 3 years (maximum) | 2.2 years (maximum)
Followup | 2 | 3.5 years (maximum) | 5 years (maximum) | NR | 2.3 years (maximum)
Followup | C | 7 years (maximum) | 9 years (maximum) | 4.1 years (average) | 4.5 years (maximum)
Test Positivity | 1 | IG (hrHPV+ or ASC-US+): 1,783/16,706 (10.7%) CG (ASC-US+): 594/16,658 (3.6%) | IG (hrHPV+): 684/16,860 (4%) CG: NR | IG (hrHPV+ or ASC-US+): NR CG (ASC-US+): 150/6,270 (2.4%) | IG (hrHPV+ or ASC-US+): 2,465/14,507 (17.0%) CG (ASC-US+): 508/4,837 (10.5%)
Test Positivity | 2 | NR | NR | NR | NR
Colposcopy Referrals | 1 | IG: 1,773/16,706 (10.6%) CG: 501/16,658 (3.0%) | NR | NR | NR
Colposcopy Referrals | 2 | NR | NR | NR | NR
False-Positive Rate for CIN2+ | 1 | IG: 1,704/16,335 (10.4%) CG: 543/16,607 (3.3%) | NR | IG: NR CG: 72/6,192 (1.2%) | NR
False-Positive Rate for CIN2+ | 2 | NR | NR | NR | NR
Absolute Detection for CIN3+ | 1 | IG: 52/16,706 (0.3%)^*^ CG: 33/16,658 (0.2%)^*^ | IG: 102/16,860 (0.6%)^*^ CG: 90/16,978 (0.5%)^*^ | IG: 72/6,257 (1.2%) CG: 55/6,270 (0.9%) | IG: 116/14,507 (0.8%) CG: 38/4,837 (0.8%)
Absolute Detection for CIN3+ | 2 | IG: 5/16,332 (0.03%)^*^ CG: 11/16,561 (0.07%)^*^ | IG: 55/16,545 (0.3%)^*^ CG: 77/16,699 (0.5%)^*^ | IG: 16/6,257 (0.3%) CG: 30/6,270 (0.5%) | NR
Absolute Detection for CIN3+ | C | IG: 57/16,706 (0.3%)^*^ CG: 44/16,658 (0.3%)^*^ | IG: 157/16,860 (0.9%) CG: 167/16,978 (1.0%) | IG: 88/6,257 (1.4%) CG: 85/6,270 (85%) | NR
Relative Risk for CIN3+ | 1 | 1.57 (95% CI, 1.02 to 2.43)^*^ | 1.14 (95% CI, 0.86 to 1.51)^†^ | 1.31 (95% CI, 0.92 to 1.87) | 1.12 (95% CI, 0.71 to 1.47)^†^
Relative Risk for CIN3+ | 2 | 0.46 (95% CI, 0.16 to 1.33)^*^ | 0.72 (95% CI, 0.51 to 1.02)^†^ | 0.53 (95% CI, 0.29 to 0.98) | NR
Relative Risk for CIN3+ | C | 1.30 (95% CI, 0.87 to 1.91)^*^ | 0.95 (95% CI, 0.76 to 1.18) | 1.04 (95% CI, 0.77 to 1.39)^†^ | NR
Absolute Detection for CIN2+ | 1 | IG: 109/16,706 (0.6%)^*^ CG: 61/16,658 (0.4%)^*^ | IG: 166/16,860 (1.0%)^*^ CG: 127/16,978 (0.7%)^*^ | IG: 144/6,257 (1.8%) CG: 76/6,270 (1.2%) | IG: 217/14,507 (1.5%) CG: 60/4,837 (1.2%)
Absolute Detection for CIN2+ | 2 | IG: 11/16,332 (0.07%)^*^ CG: 19/16,561 (0.1%)^*^ | IG: 108/16,545 (0.6%)^*^ CG: 121/16,699 (0.7%)^*^ | IG: 25/6,257 (0.4%) CG: 43/6,270 (0.7%) | NR
Absolute Detection for CIN2+ | C | IG: 120/16,706 (0.7%)^*^ CG: 80/16,658 (0.5%)^*^ | IG: 274/16,860 (1.6%) CG: 248/16,978 (1.5%) | IG: 139/6,257 (2.2%) CG: 119/6,270 (1.9%) | NR
Relative Risk for CIN2+ | 1 | 1.78 (95% CI, 1.30 to 2.44)^*^ | 1.32 (95% CI, 1.05 to 1.66)^†^ | 1.51 (95% CI, 1.13 to 2.02) | 1.21 (95% CI, 0.91 to 1.60)^†^
Relative Risk for CIN2+ | 2 | 0.59 (95% CI, 0.28 to 1.24)^*^ | 0.90 (95% CI, 0.70 to 1.17)^†^ | 0.58 (95% CI, 0.36 to 0.96) | NR
Relative Risk for CIN2+ | C | 1.50 (95% CI, 1.13 to 1.98)^*^ | 1.11 (95% CI, 0.94 to 1.32) | 1.17 (95% CI, 0.92 to 1.49)^†^ | NR
Invasive Cervical Cancer | 1 | NR | IG: 10/16,860 (0.06%)^*^ CG: 4/16,978 (0.02%)^*^ | NR | IG: 5/14,507 (0.03%) CG: 3/4,837 (0.06%)
Invasive Cervical Cancer | 2 | NR | IG: 4/16,545 (0.02%)^*^ CG: 9/16,699 (0.05%)^*^ | NR | IG: 2/9,037 (0.02%)^‡^ CG: 0/2,965 (0%)^‡^
Invasive Cervical Cancer | C | NR | IG: 14/16,860 (0.08%)^*^ CG: 13/16,978 (0.08%) | IG: 1/6,257 (0.02%) CG: 5/6,270 (0.08%) | IG: 7/14,507 (0.05%)^‡^ CG: 3/4,837 (0.06%)^‡^

* From author inquiry

† Calculated (unadjusted)

‡ Preliminary or incomplete results

Estimated data from figure

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; ASC-US = Atypical squamous cells of undetermined significance; CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV = high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening; POBASCAM = Population Based Screening Study Amsterdam Program

Table 13 Results for Trials of hrHPV Cotesting, Women Age >30–35 Years

Parameter | Round | NTCC Phase I^120,^ ^133,^ ^134^ | POBASCAM^121,^ ^135,^ ^136^ | SWEDESCREEN^119,^ ^137^ | ARTISTIC^117,^ ^138–140^
Quality | -- | Good | Good | Fair | Fair
N Randomized | -- | 11,810 | 6,267 | | 5,166
Ages Recruited | -- | 25–34 years | 29–33 years | | 20–29 years
# of Rounds (Interval) | -- | 2 (3 years) | 2 (5 years) | | 2 (3 years)
Screening Approach (IG vs. CG) | 1 | hrHPV cotesting vs. CC | hrHPV cotesting vs. CC | | hrHPV cotesting vs. LBC
Screening Approach (IG vs. CG) | 2 | CC vs. CC (both arms received same testing strategy) | hrHPV cotesting vs. hrHPV cotesting (both arms received same testing strategy) | | hrHPV cotesting vs. LBC
Followup | 1 | 3.5 years (maximum) | 4 years (maximum) | | 2.2 years (maximum)
Followup | 2 | 3.5 years (maximum) | 5 years (maximum) | | 2.3 years (maximum)
Followup | C | 7 years (maximum) | 9 years (maximum) | | 4.5 years (maximum)
Test Positivity | 1 | IG (hrHPV+ or ASC-US+): 1,047/6,002 (17.4%) CG (ASC-US+): 261/5,808 (4.5%) | IG (hrHPV+): 373/3,139 (12.0%) CG: NR | | IG (hrHPV+ or ASC-US+): 1,554/3,879 (40.1%) CG (ASC-US+): 278/1,287 (21.6%)
Test Positivity | 2 | NR | NR | | NR
Colposcopy Referrals | 1 | IG: 697/6,002 (11.6%) CG: 237/5,808 (4.1%) | NR | | NR
Colposcopy Referrals | 2 | NR | NR | | NR
False-Positive Rate for CIN2+ | 1 | IG: 998/4,980 (20.0%) CG: 228/5,775 (3.9%) | | | NR
False-Positive Rate for CIN2+ | 2 | NR | | | NR
Absolute Detection for CIN3+ | 1 | IG: 23/6,002 (0.4%)^*^ CG: 25/5,808 (0.4%)^*^ | IG: 69/3,139 (2.2%)^*^ CG: 60/3,128 (1.9%)^*^ | | IG: 117/3,879 (3.0%) CG: 42/1,287 (3.3%)
Absolute Detection for CIN3+ | 2 | IG: 8/5,761 (0.1%)^*^ CG: 8/5,769 (0.1%)^*^ | IG: 33/3,034 (1.1%)^*^ CG: 45/3,032 (1.3%)^*^ | | NR
Absolute Detection for CIN3+ | C | IG: 31/6,002 (0.5%)^*^ CG: 33/5,808 (0.6%)^*^ | IG: 102/3,139 (3.3%) CG: 105/3,128 (3.4%) | | NR
Relative Risk for CIN3+ | 1 | 0.89 (95% CI, 0.51 to 1.57)^*^ | 1.15 (95% CI, 0.81 to 1.61)^†^ | | 0.92 (95% CI, 0.65 to 1.31)^†^
Relative Risk for CIN3+ | 2 | 1.00 (95% CI, 0.38 to 2.67)^*^ | 0.73 (95% CI, 0.47 to 1.15)^†^ | | NR
Relative Risk for CIN3+ | C | 0.91 (95% CI, 0.56 to 1.48)^*^ | 0.97 (95% CI, 0.74 to 1.27) | | NR
Absolute Detection for CIN2+ | 1 | IG: 78/6,002 (1.3%)^*^ CG: 38/5,808 (0.6%)^*^ | IG: 101/3,139 (3.2%)^*^ CG: 88/3,128 (2.8%)^*^ | | IG: 236/3,879 (6.1%) CG: 73/1,287 (5.7%)
Absolute Detection for CIN2+ | 2 | IG: 11/5,761 (0.2%)^*^ CG: 15/5,769 (0.3%)^*^ | IG: 52/3,034 (1.7%)^*^ CG: 63/3,032 (2.1%)^*^ | | NR
Absolute Detection for CIN2+ | C | IG: 89/6,002 (1.5%)^*^ CG: 53/5,808 (0.9%)^*^ | IG: 153/3,139 (4.9%) CG: 151/3,128 (4.8%) | | NR
Relative Risk for CIN2+ | 1 | 1.99 (95% CI, 1.35 to 2.92)^*^ | 1.14 (95% CI, 0.86 to 1.52)^†^ | | 1.07 (95% CI, 0.83 to 1.38)^†^
Relative Risk for CIN2+ | 2 | 0.73 (95% CI, 0.34 to 1.60)^*^ | 0.82 (95% CI, 0.57 to 1.19)^†^ | | NR
Relative Risk for CIN2+ | C | 1.63 (95% CI, 1.16 to 2.28)^*^ | 1.01 (95% CI, 0.81 to 1.26) | | NR
Invasive Cervical Cancer | 1 | NR | IG: 2/3,139 (0.06%)^*^ CG: 2/3,128 (0.06%)^*^ | | IG: 0/3,879 (0%) CG: 1/1,287 (0.08%)
Invasive Cervical Cancer | 2 | NR | IG: 0/3,034 (0%)^*^ CG: 5/3,032 (0.16%)^*^ | | IG: 1/1,679 (0.06%)^‡^ CG: 0/549 (0%)^‡^
Invasive Cervical Cancer | C | NR | IG: 2/3,139 (0.06%)^*^ CG: 7/3,128 (0.22%)^§^ | | IG: 1/3,879 (0.03%)^‡^ CG: 1/1,287 (0.08%)^‡^

^*^ From author inquiry

^†^ Calculated (unadjusted)

^‡^ Preliminary or incomplete results

^§^ Estimated data from figure

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; ASC-US = Atypical squamous cells of undetermined significance; CC = conventional cytology; CIN = cervical intraepithelial neoplasia; CG = control group; hrHPV = high risk human papillomavirus; IG = intervention group; LBC = liquid-based cytology; NR = not reported; NTCC = New Technologies for Cervical Cancer Screening; POBASCAM = Population Based Screening Study Amsterdam Program

The fair-quality SWEDESCREEN trial compared hrHPV cotesting using the GP5+/6+ PCR enzyme immunoassay combined with conventional cytology compared with conventional cytology alone in the first round of screening.^118,^ ^135^ All women received both tests at baseline, but hrHPV samples were frozen for future testing in the control arm. A total of 12,527 Swedish women who were invited for routine cervical cancer screening agreed to randomization and were followed after the first round of screening for slightly more than 4 years through comprehensive registry data. Screening protocols for women negative in Round 1 were through usual care. After 3 years, blinding of hrHPV results was discontinued because of concerns about higher rates of CIN2 and CIN3 associated with positive hrHPV results; all women enrolled in the study were informed of their hrHPV results. According to study protocol, women with cytology results consistent with CIN2+ were referred to colposcopy in all communities, but followup for ASC-US and LSIL varied by community, with women either referred to colposcopy or undergoing a repeat Pap smear. Women with normal cytology and a positive hrHPV test result were invited to repeat cotesting at 12 months, and referred to colposcopy if the hrHPV test was still positive at that time.

In the fair-quality ARTISTIC trial, Kitchener and colleagues compared hrHPV with LBC among women ages 20 to 64 years invited for routine cervical cancer screening in the United Kingdom.^116,^ ^136–138^ A total of 25,078 women received LBC and hrHPV testing and were randomized in a 3-to-1 ratio to have both hrHPV and LBC results revealed to the patient and the investigator (18,386 women in the intervention group), or to have only LBC results revealed (6,124 women in the control group). LBC was processed via a ThinPrep system; hrHPV testing was conducted with HC2. Two rounds of screening were conducted, with the second round using the same screening protocol at a 3-year interval. Women with HSIL+ in either group were referred directly to colposcopy and biopsy. Women with LSIL in either group had repeat testing at 6 months and were referred to colposcopy if persistently positive. Women with borderline cytology in either group were retested at 6 and 12 months; if persistently positive, they were referred to colposcopy. Women in the intervention group with a positive hrHPV test and normal cytology were retested at 12 months. If the positive hrHPV result persisted, they were offered colposcopy or repeat testing at 24 months. Women with positive hrHPV testing at 24 months were referred to colposcopy. Loss to followup before the second round of screening was 33.2 percent in the intervention group and 34.2 percent in the control group.

In the good-quality POBASCAM trial, Rijkaart and colleagues randomized 44,938 women ages 29 to 61 years to one round of cotesting with hrHPV with the GP5+/6+ PCR enzyme immunoassay testing and conventional cytology (19,999 women in the intervention group), or conventional cytology alone (20,106 women) with blinded hrHPV testing.^120,^ ^133,^ ^134^ After this single round of screening, followup testing 4 to 6 years later included cotesting with hrHPV GP5+/6+ PCR enzyme immunoassay and conventional cytology tests for all women. Women who had normal cytology with a positive hrHPV test result had repeat testing at 6 and 18 months. Women with moderate dyskaryosis or worse (HSIL+) in either group were referred for colposcopy and biopsy. Women in the intervention group with less than HSIL on cytology underwent repeat cytology and hrHPV testing at 6 months. If hrHPV was positive, they were referred to colposcopy and biopsy; if not, testing was repeated at 18 months. Overall loss to followup from all causes was 16.5 percent and was similar between arms.

Ronco and colleagues conducted an IPD meta-analysis of five trials: four trials of cotesting (NTCC Phase I, SWEDESCREEN, ARTISTIC, and POBASCAM) and a single trial of primary hrHPV testing (NTCC Phase II).^139^ Participant data were pooled although these trials had distinctly different screening protocols, screening intervals, and hrHPV test types. Cancer ascertainment was performed at the individual trial level with no additional case review. Followup duration ranged from 5 to 12 years.

##### Cohorts

Numerous reports have been published on a cohort of women who received cotesting at KPNC, a large health maintenance organization (Table 9; Appendix Tables 5 and 6).^122,^ ^141–143^ The number of women included in the cohort varied depending on the research question, the continuity of the screened population, selected characteristics of participants, and the number of rounds of screening considered. A study on cotesting over time in the same cohort of women was included to add representation of the U.S. population, and a larger but less continuous KPNC cohort substudy provided age-stratified comparisons (presented below). The cohort had no comparison group, but this large U.S.-based study did report outcomes on a group of 331,818 women age 30 years and older who underwent initial cotesting with conventional cytology and HC2 hrHPV testing between 2003 and 2005 (prevalence screen) with cumulative outcomes up to 6 years from enrollment.^122^ They reported incidence screening outcomes on a group of 195,975 women with initial negative cotesting results who underwent a second cotesting round 3 years later. A recently published report on 1,262,713 women who underwent screening one or more times in KPNC between 2003 and 2015 included both women ages 25 to 29 years undergoing cytology and ASC-US triage with hrHPV testing and women ages 30 to 77 years screened with cotesting. This analysis presented cumulative 5-year risk of CIN3+ and ICC stratified by hrHPV results and cytology results.^115^

A German prospective observational cohort study included 19,795 women who underwent cotesting with conventional cytology and HC2 testing with a 5-year screening interval.^123,^ ^140^ No comparison group was included. Women with abnormal cytology and negative hrHPV testing and those with positive hrHPV testing and normal cytology underwent repeat cytology at 6 months and hrHPV testing at 12 months with referral to colposcopy for any abnormal results. The investigators reported interim outcomes of 4,067 women screened in the first and second rounds for the same time interval beyond screening.

### Detailed Results

#### CIN2+ and CIN3+ Detection

##### Screening With Primary hrHPV Testing

In the NTCC Phase II trial, over two rounds of screening, detection rates for CIN3+ were 0.4 percent in the intervention group and 0.2 percent in the control group, with an RR for CIN3+ detection of 1.81 (95% CI, 1.31 to 2.51).^119^ In the HPV FOCAL trial, during the first round of screening, CIN3+ detection was 0.8 percent in the intervention group and 0.5 percent in the control group; the RR for CIN3+ detection was 1.61 (95% CI, 1.09 to 2.37). After 2 years, CIN3+ detection was 0.06 percent in the safety arm (screened in Round 1 with hrHPV) and 0.25 percent in the control arm.^144^ Final results, including cumulative CIN3+ detection rates over the full 4 years of the trial, are pending publication. In the FINNISH trial, the RR for detection of CIN3+ among women in the hrHPV group was 1.64 (95% CI, 1.30 to 2.06), with 195 (0.3%) women in the intervention group found to have CIN3+ compared with 118 (0.2%) in the group screened with conventional cytology.^124^ In the Compass trial’s first round of screening, CIN3+ detection was 0.8 percent in the intervention group and 0.1 percent in the control group; the RR for CIN3+ detection was 7.46 (95% CI, 1.02 to 54.66).^104^ Detailed results for randomized trials of primary hrHPV testing are summarized in Table 6.

In the Italian cohort study at Round 1, detection rates including 1-year followup were 215 cases of CIN2+, 95 cases of CIN3+, and 6 cases of ICC (CIN3+, 0.2%).^126^ Detection rates at Round 2 including 1-year followup were 23 cases of CIN2+, 6 cases of CIN3+, and no cases of cervical cancer (CIN3+, 0.03%). The RR for CIN3+ detection at Round 2 compared to Round 1 was 0.14 (95% CI, 0.06 to 0.32).

##### Screening With hrHPV Cotesting

In the NTCC Phase I trial in the first round of screening, 0.3 percent of 22,708 women had CIN3+ detected in the intervention group compared with 0.3 percent of 22,466 women in the control group, with an RR of 1.28 (95% CI, 0.91 to 1.80).^132^ In Round 2, CIN3+ detection was 0.06 percent of 22,093 women in the intervention group compared with 0.08 percent of 22,330 women in the control group, with an RR of 0.96 (95% CI, 0.34 to 1.40). Cumulatively, the RR for detection of CIN3+ was 1.13 (95% CI, 0.83 to 1.53), with 88 (0.4%) of 22,708 women in the intervention group compared with 77 (0.3%) women in the comparison group found to have CIN3+ (Table 11).

In the SWEDESCREEN trial, Round 1 screening detected CIN3+ in 1.2 percent of 6,257 women in the intervention group compared with 0.9 percent of 6,270 women in the control group, with an RR of 1.31 (95% CI, 0.92 to 1.87).^118^ Registry followup of usual care screening identified CIN3+ in 0.3 percent of 6,257 women in the intervention group compared with 0.5 percent of 6,270 women in the control group. The RR for detection of CIN3+ was lower for the intervention group in the second round of screening at 0.53 (95% CI, 0.29 to 0.98). Cumulative detection of CIN3+ over one round of screening with subsequent usual care followup was similar between arms: 88 (1.4%) in the cotesting arm and 85 (1.4%) in the cytology group, with an RR of 1.04 (95% CI, 0.77 to 1.39). Long-term followup was reported at up to 13 years based on tracking study participants in the National Quality Registry for Cervical Cancer Prevention, a national Swedish registry including cervical cytology and biopsy results from all sources in Sweden (Appendix F Table 4).^135^ No statistical difference remained in cumulative CIN3+ rates between the intervention and control arms of the study. Cumulative rates of CIN3+ were examined for both baseline test results for both the combined study arms (cytology, hrHPV, and hrHPV/cytology combined). Among women in either group with negative cytology, CIN3+ rates were lowest for women with negative hrHPV tests at baseline in both the intervention and control arms and highest in women with negative cytology without consideration (i.e., no knowledge) of hrHPV test results.

In the ARTISTIC trial, Round 1 screening detected CIN 3+ in 1.3 percent of women in the intervention group and 1.3 percent of women in the control group.^116^ The RR for CIN3+ during Round 1 was 0.96 (95% CI, 0.74 to 1.23). Round 2 detection of CIN3+ was 0.3 percent of women in the intervention group and 0.4 percent of women in the control group, with an RR of 0.76 (95% CI, 0.43 to 1.34). Cumulative detection of CIN3+ was 1.5 percent of women in the intervention group and 1.6 percent in the control group. The cumulative RR for CIN3+ after two rounds of cotesting was 0.91 (95% CI, 0.73 to 1.15) (Table 11). After the second round of screening, all results were revealed; under a revised consent and protocol, a third round of testing was conducted. Due to loss of randomization, protocol changes, and further loss to followup, those results were not included in this review.^137^

During the first round of screening in POBASCAM, CIN3+ was detected in 0.9 percent of women in the intervention group compared with 0.7 percent of women in the control group. The RR was 1.15 (95% CI, 0.92 to 1.43).^120^ At Round 2, CIN3+ was detected in 0.4 percent of women in the intervention group compared with 0.6 percent of women in the control group, with an RR of 0.73 (95% CI, 0.55 to 0.96). With 9 years of followup after the two rounds of screening, and the second round including hrHPV testing for all subjects, the cumulative RR for CIN3+ in the intervention group was 0.96 (95% CI, 0.81 to 1.13) (Table 11). Detection of CIN3+ was 259 (1.3%) women in the intervention group compared with 272 (1.3%) women in the control group. Additional followup data from the POBASCAM trial was recently published in a report by Dijkstra and colleagues.^134^ Outcomes for initially hrHPV negative women (intervention group) and cytology negative women (control group) were reported after 14 years of followup, through the National Network of Cervical Histology and Cytology. At Round 3 of screening, participants in both groups were managed based on cytology results. The authors reported outcomes of analyses that were not prespecified for women who were cytology negative/hrHPV negative and cytology positive/hrHPV negative in the intervention group, and compared them to cytology negative women in the control group; HPV negative women had lowest rates of CIN3+ (Appendix F Table 4). The RRs for these subsets in the intervention versus control groups for CIN3+ were not significantly different from 1.0.

The KPNC cohort reported incidence screening outcomes on 331,818 women: 24,849 women (7.5%) had a positive hrHPV test result or abnormal cytology result, and 834 (0.3%) cases of CIN3+ were detected (Table 15).^122^ Among the 195,975 women with initial negative cotesting who had repeat screening 3 years later, 102 (0.05%) cases of CIN3+ were detected. A subsequent report on women with positive hrHPV test results and negative cytology in the Kaiser cohort extended inclusion through 2010. In this group of 32,374 women who were followed for variable durations after testing, CIN3+ was detected in 753 (2.3%) women.^142^ A recently published followup paper from 2003–2015 of 1,262,713 women with median followup of 3 years reported 2,106 CIN3+ cases among women with normal cytology results, with a 5-year cumulative risk of 0.25 percent (95% CI, 0.24 to 0.27). Among women with a negative hrHPV test, regardless of cytology results, there were 1,003 cases of CIN3+, a 5-year cumulative risk of 0.12 percent (95% CI, 0.11 to 0.12).^115^ These results add evidence of the very low risk of CIN3+ among women testing negative for hrHPV. In the German cohort, CIN3+ was detected in 0.87 percent of women in Round 1 compared with 0.05 percent of women in Round 2, suggesting a declining risk over cotesting screening rounds. However, without a cytology-only comparison group, the incremental benefit of cotesting could not be assessed.

Table 15 Results From the KPNC Cotesting Observational Study, All Participants

Parameter | Round | KPNC^123^
N Analyzed | -- | 331,818
Ages Recruited | -- | ≥30 years
Number of Rounds (Interval) | -- | 2 (3 years)
Screening Approach | -- | hrHPV cotesting (HC2 and CC)
Followup | 1 | NR
Followup | 2 | 2.9 years
Followup | C | 6 years
Test Positivity | -- | hrHPV+ or ASC-US+: 24,849/331,818 (7.5%)
Colposcopy Referrals | -- | NR
Absolute Detection for CIN3+ | 1 | NR
Absolute Detection for CIN3+ | 2 | 102/195,975 (0.05%)
Absolute Detection for CIN3+ | C | 834/331,818 (0.3%)
Absolute Detection for CIN2+ | 1 | NR
Absolute Detection for CIN2+ | 2 | 346/195,975 (0.2%)
Absolute Detection for CIN2+ | C | 2,310/331,818 (0.7%)
Invasive Cervical Cancer | 1 | NR
Invasive Cervical Cancer | 2 | 13/195,975 (0.01%)
Invasive Cervical Cancer | C | 87/331,818 (0.03%)

* Among women undergoing a colposcopy

Abbreviations: ASC-US = Atypical squamous cells of undetermined significance; C = cumulative; CC = conventional cytology; CIN = cervical intraepithelial neoplasia; hrHPV = high-risk human papillomavirus; KPNC = Kaiser Permanente Northern California; LBC = liquid-based cytology; NR = not reported

#### ICC

Trials had low rates of ICC and not all trials reported on ICC cases. For hrHPV primary testing, the FINNISH trial reported 17 cases of ICC among 66,410 women (0.03%) in the intervention group compared with 9 cases among 65,784 women (0.01%) in the control group in one round of screening. Among the cotesting trials, POBASCAM and ARTISTIC reported on ICC detection over two rounds of screening. In POBASCAM, the intervention group ICC detection was 12/19,999 women (0.06%) in Round 1 and 4/19,579 (0.02%) women in Round 2. In the control group, ICC detection was 6/20,109 women (0.03%) in Round 1, and 14/19,731 women (0.07%) in Round 2. In ARTISTIC, ICC detection in the intervention group was 5/18,386 women (0.03%) in Round 1, and 8/18,386 women (0.04%) in Round 2. ICC detection in the control group was 4/6,124 women (0.07%) in Round 1, and 0/3,514 women (0%) in Round 2.

The IPD meta-analysis of four trials of cotesting (NTCC Phase I, SWEDESCREEN, ARTISTIC, and POBASCAM) and a single trial of primary hrHPV testing (NTCC Phase II)^139^ included a total of 176,464 women with 1,214,415 person-years of followup, with 107 cases of ICC in a median followup period of 6.5 years (Table 14). After 8 years of followup, cumulative detection of ICC was 0.047 percent in the hrHPV screened women compared with 0.094 percent women in the control groups. With a fixed effects model, the overall pooled rate ratio for ICC in the hrHPV screened women was 0.60 (95% CI, 0.40 to 0.89). The I^2^ test for statistical heterogeneity was not significant (0.0%; p=0.52). A random effects model gave a similar estimate of 0.61 (95% CI, 0.41 to 0.91).

Table 14 Results of an Included Individual Participant Data Meta-Analysis of hrHPV-Based Screening Trials^141^

| NTCC Phases I and II | POBASCAM | SWEDESCREEN | ARTISTIC | Pooled Analysis
N Randomized | IG: 47,369 CG: 47,001 | IG: 22,197 CG: 22,292 | IG: 6,257 CG: 6,270 | IG: 18,816 CG: 6,262 | IG: 94,639 CG: 81,825
N Analyzed | IG: 47,369 CG: 47,001 | IG: 21,996 CG: 22,106 | IG: 6,257 CG: 6,270 | IG: 18,386 CG: 6,124 | IG: 94,008 CG: 81,411
Median followup, years | 5.1 | 9.0 | 12.0 | 7.5 | 6.5
Invasive cervical cancer | IG: 9 (0.02%) CG: 24 (0.05%) | IG: 20 (0.09%) CG: 28 (0.13%) | IG: 5 (0.08%) CG: 7 (0.11%) | IG: 10 (0.05%) CG: 4 (0.07%) | IG: 44 (0.05%) CG: 63 (0.08%)
Detection rate of invasive cervical cancer | 0.37 (95% CI, 0.17 to 0.80) | 0.72 (95% CI, 0.40 to 1.27) | 0.71 (95% CI, 0.23 to 2.25) | 0.83 (95% CI, 0.26 to 2.66) | 0.60 (95% CI, 0.40 to 0.89) I^2^=0.0%, p=0.52
Invasive cervical cancer among women with a negative test at entry^†^ | IG: 1 (0.002%) CG: 14 (0.3%) | IG: 6 (0.03%) CG: 17 (0.08%) | IG: 2 (0.03%) CG: 4 (0.06%) | IG: 3 (0.02%) CG: 0 (0%) | IG: 12 (0.01%) CG: 35 (0.04%)
Rate ratio for false-negative tests | 0.07 (95% CI, 0.01 to 0.56) | 0.36 (95% CI, 0.14 to 0.91) | 0.50 (95% CI, 0.09 to 2.73) | 2.06 (95% CI, 0.10 to 41.19) | 0.30 (95% CI, 0.15 to 0.60)
Biopsy procedures | IG: 2,538 (5%) CG: 1,127 (2%) | IG: 1,535 (7%) CG: 1,533 (7%) | IG: 675 (11%) CG: 701 (11%) | IG: 1,716 (9%) CG: 528 (9%) | IG: 6,464 (6.9%) CG: 3,889 (4.8%)
Rate ratio for biopsy procedures | 2.24 (95% CI, 2.09 to 2.39) | 1.01 (95% CI, 0.94 to 1.08) | 0.97 (95% CI, 0.87 to 1.07) | 1.08 (95% CI, 0.97 to 1.19) | 1.35 (95% CI, 1.30 to 1.40) I^2^=99.1, p<0.0001^*^

* Sensitivity analysis excluding the NTCC Phase I and Phase II trials: Rate ratio, 1.02 (95% CI, 0.97 to 1.07), I^2^=30.7%, p=0.236

† Observations censored 2.5 years after CIN2 or CIN3

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; CG = control group; CI = confidence interval; IG = intervention group; NTCC = New Technologies for Cervical Cancer Screening; POBASCAM = Population Based Screening Study Amsterdam Program

In the KPNC cohort, of the 331,818 women, there were 87 (0.03%) cases of ICC; 13 (0.01%) of those cases were detected among the 195,975 women with initial negative cotesting who had repeat screening 3 years later. In the cohort of 1,262,713 women with median 3 years followup, there were 452 ICC cases.

## KQ1a Does the Effectiveness of hrHPV Testing to Reduce Cervical Cancer Outcomes Vary by Subpopulation?

### Age

#### Screening With Primary hrHPV Testing

In the trials of primary hrHPV testing, subjects were eligible to start screening at age 25 years. Screening ended at age 60 years for NTCC Phase II and at age 65 years for the HPV FOCAL and FINNISH trials (Table 5). Results for these trials were stratified by age for women older (Table 7) and younger than age 35 years (Table 8). The NTCC Phase II trial included 13,725 women younger than age 35 years and 35,471 women age 35 years or older who were followed over two rounds of screening at 3-year intervals for a maximum followup of 7 years.^1,^ ^2^ hrHPV test positivity rates were substantially higher in women younger than age 35 years (13.1%) compared with women age 35 years or older (5.8%). In contrast, rates of abnormal cytology were more similar across age groups, although still higher in women younger than age 35 years (4% vs. 3.1%). Cumulative CIN3+ rates were also higher in women younger than age 35 years (intervention group [IG], 0.7%; control group [CG], 0.3%) compared with women age 35 years or older (IG, 0.3%; CG, 0.2%). Detection of CIN3+ was highest in the intervention group in Round 1, particularly for women younger than age 35 years (RR, 4.00 [95% CI, 2.07 to 7.73]) (Table 8) compared with women age 35 years and older (RR, 2.37 [95% CI, 1.44 to 3.89]) (Table 7). In Round 2, it was similarly lower for the intervention group in both age groups, with an RR of 0.20 (95% CI, 0.05 to 0.93) for women younger than age 35 years (Table 8) and an RR of 0.23 (95% CI, 0.07 to 0.82) for women age 35 years and older (Table 7). Over both rounds of screening, the RR for CIN3+ was 2.19 (95% CI, 1.31 to 3.66) in women younger than age 35 years (Table 8) and 1.57 (95% CI, 1.03 to 2.40) in women older than age 35 years (Table 7).

The HPV FOCAL trial has published results from the initial round of screening and from the safety arm at 24 months.^125,^ ^128,^ ^129^ Among the 4,849 women younger than age 35 years, Round 1 CIN3+ detection rates were 2.4 percent in the intervention group compared with 1.7 percent in the control group (Table 8). Round 1 CIN3+ rates among women ages 25 to 29 years were 3.1 percent in the intervention group, the highest of all age groups within the HPV FOCAL trial, compared to 1.7 percent in the control group. No other trial reported specifically on this age group. Among the 20,394 women age 35 years or older, CIN3+ detection rates were 0.5 percent in the intervention group compared with 0.3 percent in the control group (Table 7). When stratified by age, differences in Round 1 CIN3+ detection between the intervention and control groups were not statistically significant. At 2 years, cumulative CIN3+ detection rates for women ages 25 to 29 years were 3.0 and 1.4 percent for women ages 30 to 34 years in the safety arm compared to 2.7 percent for women ages 25 to 29 years and 1.7 percent for women ages 30 to 34 years in the control arm.^144^ Rates among women age 35 years and older were 0.4 percent and 0.3 percent, respectively.

The FINNISH trial included 22,262 women younger than age 35 years and 109,932 women ages 35 to 65 years who were screened with one round of hrHPV testing with cytology triage compared with conventional cytology, and followed up for 5 years.^124^ CIN3+ rates were higher in the intervention group for women younger than 35 years (2.3% vs. 1.9%) (Table 8). The RR for CIN3+ detection in the intervention group among the younger age group was 1.83 (95% CI, 1.21 to 2.78). CIN3+ rates were much lower overall in women age 35 years and older (<0.3% in both the intervention and control groups) but still more frequently detected in the intervention group (RR, 1.56 [95% CI, 1.18 to 2.04]) (Table 7).

No studies provided data on race/ethnicity, screening history, hrHPV immunization status, and socioeconomic status for primary hrHPV testing.

#### Screening With hrHPV Cotesting

Three trials of hrHPV cotesting reported on outcomes by age group (Tables 12 and 13). The SWEDESCREEN trial recruited only women ages 32 to 38 years; overall results of that trial are reported above.^118,^ ^135^ NTCC Phase I included 11,810 women ages 25 to 34 years.^119,^ ^131,^ ^132^ Over two rounds of screening, 17.4 percent of 6,002 women in the intervention group had a positive hrHPV or ASC-US test result compared with an ASC-US positive rate of 4.5 percent of 5,808 women in the control group. Rates of CIN3+ were similar between groups in all rounds: 0.4 percent in Round 1 and 0.1 percent in Round 2 in both groups. Cumulative CIN3+ rates were 0.5 percent in the intervention group and 0.6 percent in the control group, with an RR for CIN3+ overall of 0.91 (95% CI, 0.56 to 1.48) (Table 13). Among the 33,364 women enrolled from ages 35 to 60 years, 17.1 percent of 16,706 women in the intervention group were hrHPV or ASC-US positive compared with 3.6 percent of 16,658 women who were ASC-US positive in the control group. CIN3+ detection was slightly higher in the intervention group in Round 1 (0.3% vs. 0.2% in the control group) and lower in Round 2 (0.03% vs. 0.07% in the control group). Cumulative CIN3+ rates were 0.3 percent in both the intervention and control groups, with an RR of 1.30 (95% CI, 0.87 to 1.19) (Table 12).

The ARTISTIC trial reported outcomes of 5,166 women ages 20 to 29 years.^116,^ ^136–138^ Only results of Round 1 were reported by age group. CIN3+ detection was 3.0 percent of 3,879 women in the intervention group compared with 3.3 percent in the control group. The CIN3+ RR for Round 1 in women ages 20 to 29 years was 0.92 (95% CI, 0.65 to 1.31) (Table 13). Among 19,344 women ages 30 to 64 years, 10.6 percent of 14,507 women in the intervention group tested hrHPV positive. The Round 1 detection of CIN3+ was 0.8 percent of 14,507 women in the intervention group and 0.8 percent of 4,837 women in the control group, with an RR of 1.12 (95% CI, 0.71 to 1.47) (Table 12).

The POBASCAM trial reported outcomes for 6,267 women ages 29 to 33 years over two rounds of screening at 4- to 5-year intervals.^120,^ ^133,^ ^134^ Of 3,139 women in the intervention group, 12 percent had a positive hrHPV test result. In Round 1, CIN3+ detection was 2.2 percent of 3,139 women in the intervention group compared with 1.9 percent of women in the control group. In Round 2, CIN3+ detection was 1.1 percent for women in the intervention group compared with 1.3 percent in the control group. Cumulative CIN3+ detection was 3.3 percent in the intervention group compared with 3.4 percent in the control group, with an RR of 0.97 (95% CI, 0.74 to 1.27) (Table 13). Among 33,838 women ages 34 to 56 years, 4 percent of women in the intervention group were hrHPV positive. CIN3+ was detected among 0.6 percent of 16,860 women in the intervention group compared with 0.5 percent of 16,978 women in the control group in Round 1. In Round 2, CIN3+ was detected in 0.3 percent of the intervention group compared with 0.5 percent in the control group. Cumulative CIN3+ rates were 0.9 percent in the intervention group compared with 1.0 percent in the control group, with an RR of 0.95 (95% CI, 0.76 to 1.18) (Table 12).

A large (n=1,307,528) age-stratified cohort of KPNC patients screened with hrHPV cotesting found 5-year CIN3+ risk was highest among women ages 35 to 39 years and 60 to 64 years (Table 16). Gage and colleagues recently published an age-stratified analysis of 1,313,128 women at KPNC who were screened for cervical cancer from 2003 to 2013.^141^ Women ages 21 to 29 years were screened with conventional cervical cytology while women ages 30 to 64 years were screened with cotesting. Cumulative risks of CIN3+ were reported based on age and cytology finding (Table 16). Women with normal cytology and positive hrHPV test results had repeat cotesting at 12 months. The cumulative incidence of CIN3+ (including baseline screening results) was higher for women ages 21 to 29 years at 3 and 5 years (0.4%) compared to women ages 30 to 64 years (0.3%). The 5-year relative risk of CIN3+ was highest for women ages 25 to 29 years (1.23 [95% CI, 1.09 to 1.39]) and lowest for women ages 50 to 64 years (0.25 [95% CI, 0.22 to 0.28]).

Table 16 Cases and 3-Year and 5-Year Risk of CIN in the KPNC Cotesting Observational Study^123^, ^145^

| | All Women^*^ | Ages 21–29 Years | Ages 30–64 Years | HSIL | LSIL | ASC-US | hrHPV+ and ASC-US | hrHPV- and ASC-US | ASC-US-
N | -- | 1,307,528 | 284,940 | 1,022,588 | 2,771 | 19,096 | 53,107 | 25,336 | 26,191 | 1,232,554
CIN2+ | 3 years | 9,689 (0.7%) | 3,233 (1.1%) | 6,456 (0.6%) | 1,881 (67.9%) | 2,081 (10.9%) | 3,453 (6.5%) | 3,241 (12.8%) | 149 (0.6%) | 2,274 (0.2%)
CIN2+ | 5 years | 11,569 (0.1%) | 3,544 (1.2%) | 8,025 (0.8%) | 1,891 (68.2%) | 2,184 (11.4%) | 3,707 (7.0%) | 3,446 (13.6%) | 198 (0.8%) | 3,787 (0.3%)
CIN2+ | 3-year risk | 1.12 (1.10 to 1.14) | 2.29 (2.22 to 2.37) | 1.05 (1.03 to 1.07) | 71.4 (69.6 to 73.3) | 13.71 (13.17 to 14.27) | 7.86 (7.62 to 8.10) | 15.69 (15.21 to 16.18) | 0.97 (0.85 to 1.10) | 0.47 (0.45 to 0.48)
CIN2+ | 5-year risk | 1.52 (1.49 to 1.54) | 3.20 (3.08 to 3.32) | 1.40 (1.37 to 1.43) | 74.0 (71.9 to 76.1) | 16.37 (15.66 to 17.11) | 9.46 (9.16 to 9.78) | 18.93 (18.30 to 19.57) | 1.49 (1.31 to 1.70) | 0.79 (0.77 to 0.82)
CIN3+ | 3 years | 3,804 (0.3%) | 986 (0.4%) | 2,818 (0.3%) | 1,162 (41.9%) | 611 (3.2%) | 1,130 (2.1%) | 1,060 (4.2%) | 48 (0.2%) | 901 (0.1%)
CIN3+ | 5 years | 4,502 (0.3%) | 1,084 (0.4%) | 3,418 (0.3%) | 1,168 (42.1%) | 644 (3.4%) | 1,240 (2.3%) | 1,154 (4.6%) | 64 (0.2%) | 1,449 (0.1%)
CIN3+ | 3-year risk | 0.44 (0.42 to 0.45) | 0.77 (0.73 to 0.82) | 0.46 (0.44 to 0.47) | 47.5 (45.2 to 49.9) | 4.35 (4.02 to 4.91) | 2.71 (2.57 to 2.87) | 5.60 (5.29 to 5.92) | 0.31 (0.24 to 0.39) | 0.18 (0.17 to 0.19)
CIN3+ | 5-year risk | 0.29 (0.57 to 0.64) | 1.12 (1.05 to 1.19) | 0.59 (0.57 to 0.61) | 50.4 (47.6 to 53.3) | 5.36 (4.91 to 5.85) | 3.39 (3.20 to 3.59) | 7.12 (6.69 to 7.58) | 0.49 (0.39 to 0.61) | 0.30 (0.29 to 0.32)

* Excludes 5,600 women with other high-grade nonnormal result

Abbreviations: ASC-US = Atypical squamous cells of undetermined significance; CG = control group; CI = confidence interval; CIN = cervical intraepithelial neoplasia; HSIL = high-grade squamous intraepithelial lesion; hrHPV = high-risk human papillomavirus; IG = intervention group; KPNC = Kaiser Permanente Northern California; LSIL = low-grade squamous intraepithelial lesion; NR = not reported; yrs = years

### Screening History

Screening history was not described for the RCT participants or the Italian or KPNC cohort studies. Only one study of unscreened women met inclusion criteria. A prospective single cohort study from Spain described the outcomes of initial cotesting with HC2 and cytology (primarily conventional) in a population of 1,832 women older than age 39 years with no record of cervical cytology in the previous 5 years.^121^ Women were referred to colposcopy if either test was positive. No comparison group was included. Followup continued over 5 years; 338 women older than age 65 years with negative testing were excluded from further followup. Of 1,494 remaining women, 767 (51.3%) completed followup. Of the initial group, 101 women had a positive hrHPV test result at baseline and 40 women had abnormal cytology (16 of these also were hrHPV positive) (Table 17). By the last followup, seven women were diagnosed with CIN3, and two women had been diagnosed with ICC (CIN3+ rate, 9/1,832 [0.5%]). All nine women had a positive hrHPV test result at baseline; six had abnormal cytology results at baseline, including both women with ICC. Forty-nine percent of women were lost to followup; loss to followup was greater among women who tested negative on initial screening (p<0.05).

Table 17 Test Positivity, Histological Results, and Referrals to Colposcopy of Other Included Observational Studies of hrHPV Cotesting

Author, Year & Quality | Outcome | Subgroup | Round or Followup | N | Results
Ibanez, 2014^122^ (Unscreened women) Fair | ASC-US+ (including 1 case of suspected adenocarcinoma) | All participants | Baseline | 1832 | 40 (2.2)
Ibanez, 2014^122^ (Unscreened women) Fair | hrHPV+ | All participants | Baseline | 1832 | 123 (6.7)
Ibanez, 2014^122^ (Unscreened women) Fair | hrHPV+/ASC-US+ | All participants | Baseline | 1832 | 139 (7.6)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | hrHPV+ | All participants | 1 | 19795 | 1232 (6.2)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | hrHPV+ | All participants | 2 | 4067 | 146 (3.6)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | ASC-US+ | All participants | 1 | 19795 | 446 (2.2)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | ASC-US+ | All participants | 2 | 4067 | 46 (1.1)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | hrHPV+/ASC-US+ | All participants | 1 | 19795 | 201 (1.0)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | hrHPV+/ASC-US+ | All participants | 2 | 4067 | 7 (0.2)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 19795 | All participants: 765 (3.9)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 2 | 4067 | All participants: 41 (1.0)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 201 | hrHPV+/ASC-US+: 201 (100)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 1031 | hrHPV+/ASC-US-: 536 (52.0)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 245 | hrHPV-/ASC-US+: 28 (11.4)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 18318 | hrHPV-/ASC-US-: 19 (0.1)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 1232 | hrHPV+: 737 (59.8)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Referred to colposcopy | All participants, stratified by cotesting results | 1 | 446 | ASC-US+: 229 (51.3)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 765 | 712 (93.1)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 2 | 41 | 38 (92.7)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 201 | hrHPV+/ASC-US+: 192 (95.5)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 536 | hrHPV+/ASC-US-: 506 (94.4)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 28 | hrHPV-/ASC-US+: 14 (50)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | NR | hrHPV-/ASC-US-: NR (NR)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 737 | hrHPV+: 698 (94.7)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Colposcopy compliance | All participants, stratified by cotesting results | 1 | 229 | ASC-US+: 206 (90.0)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | CIN2+ | All participants | 1 | 19795 | 309 (1.6)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | CIN3+ | All participants | 1 | 19795 | 172 (0.87)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | CIN3+ | All participants | 2 | 4067 | 2 (0.05)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | Adenocarcinoma in situ | All participants | 1 | 19795 | 13 (0.07)
Luyten, 2014^124,^ ^142^ WOLPHSCREEN Fair | ICC | All participants | 1 | 19795 | 20 (0.1)

Abbreviations: ASC-US = atypical squamous cells of undetermined significance CIN = cervical intraepithelial neoplasia; hrHPV = high-risk human papillomavirus; ICC = invasive cervical cancer; NR = not reported

No studies of cotesting provided data on race/ethnicity, hrHPV immunization status, and socioeconomic status.

## KQ1b For Each Primary Screening Strategy, How Does the Rescreening Interval Relate to Future Cancer Incidence or Progression?

Data from trials are not adequate to address outcomes of different rescreening intervals, due to lack of data from direct comparisons of intervals or consistent application of initial screening strategies for more than one screening round. Only one trial (HPV FOCAL) directly compared different rescreening intervals (2-year interval of cytology alone or primary hrHPV testing vs. 4-year interval of primary hrHPV testing), and findings of the interval comparisons have not yet been published. Rescreening intervals in the completed trials ranged from 2 to 4 years for primary hrHPV testing; in trials of cotesting, rescreening intervals were 3 years with the exception of POBASCAM, with a rescreening interval of 5 years. CIN3+ outcomes in POBSCAM were within the range of outcomes from cotesting trials with 3-year screening intervals. No included trials had more than two rounds of screening. Only the ARTISTIC trial had two screening rounds using the assigned screening protocol for each group. All other trials did one round of randomized screening and at subsequent rounds women either all received cervical cytology or all received cotesting.

## KQ1c Does the Appropriate Rescreening Interval for Each Primary Screening Strategy Vary by Subpopulation?

No data were available to address rescreening intervals by subpopulation.

## KQ2 What Are the Potential Adverse Effects of hrHPV Testing, With or Without Cytology, as a Primary Screening Strategy Compared With Currently Recommended Screening Strategies for Women in the United States?

### Summary

None of the included trials reported on or were adequately powered to assess uncommon harms that can occur as a result of biopsy of a positive screening result or treatments of cervical lesions diagnosed after colposcopy. Colposcopy rates were at least twice as high with hrHPV testing, indicating a higher relative burden of testing and potential differences in the downstream consequences of treatment. Similarly, the test positivity rates and FPR of different screening interventions can be an indication of the burden of screening and the risk of downstream harms of treatment. Because of the potential for CIN to regress, the concept of overdetection is relevant to cervical cancer screening.

Test positivity rates were higher in the intervention arm for both hrHPV primary and hrHPV cotesting, particularly for the first screening round (i.e., prevalence round). The FPR was also higher in the intervention arm for the first screening round in the five trials reporting sufficient data for this comparison. The FPR at a second round of screening was similar between arms in one trial of cotesting, but remained higher in the intervention group for another cotesting trial (with high loss to followup). One trial of cotesting reported colposcopy referral rates for more than one round of screening, with higher rates in the intervention arm at Round 1, and more comparable rates at Round 2 (with high loss to followup). Two of the four trials that tested a hrHPV primary screening strategy had similar rates of colposcopy in the intervention and control arms, but in two hrHPV primary screening trial and all trials of cotesting, colposcopy referrals were higher for the intervention arm. None of the trials that tested a hrHPV primary screening strategy reported the test positivity or colposcopy rates for a second round of screening, and initial screening strategies were not maintained for a second round of testing. This limited comparative evaluation of harms beyond a prevalence screen. None of the included studies reported harms occurring from the screening test itself or the diagnostic testing that followed a positive screen.

There was evidence that a hrHPV positive screening result is associated with greater psychological harm than a positive cytology result, including increased anxiety and distress, and lower satisfaction with past and current sexual partners.

The included studies did not provide evidence on differences in adverse effects by any patient characteristic or risk factor other than age. Test positivity and colposcopy rates were higher for younger women (younger than 30 to 35 years) with hrHPV screening strategies; the difference was even more pronounced in one trial reporting rates of colposcopy for women ages 25 to 29 years.

The available trial evidence did not address differences in adverse effects by rescreening interval because none of the included studies was designed to directly compare intervals, and the between-study differences in design, screening strategies, and followup protocols are too great to support inferences about the effects of interval on harms. We could not ascertain from the available evidence how the screening interval and the type of screening strategy related to the potential harms of missed cancer cases and overdetection.

### Study Characteristics

The same eight RCTs, an IPD meta-analysis, and three observational cohort studies described above^110,122,^ ^123,^ ^126^ and included for KQ1 also reported harms outcomes included for KQ2 (Tables 5 and 9). An additional cross-sectional study on psychological harms was also included.^117^ Harms or adverse events associated with hrHPV screening strategies were compared to those associated with cytology-only screening programs. We sought evidence on harms associated with the screening test itself, the test performance of screening (i.e., false-negative and false-positive results), and the procedures conducted as a result of screening (i.e., colposcopy and biopsy). The test positivity for different screening strategies is also presented because the definition of a positive screening test employed in a screening program has implications for referrals to followup, which eventually may include colposcopy and biopsy. Evidence on the psychological effects of screening was also included, such as potential harms of screening related to reduced quality of life, anxiety and distress, partner discord, stigma, and labeling.

As reported for KQ1, the quality of many of the included studies was rated as fair due to problems with attrition, protocol changes, and blinding of outcome assessors. In addition, the overall body of evidence has shortcomings for drawing conclusions due to the limited number of randomized rounds of screening available for comparisons. Several of the trials changed screening or followup protocols after the first round of screening, making it impossible to draw conclusions about harms of screening beyond the prevalence screen. Outcome reporting on colposcopy and biopsy rates was also inconsistent, and none of the trials reported on adverse events associated with the screening tests or the diagnostic and treatment procedures undertaken as a consequence of screening.

### Detailed Results

#### Test Positivity, FPR, Colposcopy, and Biopsy

##### Screening With Primary hrHPV Testing

In NTCC Phase II, any woman with a positive hrHPV test result in the intervention screening condition was referred to colposcopy, as were women in the cytology-alone control condition with ASC-US+ or LSIL+, according to the study protocol.^119,^ ^127^ The test positivity rate at the first round of screening was 7.9 percent (1,936/24,661) for the hrHPV screening intervention arm. In the control group, 3.4 percent (825/24,353) had positive cytology results (ASC-US+). The FPR for CIN2+ was higher (IG, 7.4%; CG, 3.2%) (Table 6). Accordingly, 7.9 percent of women in the intervention group were referred to colposcopy, compared with 2.8 percent of women in the control group (Table 6; Appendix F Table 8). The rate of referrals to colposcopy for the cytology arm was lower than would be expected per trial protocol but was not explained. Most women referred to colposcopy underwent the procedure (IG, 93.6%; CG, 90.6%). Biopsies were taken from 44 percent of colposcopies in the hrHPV screening arm and 52 percent of colposcopies in the cytology control group. More women in the intervention arm had a biopsy based on Round 1 screening (IG, 3.2%; CG, 1.3%). At Round 2, both groups received conventional cytology alone and colposcopy rates were not reported; therefore, the NTCC Phase II trial does not provide evidence on hrHPV-related colposcopy and biopsy harms beyond one round of screening and followup.

The HPV FOCAL trial reported test positivity, colposcopy, and biopsy rates over one round of screening with 4 years of followup data, providing a comparison between hrHPV primary screening and LBC primary screening.^125,^ ^128–130^ More women randomized to the hrHPV primary screening intervention had a positive initial test: 8.2 percent (1,290/15,744) had positive hrHPV results in the intervention, and 3.6 percent (334/9,408) had positive ASC-US results in the LBC comparison arm (Table 6). Nearly twice as many women in the intervention group were referred to colposcopy than in the control group (5.9% vs. 3.1%) on the basis of initial results or hrHPV/LBC triage, and nearly all attended (IG, 97%; CG, 96%). The number of women undergoing a biopsy and the FPR for CIN2+ has not been reported for this trial (Appendix F Table 8).

In the FINNISH trial, hrHPV test positivity was 8 percent (4,971/62,106) in the intervention group and 7 percent (4506/65,747) for ASC-US+ in the cytology comparison group.^124^ The FPR for CIN2+ was similar between the two study arms (IG, 7.2%; CG, 6.5%) (Appendix F Table 7). Of women screened, 1.2 percent (796/66,410) of those in the intervention arm were referred for colposcopy compared with 1.1 percent (755/65,784) in the cytology comparison group (Table 6; Appendix F Table 8). The number of colposcopies attended and biopsies conducted were not reported.

The Compass trial had similar rates of test positivity, with 6.9 percent (277/4,000) in the intervention group and 6.7 percent (67/995) in the control group.^104^ Referrals to colposcopy were 3.8 percent (154/4,000) in the intervention group and 2.7 percent (27/995) in the control group. FPRs were not reported.

An Italian population-based cohort (n=48,751) provides supplemental observational evidence on test positivity and colposcopy referrals for primary hrHPV screening with cytology triage and a 3-year screening interval.^126^ The results are qualitatively consistent with trial evidence, finding that hrHPV test positivity was halved at the second round of screening overall (6.4% vs. 3.5%) (Table 10). Similarly, following ASC-US triage (with 1-year retesting for hrHPV positive/cytology negative), colposcopy referrals were halved from Round 1 to Round 2 (4.4% vs. 2.2%). The rural study setting was thought to account for the lower rates of hrHPV positivity in this study population.

##### Screening With hrHPV Cotesting

Test positivity rates were higher in the hrHPV cotesting arms compared with cytology alone after one round of screening for all included trials testing this comparison (Table 11). The protocol for positive test results differed between trials such that different combinations of results from cotesting had different implications for followup (Appendix F Table 2). In ARTISTIC, for example, positive cytology resulted in immediate colposcopy for HSIL+ or retesting (ASC-US or LSIL), and hrHPV+ test results with normal cytology had a repeat hrHPV test at 12 months.^116,^ ^136–138^ In contrast, the SWEDESCREEN trial referred hrHPV+ with normal cytology to a repeat screen but referred ASC-US or LSIL to immediate colposcopy or a repeat screen at 12 months, depending on the community practice.^118,^ ^135^

All trials reported test positivity at the first round of screening, and two of the trials, ARTISTIC and POBASCAM, also reported test positivity at a second round of screening (Table 11). In the NTCC Phase I trial, 12.5 percent (2,830/22,708) of women in the intervention group tested positive (hrHPV+ or ASC-US+); 9 percent were hrHPV+ (2,021/22,708).^119,^ ^131,^ ^132^ The test positivity rate (ASC-US+) in the control group was 4 percent (855/22,466) of screened women. The FPR for CIN2+ was higher in the intervention group (IG, 12.3%; CG, 3.5%) (Appendix F Table 7). In SWEDESCREEN, the test positivity (for hrHPV+) was 7 percent (433/6,257) in the intervention group and 2 percent (150/6,270) in the control group. The FPR in the control group was 1.2 percent, and was not calculable for the intervention group. In ARTISTIC, the test positivity rate in the intervention group was 22 percent (4,019/18,386), with 16 percent (2,860/18,386) testing hrHPV positive. In the control group, test positivity was 13 percent (786/6,124). At the second round of screening, after 3 years, 11 percent (1,258/11,862) tested positive in the intervention group, and 5 percent (210/3,928) screened positive in the control group. The FPR in ARTISTIC was also higher in the intervention arm at Round 1 (IG, 19.9%; CG, 10.9%) and at Round 2 (IG, 11.2%; CG, 4.6%) (Appendix F Table 7).

In POBASCAM, test positivity was 7 percent (1,406/19,999) in the intervention group and 4 percent (706/20,106) in the control group.^120,^ ^133,^ ^134^ At Round 2, test positivity was the same for both study arms, at approximately 4 percent (IG, 3.8% [742/19,579]; CG, 3.9% [774/19,731]) (Table 11). The FPR was higher in the intervention arm than the control arm at Round 1 (IG, 5.8%; CG, 2.6%) but similar at Round 2 screening, and slightly higher in magnitude than at Round 1 (IG, 6.4%; CG, 6.5%) (Appendix F Table 7).

In the NTCC Phase I trial, colposcopy referral rates were higher in the intervention arm than in the control cytology-only arm (IG, 10.9%; CG, 3.3%) (Appendix F Table 8).^119,^ ^131,^ ^132^ Of those referred, 94 percent in the intervention group and 91 percent in the control group received a colposcopy. In the ARTISTIC trial, referral to colposcopy was similar between study arms at Round 1 (IG, 6.8%; CG, 5.2%) and lower at Round 2 but similar between groups (IG, 2.7%; CG, 2.1%).^116,^ ^136–138^ The proportion of women attending colposcopy and undergoing biopsy was not reported (Appendix F Table 8). Colposcopies and biopsies were not reported in the SWEDESCREEN or POBASCAM trials.

The IPD meta-analysis, which obtained additional data from these cotesting trials, suggests that the overall biopsy rates for all screened women were similar in the intervention and control groups.^139^ In the NTCC trials (combining Phase I and II results), however, biopsy rates were twice as high in the intervention arm where hrHPV+ results were referred directly to colposcopy. The meta-analysis did not report colposcopy rates.

Data published on a cohort of women who received cotesting at KPNC provided U.S. estimates of screening test performance observed in a population with access to coordinated health care (Table 9).^122,^ ^141–143^ The authors reported test positivity rates in a group of 195,975 women with initial negative cotesting results who underwent a second cotesting Round 3 years later. Of the 331,818 women, 24,849 women (7.5%) had a positive hrHPV test result or abnormal cytology result, but the colposcopy rates for test positives were not reported (Table 15). A German prospective observational cohort study included 19,795 women who underwent cotesting with conventional cytology and HC2 testing with a 5-year screening interval.^123,^ ^140^ No comparison group was included. Women with abnormal cytology and negative hrHPV testing and those with positive hrHPV testing and normal cytology underwent repeat cytology at 6 months and hrHPV testing at 12 months, with referral to colposcopy for any abnormal results. At the first round of screening, 4 percent (765/19,795) of women were referred to colposcopy and at Round 2, with a much diminished followup population, an additional 1 percent (41/4,067) of women were referred to colposcopy (Table 17).

#### False-Negative Rates

The occurrence of ICC among women who screened negative in earlier rounds of screening provides some indication of the extent to which a screening program might miss cases, owing to a host of factors that comprise the strategy, including the triage approach, rescreening intervals, and underlying features of the screened population (age, disease prevalence), as well as technical factors relating to test sensitivity and laboratory quality. Estimating false-negative rates is a challenge since women with negative results from hrHPV and cytology screening do not undergo colposcopy. Future rounds of screening may detect ICC, but otherwise identification of false negatives relies on registry data, with cases of cancer more likely to be captured after longer followup periods.

##### Screening With Primary hrHPV Testing

The incidence of ICC among women with negative screening test results was reported at each screening round for two of four included trials (Appendix F Table 9). In NTCC Phase II there were no ICC cases (and no CIN3) among screen-negative women in either group in followup on the first round of screening (3.5 years maximum).^119,^ ^127^ The FINNISH trial reported ICC among screen-negative women in 0.01 percent (5/57,135) of the intervention group and 0.003 percent (2/61,241) of the control group participants after one round of screening with 5 years of followup.^124^ Data on ICC among screen-negative women were not yet available for HPV FOCAL or Compass.

##### Screening With hrHPV Cotesting

In NTCC Phase I, no ICC cases were observed among screen-negative women in either screening arm after the first round of screening and 3.5 years of followup.^119,^ ^131,^ ^132^ SWEDESCREEN did not report ICC rates among screen-negative women.^118,^ ^135^ For ARTISTIC, with 3-year intervals, there were no cases of ICC among screen-negative women in either trial arm for either round of screening.^116,^ ^136–138^ In POBASCAM, which had longer screening intervals than ARTISTIC (5 years), there was 1 case of ICC detected in a screen-negative woman in the control group and no cases in the intervention group during the trial.^120,^ ^133,^ ^134^ Long-term followup data on ICC among screen-negative women in trials was available only from POBASCAM (Appendix F Table 4). With 14 years of followup, there was not a statistically significant difference between study arms in the cumulative incidence of ICC among screen-negative women. In the KPNC cohort, of 1,262,713 women with median 3 years of followup, there were 144 ICC cases that occurred among women with negative cytology, and 95 cases among women with negative hrHPV testing. The cumulative 5-year risk for ICC among women with negative cytology results (regardless of hrHPV test results) was 0.018 percent (95% CI, 0.01 to 0.02), and among women with negative hrHPV testing (regardless of cytology results) it was 0.013 percent (95% CI, 0.01 to 0.02).^115^ In the meta-analysis, among women testing negative at study entry, 12/592,060 women in the pooled intervention group were later diagnosed with ICC compared to 35/525,303 women in the pooled control group. Among these women whose baseline (entry) screening test was negative, the pooled rate ratio in a fixed effects model was 0.30 (95% CI, 0.15 to 0.60). The I^2^ test for statistical heterogeneity was not significant (21.4%; p=0.23).^139^

#### Psychological Effects

We identified two studies that reported on the psychological effects of hrHPV cotesting (i.e., anxiety and distress).^117,^ ^138^ We did not identify any studies that addressed labeling, stigma, partner discord, or quality of life. No studies reported on the psychological effects of primary hrHPV testing.

In ARTISTIC, samples of consecutive women ages 20 to 64 years received information leaflets and questionnaires approximately 2 weeks after receiving cervical screening results. Women randomized to the revealed arm (intervention group) received their hrHPV and cytology results while women in the concealed arm (control group) only received their cytology results. Of 3,582 questionnaires sent, 2,508 (70.0%) were returned (1,904/2,700 in the intervention group and 604/882 in the control group). Measures collected were the General Health Questionnaire (GHQ-28) to measure psychological distress, the Sexual Rating Scale (SRS) to measure sexual satisfaction, and the Spielberger State-Trait Anxiety Inventory (STAI) to measure anxiety. The two groups did not differ in distress or anxiety after receiving their screening results (Table 18), however, women in the intervention group reported lower sexual satisfaction than women in the control group (p=0.042). There were also no differences between groups among women with ASC-US/LSIL cytology in anxiety, distress, or sexual satisfaction. Women with normal cytology who were hrHPV+ in the intervention group had lower sexual satisfaction ratings than women with normal cytology who were hrHPV+ (concealed) in the control group (p=0.003). Observational comparisons of women in the intervention arm showed hrHPV+ (revealed) women with normal cytology were at higher risk of psychological distress (odds ratio [OR], 1.70 [95% CI, 1.33 to 2.17]) with higher GHQ scores (age-adjusted mean difference, 1.43 [95% CI, 0.75 to 2.10]) than women who were hrHPV- with normal cytology; they also reported higher scores for state (age-adjusted mean difference, 2.90 [95% CI, 1.40 to 4.39]) and trait (age-adjusted mean difference, 1.53 [95% CI, 0.16 to 2.92]) anxiety than hrHPV- women with normal cytology. Women who were hrHPV+ with ASC-US/LSIL cytology reported lower sexual satisfaction ratings than women who were hrHPV- with ASC-US/LSIL cytology (age-adjusted mean difference, 8.66 [95% CI, 4.30 to 130.2]). Similar trends were seen between control group women who were hrHPV+ (concealed) and hrHPV- (data not shown).

Table 18 Psychological Harms Reported in the ARTISTIC Trial

Author, Year Quality | Outcome | Subgroup | IG n | IG Results | CG n | CG Results | Odds Ratio or Age-Adjusted Mean Difference (95% CI) | P-Value
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ ≥4, n (%) | All responders | 1872 | 717.0 (38.3) | 593 | 222.9 (37.6) | 1.00 (0.82 to 1.23) | 0.982
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ ≥4, n (%) | hrHPV-/ASC-US- | 972 | 286 (29.4) | 331 | 106 (32.0) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ ≥4, n (%) | hrHPV-/ASC-US+ | 292 | 115 (39.4) | 91 | 36 (39.6) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ ≥4, n (%) | hrHPV+/ASC-US- | 407 | 170 (41.8) | 103 | 36 (35.0) | 1.33 (0.85 to 2.09) | 0.213
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ ≥4, n (%) | hrHPV+/ASC-US+ | 201 | 84 (41.8) | 68 | 32 (47.1) | 0.80 (0.46 to 1.40) | 0.437
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ, mean (SD) | All responders | 1872 | 4.26 (5.73) | 593 | 4.18 (5.71) | −0.01 (−0.65 to 0.60) | 0.968
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ, mean (SD) | hrHPV-/ASC-US- | 972 | 3.31 (5.18) | 331 | 3.22 (4.80) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ, mean (SD) | hrHPV-/ASC-US+ | 292 | 4.22 (5.63) | 91 | 4.29 (5.83) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ, mean (SD) | hrHPV+/ASC-US- | 407 | 4.77 (6.21) | 103 | 4.02 (5.77) | 0.74 (−0.63 to 1.91) | 0.220
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | GHQ, mean (SD) | hrHPV+/ASC-US+ | 201 | 4.57 (5.44) | 68 | 5.75 (6.50) | −1.19 (−2.98 to 0.40) | 0.121
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | SRS, mean (SD) | All responders | 1520 | 53.32 (23.02) | 483 | 54.90 (23.00) | −2.40 (−4.91 to 0.16) | 0.042
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | SRS, mean (SD) | hrHPV-/ASC-US- | 803 | 51.28 (20.89) | 271 | 50.81 (22.50) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | SRS, mean (SD) | hrHPV-/ASC-US+ | 255 | 48.73 (23.34) | 82 | 50.53 (21.26) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | SRS, mean (SD) | hrHPV+/ASC-US- | 311 | 55.32 (22.95) | 76 | 61.10 (23.74) | −7.28 (−12.74 to −1.52) | 0.007
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | SRS, mean (SD) | hrHPV+/ASC-US+ | 151 | 62.67 (23.00) | 54 | 62.46 (22.97) | 0.15 (−6.44 to 6.74) | 0.965
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-STATE, mean (SD) | All responders | 1875 | 38.10 (12.64) | 594 | 38.27 (12.61) | −0.31 (−1.62 to 0.92) | 0.618
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-STATE, mean (SD) | hrHPV-/ASC-US- | 971 | 35.85 (11.92) | 331 | 36.00 (11.49) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-STATE, mean (SD) | hrHPV-/ASC-US+ | 290 | 37.99 (12.43) | 91 | 40.66 (13.57) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-STATE, mean (SD) | hrHPV+/ASC-US- | 410 | 38.87 (13.33) | 103 | 37.10 (12.58) | 1.73 (−1.27 to 4.53) | 0.202
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-STATE, mean (SD) | hrHPV+/ASC-US+ | 204 | 39.77 (12.5) | 69 | 39.97 (12.35) | −0.25 (−3.79 to 3.03) | 0.885
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-TRAIT, mean (SD) | All responders | 1877 | 40.12 (11.40) | 596 | 40.13 (11.49) | −0.10 (−1.27 to 1.13) | 0.858
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-TRAIT, mean (SD) | hrHPV-/ASC-US- | 971 | 38.84 (11.34) | 331 | 39.00 (11.13) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-TRAIT, mean (SD) | hrHPV-/ASC-US+ | 289 | 39.95 (11.08) | 91 | 41.57 (12.43) | NR | NR
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-TRAIT, mean (SD) | hrHPV+/ASC-US- | 413 | 40.54 (11.83) | 105 | 39.39 (10.80) | 1.07 (−1.30 to 3.41) | 0.386
Kitchener, 2009^117,^ ^140^ ARTISTIC Fair | STAI-TRAIT, mean (SD) | hrHPV+/ASC-US+ | 204 | 41.28 (10.89) | 69 | 40.88 (11.54) | 0.36 (−2.80 to 3.53) | 0.819

Abbreviations: ARTISTIC = A Randomised Trial in Screening to Improve Cytology; ASC-US = atypical cells of undetermined significance; CG = control group; CI = confidence interval; GHQ = General Health Questionnaire; hrHPV = high risk human papillomavirus; IG = intervention group; NR = not reported; SD = standard deviation

A cross-sectional study by McCaffery and colleagues evaluated the psychological effects of hrHPV cotesting in 428 women ages 20 to 64 years.^117^ All women were mailed the results of their tests and provided a self-report questionnaire 1 week after receiving test results to assess psychosocial outcomes, including anxiety (STAI), distress (Cervical Screening Questionnaire), and feelings about sexual relationships. Three hundred and eleven (71%) women returned the questionnaires and 271 (63%) were included in the analyses; 69 (25.5%) screened positive for hrHPV and 40 (14.8%) had an abnormal or unsatisfactory cytology smear. Among women with normal cytology, women who were hrHPV+ were significantly more distressed (p<0.0001) and anxious (p<0.0001) than women who were hrHPV- (Table 19). Among women with an abnormal or unsatisfactory cytology smear, women who were hrHPV+ were significantly more distressed (p=0.002) but similarly anxious (no significant difference between groups). Women who were hrHPV+ also tended to have worse feelings about their current, past, and future sexual partners than women who were hrHPV-, regardless of cytology result.

Table 19 Psychological Harms Reported in the Included Observational Studies

Author, Year Quality | Outcome | Subgroup | N Analyzed | Results | Between Group Comparisons
McCaffery, 2004^118^ Fair | CSQ score, mean (95% CI) | hrHPV-/cytology- | 185 | 8.9 (8.4 to 9.3) | hrHPV+ (cytology- vs. cytology +): p=0.0001 hrHPV- (cytology - vs. cytology +): p<0.0001 Cytology+ (hrHPV+ vs. hrHPV-): p=0.002 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | CSQ score, mean (95% CI) | hrHPV-/cytology+ | 17 | 14 (12 to 15) | hrHPV+ (cytology- vs. cytology +): p=0.0001 hrHPV- (cytology - vs. cytology +): p<0.0001 Cytology+ (hrHPV+ vs. hrHPV-): p=0.002 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | CSQ score, mean (95% CI) | hrHPV+/cytology- | 13 | 13 (12 to 14) | hrHPV+ (cytology- vs. cytology +): p=0.0001 hrHPV- (cytology - vs. cytology +): p<0.0001 Cytology+ (hrHPV+ vs. hrHPV-): p=0.002 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | CSQ score, mean (95% CI) | hrHPV+/cytology+ | 23 | 17 (16 to 18) | hrHPV+ (cytology- vs. cytology +): p=0.0001 hrHPV- (cytology - vs. cytology +): p<0.0001 Cytology+ (hrHPV+ vs. hrHPV-): p=0.002 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | STAI score, mean (95% CI) | hrHPV-/cytology- | 185 | 29.8 (27.9 to 31.7) | hrHPV+ (cytology - vs. cytology +): p=0.55 hrHPV- (cytology - vs. cytology +): p=0.0008 Cytology + (hrHPV+ vs. hrHPV-): p=NSD Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | STAI score, mean (95% CI) | hrHPV-/cytology+ | 17 | 41.1 (34.9 to 47.5) | hrHPV+ (cytology - vs. cytology +): p=0.55 hrHPV- (cytology - vs. cytology +): p=0.0008 Cytology + (hrHPV+ vs. hrHPV-): p=NSD Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | STAI score, mean (95% CI) | hrHPV+/cytology- | 46 | 43.5 (39.7 to 47.3) | hrHPV+ (cytology - vs. cytology +): p=0.55 hrHPV- (cytology - vs. cytology +): p=0.0008 Cytology + (hrHPV+ vs. hrHPV-): p=NSD Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | STAI score, mean (95% CI) | hrHPV+/cytology+ | 23 | 46 (40.6 to 51.4) | hrHPV+ (cytology - vs. cytology +): p=0.55 hrHPV- (cytology - vs. cytology +): p=0.0008 Cytology + (hrHPV+ vs. hrHPV-): p=NSD Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about current partner, worse than usual | hrHPV-/cytology- | 162 | 2 (99) | Cytology+ (hrHPV+ vs. hrHPV-): NSD Cytology - (hrHPV+ vs. hrHPV-): p=0.04
McCaffery, 2004^118^ Fair | Feelings about current partner, worse than usual | hrHPV-/cytology+ | 16 | 0 (0) | Cytology+ (hrHPV+ vs. hrHPV-): NSD Cytology - (hrHPV+ vs. hrHPV-): p=0.04
McCaffery, 2004^118^ Fair | Feelings about current partner, worse than usual | hrHPV+/cytology- | 36 | 3 (8) | Cytology+ (hrHPV+ vs. hrHPV-): NSD Cytology - (hrHPV+ vs. hrHPV-): p=0.04
McCaffery, 2004^118^ Fair | Feelings about current partner, worse than usual | hrHPV+/cytology+ | 16 | 2 (13) | Cytology+ (hrHPV+ vs. hrHPV-): NSD Cytology - (hrHPV+ vs. hrHPV-): p=0.04
McCaffery, 2004^118^ Fair | Feelings about future partners, worse than usual | hrHPV-/cytology- | 176 | 3 (2) | Cytology + (hrHPV+ vs. hrHPV-): p=0.02 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about future partners, worse than usual | hrHPV-/cytology+ | 15 | 0 (0) | Cytology + (hrHPV+ vs. hrHPV-): p=0.02 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about future partners, worse than usual | hrHPV+/cytology- | 44 | 12 (27) | Cytology + (hrHPV+ vs. hrHPV-): p=0.02 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about future partners, worse than usual | hrHPV+/cytology+ | 22 | 7 (32) | Cytology + (hrHPV+ vs. hrHPV-): p=0.02 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about previous partners, worse than usual | hrHPV-/cytology- | 23 | 2 (99) | Cytology + (hrHPV+ vs. hrHPV-): p=0.01 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about previous partners, worse than usual | hrHPV-/cytology+ | 45 | 0 (0) | Cytology + (hrHPV+ vs. hrHPV-): p=0.01 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about previous partners, worse than usual | hrHPV+/cytology- | 15 | 15 (33) | Cytology + (hrHPV+ vs. hrHPV-): p=0.01 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001
McCaffery, 2004^118^ Fair | Feelings about previous partners, worse than usual | hrHPV+/cytology+ | 169 | 8 (35) | Cytology + (hrHPV+ vs. hrHPV-): p=0.01 Cytology - (hrHPV+ vs. hrHPV-): p<0.0001

Abbreviations: CSQ = Cervical Screening Questionnaire; hrHPV = high-risk human papillomavirus; STAI = Spielberger’s State Trait Anxiety Inventory

## KQ 2a Do Adverse Effects of hrHPV Compared With Cytology Screening Vary by Subpopulation?

### Age

Test positivity rates were higher at younger ages for hrHPV primary and cotesting interventions, as described above in the results for KQ1. Age-stratified data on colposcopy was available for all three primary hrHPV screening trials, but only one of the hrHPV cotesting trials.

#### Screening With Primary hrHPV Testing

In trials of primary hrHPV screening, differences in colposcopy referral between study arms were more pronounced among younger women. Among women ages 35 to 60 years in the NTCC Phase II trial, 6 percent (1,029/17,724) of women in the hrHPV screening intervention and 3 percent (435/17,747) of women in the cytology-alone control condition were referred to colposcopy at Round 1 screening (Table 7).^119,^ ^127^ In the younger age group (25 to 34 years) in the NTCC Phase II trial, referral to colposcopy was more likely, particularly in the hrHPV screening arm: 13 percent (970/6,937) of women in the intervention group and 4 percent (270/6,788) in the control group were referred to colposcopy (Table 8). The HPV FOCAL trial provided additional data on the youngest women, with colposcopy rates reported for women ages 25 to 29 years and ages 30 to 34 years.^125,^ ^128–130^ Rates of colposcopy were highest among the youngest women assigned to the intervention group (hrHPV with LBC triage) in HPV FOCAL (19.9% of women screened) compared to those ages 30 to 34 years (174/1,612 [10.8%]) and ages 35 to 65 years (487/12,810 [3.8%]). In the FINNISH trial, colposcopy referrals were not as disparate between study arms, possibly owing to the cytology triage protocol.^124^ Two percent of women ages 25 to 34 years were referred to colposcopy (IG, 257/11,191 [2.3%]; CG, 210/11,071 [1.9%]) and 1 percent of women ages 35 to 65 years were referred (IG, 506/55,219 [0.9%]; CG, 544/54,713 [1.0%]). In the Italian cohort,^126^ higher test positivity rates were observed at Round 1 among women ages 25 to 29 years (14.8%) compared to women ages 30 to 64 years (5.5%), and colposcopy referrals were not reported by age (Table 9). More than half of participants in both age groups and in both screening rounds were no longer hrHPV+ when retested at 1 year following an hrHPV+ result with negative triage cytology.

#### Screening With hrHPV Cotesting

Among the trials of hrHPV cotesting screening strategies, colposcopy referrals were reported by age only in NTCC Phase I (estimated from a figure) and only for Round 1 screening.^119,^ ^131,^ ^132^ In the cotesting arm, 12 percent of women ages 25 to 34 years and 11 percent of women ages 35 to 60 years were referred to colposcopy, whereas in the cytology arm, 4 percent of women ages 25 to 34 years and 3 percent of women ages 35 to 60 years were referred. Notably, in this trial detection rates were not significantly different between arms by Round 2, and for the younger age group, were also not significant at Round 1 screening.

No included studies provided data on adverse effects of screening with hrHPV primary or cotesting by race/ethnicity or hrHPV immunization status.

## KQ 2b Do Adverse Effects Vary by Screening Strategy, Including by Rescreening Interval?

The screening intervals of included trials ranged from 3 to 5 years, but none were designed to test differences in colposcopy rates or false negatives with shorter and longer intervals within a trial (Appendix F Table 9). The longest maximum screening intervals tested were in the FINNISH trial^124^ (5 years) and the POBASCAM trial^120,^ ^133,^ ^134^ (4 to 5 years). The shortest intervals were tested in the ARTISTIC trial with two screening rounds at approximately 3-year intervals.^116,^ ^136–138^ There were no ICC cases among women who had screened negative at the previous round. The longer interval trials did identify ICC cases among women who had tested negative, but attribution to the interval is not certain because these trials had larger samples than ARTISTIC, and there were very few ICC cases overall. Specifically, in the FINNISH trial, there were 5 ICC cases (of 57,135 screened) in the intervention group and 2 ICC cases (of 61,241 screened) in the control group after a negative screening result at the first round of screening and 5 years of followup (maximum). The POBASCAM trial reported 13 cases of ICC among women screened with normal cytology in the control arm, and 2 cases of ICC among women with normal cotesting results (i.e., cytology normal, hrHPV negative) over two rounds of screening. In 14 additional years of trial followup there were no statistical differences in ICC cumulative incidence among screen-negative women, but numbers were low, with 4 ICC cases observed among women who were hrHPV- in the intervention group.