# Chapter 2 Methods

## Scope and Purpose

This systematic review evaluated the evidence for the benefits and harms of cervical cancer screening using hrHPV testing with cytology (cotesting) or alone (primary testing). The USPSTF will use this review to update the 2012 recommendation on cervical cancer screening focusing on use of a hrHPV test alone or with cotesting compared to cytology as screening strategies.^90^

## Key Questions and Analytic Framework

In consultation with the Agency for Healthcare Research and Quality (AHRQ) and members of the USPSTF, we developed an analytic framework (Figure 1) and two Key Questions (KQs) to guide our review.

1. What is the effectiveness of hrHPV testing, with or without cytology, as a primary screening strategy for reducing cervical cancer mortality and incidence compared with currently recommended screening strategies for women in the United States?
  a. Does the effectiveness of hrHPV testing to reduce cervical cancer outcomes vary by subpopulation (e.g., age, race/ethnicity, screening history, hrHPV immunization status, and socioeconomic status)?
  b. For each primary screening strategy, how does the rescreening interval relate to future cancer incidence or progression?
  c. Does the appropriate rescreening interval for each primary screening strategy vary by subpopulation (e.g., age, race/ethnicity, screening history, hrHPV immunization status, and socioeconomic status)?
2. What are the potential adverse effects of hrHPV testing, with or without cytology, as a primary screening strategy compared with currently recommended screening strategies for women in the United States?
  a. Do the adverse effects vary by subpopulation (e.g., age, race/ethnicity, and hrHPV immunization status)?
  b. Do the adverse effects vary by screening strategy, including by rescreening interval?

Figure 1 Analytic Framework

The figure is an analytic framework that depicts the two Key Questions described in the Methods section of this report. The figure illustrates how cervical cancer screening programs among females age 21 years or older with a cervix may improve health outcomes (KQ1) and may have possible harms (KQ2).

## Data Sources and Searches

In addition to evaluating all previously included studies for inclusion in the current review, we conducted an initial search of existing systematic reviews related to cervical cancer screening in the following databases: MEDLINE, PubMed, Cochrane Database of Systematic Reviews, and the Database of Abstracts of Reviews of Effects, and the databases or Web sites of various organizations, including AHRQ, the Canadian Agency for Drugs and Technologies in Health, DynaMed, First Consult (via Clinical Key), Health Technology Assessment, the Institute for Clinical Systems Improvement, the Institute of Medicine, the NHS Health Technology Assessment Programme, and the National Institute for Health and Care Excellence from January 2010 through February 25, 2015. The search strategies are listed in Appendix A.

We searched for newly published literature in the following databases: MEDLINE/PubMed, Cochrane Central Register of Controlled Trials, and PsycINFO from January 2011 through February 15, 2017, bridging from the previous USPSTF review with a 1-year overlap. After February 2017, ongoing surveillance continued through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that could affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on May 25, 2018, and resulted in the addition of the initial results of the Compass trial.^104^ The search strategies are listed in Appendix A. We managed literature search results using EndNote^TM^ version 7.3.1 (Thomson Reuters, New York, NY).

## Study Selection

Two investigators independently reviewed titles/abstracts using an online platform (Abstrackr)^105^ and full-text articles against prespecified inclusion and exclusion criteria (Appendix A Table 1). Disagreements were resolved through discussion and consensus or consultation with the other investigators. A list of excluded studies after full-text review, including the reasons for exclusion, is available in Appendix C.

We included good- and fair-quality randomized, controlled trials (RCTs), controlled clinical trials (CCTs), individual participant data (IPD) meta-analyses and systematic reviews, and large cohort studies published in the English language that were conducted among women age 21 years or older. Women younger than age 21 years were excluded on the basis that the current recommendation to screen for cervical cancer with cytology (Pap test) applies to those age 21 years or older. Women in high-risk populations (e.g., women living with HIV), women without a cervix or who have had a hysterectomy (including removal of the cervix), and pregnant women were excluded, as these women may be managed differently with regards to cervical cancer screening. We also required studies to be conducted in primary care or other settings generalizable to primary care in countries categorized as “very high” on the 2014 Human Development Index,^106^ as defined by the United Nations Development Programme, for greater applicability to current cervical cancer screening practices in the United States.

We required studies to evaluate hrHPV screening as either the hrHPV test alone (primary screening) or in combination with cytology (cotesting). Cervical cancer screening strategies that did not include an hrHPV test (e.g., primary cytology-based screening) or used an hrHPV test for a purpose other than primary screening (i.e., cytology with hrHPV triage of abnormal cytology) were excluded. For comparators, we included any cervical cancer screening test, including cytology-based or other hrHPV screening strategies. Studies evaluating the comparative effectiveness of cytology-based screening strategies were excluded.

For KQ1, we included studies if they reported on at least one of the following health outcomes, as defined by USPSTF procedures for evaluating potential benefits of screening:^107^ early detection of disease (CIN2+ or CIN3+), ICC, all-cause or cervical cancer mortality, and quality of life. Our review focused on CIN3+ to define disease, in the absence of cervical cancer or mortality outcomes, based on natural history considerations discussed above. CIN regression rates are higher for CIN1 and CIN2 lesions, and the risk of developing ICC is considerably lower for CIN1/CIN2 than for CIN3. Cervical cancer is rare in screened populations, and cervical cancer mortality even more rare in this group. Disease detection in this review focuses on detection of CIN3+ cases, which include both cancer and the category of intraepithelial neoplasia that is most likely to lead to cancer if left untreated, and have a lower chance of resolving without treatment.

For KQ1, we used the following hierarchy^108^ of cervical cancer–related outcomes for data abstraction and analysis:

- Rank 1: Cervical cancer mortality
- Rank 2: Cervical cancer morbidity/cancer stage IB+ incidence
- Rank 3: Cervical cancer incidence (including microinvasive)
- Rank 4: Reduced CIN3+ incidence or p16 immunohistochemistry-associated high-grade squamous intraepithelial lesion incidence^109^
- Rank 5: Increased detection of CIN3+ (or CIN2+)
  ○ More CIN3+ detection overall (cumulative CIN3+)
  ○ More CIN2+ detection followed by less CIN3+ detection at subsequent screening (note: CIN2+ detection may include overdiagnosis)
- Rank 6: Increased test positivity with increased, similar, or minimally reduced positive predictive value

For KQ2, we included studies if they reported on at least one of the following harms: rates of false-positive or false-negative screening tests for CIN or cancer; biopsy and/or colposcopy rates; and partner discord and other psychological harms (e.g., labeling, stigma, distress, quality of life). The potential harms of treatment, following screening results and diagnostic testing, are discussed, but these outcomes are not generally reported in cervical cancer screening trials.

We applied the following hierarchy to select study designs to answer our KQs: 1) RCTs, 2) comparative cohort studies that provide outcomes/analyses not represented in RCTs, and 3) single-group cohorts that provide outcomes/analyses not represented in RCTs, with priority placed on studies generalizable to U.S.-based clinical practices and health care settings. We excluded studies that were based exclusively on laboratory results and did not have the capacity to track individual women over time. We selected publications that reported on final results only (usually the most recent study publication); publications on interim and preliminary results were excluded (unless they provided detailed methodology).

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of included studies using criteria defined by the USPSTF^110^ supplemented with the Newcastle-Ottawa Scale^111^ for observational studies (Appendix A Table 2). Each study was assigned a final quality rating of good, fair, or poor after investigators resolved any disagreements through discussion. Studies with a single “fatal flaw” (e.g., attrition >40%, differential attrition >20%) or multiple important limitations that could invalidate the results were rated as poor quality and excluded. Studies rated as good quality met all or most of the criteria for the study design (e.g., adequate randomization methods); quality ratings were downgraded if studies did not meet most of the study design–specific criteria but did not have a fatal flaw that could invalidate the results.^112^ Studies included in previous reviews were re-evaluated and not necessarily given the same quality ratings owing to differences in the review scope (KQs and outcomes) or the availability of additional information and data published after the prior review.

One investigator abstracted data from all included studies into a Microsoft Access® database (Microsoft Corporation, Redmond, WA) and a second investigator checked the data for accuracy. We abstracted study design, population demographics, intervention characteristics, screening and round protocols, outcomes, and adverse effects. When necessary, we contacted study authors for data clarifications and requests for final data.

## Data Synthesis and Analysis

Due to the heterogeneity of screening tests, screening protocols, settings, and followup protocols, we did not quantitatively pool results using meta-analysis. We instead conducted a narrative synthesis of the results by screening strategy and age. We generated summary tables and descriptive text detailing the populations, protocols, and the interventions and followup procedures at each round of screening for included studies. The prespecified outcomes were abstracted from each study by KQ, and results were presented in groups defined by the intervention type (primary hrHPV testing or hrHPV cotesting), and when possible, by age. We highlighted the absence of relevant outcomes. We drew inferences when possible, but also highlighted limitations in the evidence.

Results from the included RCTs were generally based on a ‘number of women screened’ denominator, rather than intention-to-treat calculations using all women randomized. These denominators are appropriate since the relative merits of the screening strategies being compared, rather than overall merits of the screening program, are being evaluated. Some results reported in the evidence and summary tables were calculated from data provided in the articles or by authors, as indicated in table annotations.

When possible, we provided data stratified by age because the prevalence of hrHPV is much lower in women age 30 years or older than in women younger than age 30 years.^32^ Cotesting with hrHPV tests in conjunction with cytology is the only FDA-approved strategy in women age 30 years or older.^60^ We defined two age categories: women younger than ages 30 to 35 years and women older than ages 30 to 35 years.

The definition of test positive for this review was defined based on the trial protocol (Appendix F Table 2). Test findings that would lead to a clinical action, based on the study protocol, such as colposcopy or more intensive followup (e.g., retest in 6 months), were defined as test positive. Thus, in some trials, the test positivity rate in the intervention group is simply the rate of hrHPV test positivity, whereas in others it is the rate of hrHPV+ with ASC-US+. We used Bethesda system terminology throughout the review and converted cytological results reported in other terminology systems to the Bethesda system, although there is not exact equivalence (e.g., borderline or mild dyskaryosis is comparable to ASC-US) (Table 1).

For evaluating potential harms or burden of screening, the false-positive rate (FPR) quantifies the chance that a patient experiences a positive screening test result, but histology results are not indicative of precancerous lesions or cervical cancer that would necessitate treatment or active surveillance if detected (CIN2+). Differences in the FPR associated with different screening strategies were estimated by comparing the number of women who do not have histologically confirmed CIN2+ diagnosed prior to or in the screening round following a test positive result (as defined above). FPR was defined as histologically confirmed CIN2+ because this degree of CIN is usually acted on clinically once detected. This definition of FPR is a pragmatic one and relies on colposcopy as a reference standard; however, there is variability in the accuracy of colposcopy and biopsy to detect CIN2+ based on colposcopist training and experience as well as the biopsy protocol.^112^

Differences in colposcopy rates for different screening strategies tested in trials are related to both the test positivity rate and the triage protocols used. Colposcopy is uncomfortable, anxiety provoking, and time consuming. While it is also a necessary step toward diagnosis and treatment, colposcopy due to a false-positive screening test may be considered a harm. Colposcopy may lead to treatments that are associated with an uncommon risk of serious harms. A screening protocol equally effective at identifying CIN3+ cases and preventing ICC, but with more colposcopies, would be evaluated as having greater potential harm.

The false-negative rate was another test performance characteristic evaluated in our analysis of potential screening harms. False-negative rates were defined in this review as the proportion of women with ICC who had negative screening findings at a previous round of screening. Although this is a rare outcome, evidence of differences in the rate of missed cases among screened women is important to consider. Since trials do not generally conduct colposcopies in women with negative screening results, we are not able to accurately estimate the false-negative rates of CIN2 or CIN3. At followup rounds of screening, it is not possible to distinguish between newly emerging CIN2/CIN3 versus cases that were missed on previous screenings. ICC generally evolves slowly, so identification of ICC after a negative screen likely reflects a false-negative result. In addition, cancer registries can be used to identify missed cases.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^113^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) Working Group.^114^ Our method explicitly addresses four of the five Evidence-based Practice Center–required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from May 28, 2015, to June 28, 2015. The draft version of this report was reviewed by experts and USPSTF federal partners. Comments received during any period were reviewed, considered, and addressed as appropriate. A draft version of this report was reviewed by invited external experts and federal partners listed in the acknowledgements. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Additionally, a draft of the full report was posted on the USPSTF Web site from September 12, 2017, through October 13, 2017. Clarifications of the report were made and an additional report on the Kaiser cotesting cohort was included.^115^

## USPSTF Involvement

This systematic review was funded by AHRQ under a contract to support the USPSTF. We consulted with USPSTF liaisons at key points in the review, including the development of the research plan (i.e., KQs, analytic framework, and inclusion and exclusion criteria) and the finalization of the systematic review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted with expert review and public comment on the research plan and draft evidence review. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review.