# Chapter 1 Introduction

## Condition Definition

Two primary histologic abnormalities account for the majority of cancer of the uterine cervix—squamous cell carcinoma (SCC) and adenocarcinoma. The majority of cervical cancer cases (≥70%) are SCC, which is thought to arise from the transformation zone of the cervix.^1^ The transformation zone is the region at the junction between the squamous and columnar cells of the cervix (squamocolumnar junction), which migrates from the exocervix to the distal endocervical canal with advancing age.^2^ Adenocarcinoma, which develops from the mucus-producing cells of the endocervix, accounts for approximately 18 percent of cervical carcinomas. Adenocarcinomas and their precursors (atypical glandular cells [AGC] and adenocarcinoma in situ) are less likely to be detected by cytology than SCC. The remainder of cervical carcinomas are adenosquamous (4%) and other carcinomas (5%) or malignancies (1.5%).^2^

## Cervical Histology

Invasive cervical cancer (ICC) generally develops over a period of years and is preceded by precancerous changes of the cervix. Historically, precancerous changes of the cervix have been histologically defined as cervical intraepithelial neoplasia (CIN), identified at varying levels of severity: CIN1, CIN2, and CIN3. The latter includes carcinoma in situ (CIS), a preinvasive carcinomatous change of the cervix.^3^ The term CIN2+ is used to indicate CIN2 or worse (CIN2, CIN3, or cancer), and CIN3+ is used to indicate CIN3 or worse (CIN3 or cancer). All of the trials and cohort studies in this review used this terminology. In 2012, a consensus group of the American College of Colposcopists and the American Society for Colposcopy and Cervical Pathology recommended changes to this terminology as part of the Lower Anogenital Squamous Terminology (LAST) Standardization Project. In the revised terminology, the primary determination is low grade squamous epithelial lesion (LSIL) or high grade squamous epithelial lesion (HSIL), concordant with the terminology for cytology described below. These designations may be further classified by the applicable CIN subcategorization.^4^ In LAST terminology, CIN1 is considered LSIL, CIN3 is considered HSIL, and CIN2 is considered HSIL but with the qualification that there is less diagnostic certainty regarding this subclassification. Immunohistochemical staining for p16 is recommended to categorize CIN2 as LSIL versus HSIL when there is diagnostic uncertainty. The studies included in this systematic review predate this terminology, so the older (CIN 1, 2, 3) terminology for histology as used by the included studies is found in this review.

## Cervical Cytology

Cervical cytology is a standard screening test for cervical cancer and precancerous changes. The terminology for reporting the spectrum of cervical cytologic abnormalities derives from the 2001 Bethesda Workshop^5^ and is displayed in Table 1.^6^ Atypical squamous cells of undetermined significance, or ASC-US, are the least reproducible of all the cytologic categories and emphasize that a specific diagnosis cannot be made. AGC abnormalities (previously called AGUS) may be reported as endocervical, endometrial, or not otherwise specified. The percentage of AGC Pap tests associated with underlying higher-grade lesions or disease (CIN2+) is higher than for ASC-US.^6^ High-grade squamous or glandular lesions can be seen in 10 to 39 percent of cases of AGC.^6^ LSIL, as used to describe a cytology result, includes cellular high-risk human papilloma virus (hrHPV) changes and generally corresponds to histology classified as CIN1. HSIL encompasses moderate to severe neoplasia and CIS—a preinvasive carcinomatous change of the cervix—and generally corresponds to histology classified as CIN2 and CIN3. The term ASC-US+ is used to indicate ASC-US or worse cytology, LSIL+ to indicate LSIL cytology or worse, and HSIL+ to indicate HSIL cytology or worse. Cervical cytology results are not diagnostic of neoplasia or cancer; biopsy and histologic confirmation are required for diagnosis.

Table 1 Cytology Test Result Categories, the 2001 Bethesda System

Acronym | Description
ASC-US | Atypical Squamous Cells of Undetermined Significance
ASC-H | Atypical Squamous Cells – cannot exclude HSIL
LSIL | Low-grade Squamous Intraepithelial Lesion Includes human papillomavirus infection/mild dysplasia/CIN 1
HSIL | High-grade Squamous Intraepithelial Lesion Includes moderate and severe dysplasia, CIN2/3, and carcinoma in situ
AGC | Atypical Glandular Cells (specify endocervical or not otherwise specified [NOS])
--- | Atypical Glandular Cells, favor neoplastic (specify endocervical or not otherwise specified [NOS])
AIS | Endocervical Adenocarcinoma In Situ
AdenoCa | Adenocarcinoma
SCC | Squamous Cell Carcinoma

## Etiology and Natural History

The recognition of hrHPV as a causative agent in more than 90 percent of cervical cancers has revolutionized the approach to prevention and screening.^7^ Progression from hrHPV infection to cervical cancer occurs over a series of three steps: 1) hrHPV transmission resulting in acute hrHPV infection, which may resolve or persist; 2) persistent hrHPV infection leading to precancerous changes; and 3) development of ICC.^8^ Transmission of hrHPV to the anogenital region occurs primarily as a result of skin-to-skin or mucosa-to-mucosa sexual contact.^8,^ ^9^

A high proportion of sexually active women become infected with HPV of all types, but most infections resolve spontaneously and only a small proportion persist. HPV infection is more than 44 percent among sexually active women younger than age 25 years, and incidence declines with increasing age.^10^ About 5 percent of HPV infections persist at 2 years, and persistent infection with hrHPV is responsible for most CIN and ICC.^11–14^ A 2011 meta-analysis of hrHPV type-specific prevalence data reported hrHPV detection in 90 percent of cervical cancers worldwide.^15^ The 12 most common hrHPV types identified by the meta-analysis, in order of decreasing prevalence, were hrHPV 16, 18, 58, 33, 45, 31, 52, 35, 59, 39, 51, and 56,^15^ with hrHPV types 16 and 18 accounting for approximately 70 percent of cervical cancers.^15,^ ^16^ A recent U.S.-based study detected hrHPV in 91 percent of cervical cancers (51% hrHPV 16, 16% hrHPV 18, and 24% other oncogenic types).^17^ Risks associated with hrHPV infection are type-specific, with types 16 and 18 conferring the highest risk for hrHPV persistence and progression to high-grade lesions, although even these types are likely to clear in young women.^18,^ ^19^

### Regression, Progression, and Persistence

Regression of HPV infection is presumably due to a successfully mounted immune response,^20^ and increased persistence of hrHPV infection is observed in immunocompromised populations.^21,^ ^22^ It is unknown whether viral infections resolve as a result of complete clearance of the virus or by maintenance of the virus in a latent state.^8^ While cohort studies have demonstrated that a viral type can reappear even after it has been thought to have cleared,^14^ incident hrHPV infections confer a lower risk given the high probability of clearance and the long time period between hrHPV infection and cancer development, particularly among older women.^23^

Regression of histologically diagnosed lesions also can occur subsequent to hrHPV infection-induced neoplasia. Regression rates are higher for CIN1 than for CIN3, while CIN2 is a less reproducible diagnosis, and is likely a mixture of CIN1 and CIN3. In a historical cohort of about 20,000 Toronto women during a period when lesions were managed conservatively, regression from CIN2 to a second normal test occurred in 6.9 percent within 2 years, 29.0 percent within 5 years, and 53.7 percent within 10 years.

Progression of neoplasia to ICC is slow. The rate of progression of CIN3 to cancer has recently been estimated as 31.3 percent in 30 years. This rate was determined using retrospective data from an unethical clinical study in New Zealand between 1965 and 1974 that left a number of women with CIN3 disease incompletely treated or untreated.^3^ Other rough estimates from early studies of women with precancerous cell changes suggest a 20 to 30 percent risk of ICC over a 5- to 10-year time frame.^24,^ ^25^ In the historical cohort described above, less than 1 percent (0.3%) of CIN2 lesions progressed to ICC within 2 years, 0.7 percent progressed within 5 years, and 1.2 percent progressed within 10 years.^26^ Rates of CIN3 progression to ICC were considerably higher (1.6% within 2 years, 2.6% within 5 years, and 9.9% within 10 years).

Using composite data from cytology, histology, or both to define CIN lesions, a review summarized studies published between 1950 and 1990 on persistence, regression, and progression of CIN.^27^ Over followup of 1 to 25 years, regression was most common for CIN1 (57% regressed, 32% persisted, and 1% progressed). For CIN2, 43 percent regressed, 35 percent persisted, and 5 percent progressed to cancer. For CIN3, regression rates were 32 percent, persistence rates were 56 percent, and progression rates were greater than 12 percent. Available data on CIN progression and regression have not discussed treatment for CIN3 specifically or its effect on the results reported, although factoring in treatment is clearly important.

Newer data suggest that CIN1 due to HPV infection does not predict any meaningful risk of progression to CIN3.^8,^ ^28^ In addition, CIN1 diagnoses in the United States are poorly reproduced,^8,^ ^28^ which has also been established recently for CIN2 diagnoses in the United States and other countries.^29,^ ^30^ Despite poor reproducibility, data from the ASC-US-LSIL Triage Study (ALTS) have been used to estimate that up to 40 percent of CIN2 detected through colposcopy referral after positive primary screening tests (cytology and hrHPV) in younger women may regress, particularly in the presence of less severe cytology such as ASC-US+, LSIL+, or hrHPV positive tests that are not hrHPV 16 positive.^31^

## Prevalence and Burden of Cervical Cancer and hrHPV

Cervical cancer incidence and mortality have substantially decreased since the introduction of screening programs more than half a century ago.^32^ The cumulative age-adjusted incidence from 2009 to 2013 was 7.5 cases per 100,000 women per year; the age-adjusted mortality rate over the same period was 2.3 deaths per 100,000 women per year.^32^ There were an estimated 12,990 new cases of cervical cancer and 4,120 deaths in 2016.^33^ In Surveillance, Epidemiology, and End Results (SEER) Program data, the median age at diagnosis was 49 years,^32^ and 48 percent were among women ages 35 to 54 years (Table 2). Black (8.9 cases per 100,000 persons) and Hispanic (9.4 cases per 100,000 persons) women had higher incidence rates (Table 3).^32^ Cervical cancer mortality was greatest among women ages 45 to 64 years (47.6%) (Table 2). Mortality for black (3.9 deaths per 100,000 persons) and American Indian/Alaskan Native (3.2 deaths per 100,000 persons) women was greater than for white (2.1 deaths per 100,000) women (Table 3).^32^ A recent analysis of National Center for Health Statistics data (2000-2012) that adjusted for differences in the hysterectomy rate by race/ethnicity found much higher mortality disparities than previously recognized.^34^ For black women, the corrected mortality rate rose to 10.1 deaths per 100,000 women (uncorrected rate, 5.7 deaths per 100,000 women). In contrast, the adjusted rate for white women was 4.7 deaths per 100,000 women. The study demonstrated that without the correction for hysterectomy, the disparity in mortality between races was underestimated by 44 percent. Correction for hysterectomy also indicated increasing cervical cancer mortality rates with age, particularly for black women, with corrected mortality rates greater than 30 deaths per 100,000 women for black women age 80 years and older.^34^

Table 2 SEER Percent of Incident Cases and Deaths From Cervical Cancer by Age Group, 2010–2014

Age Group (years) | Incident Cases | Deaths
<20 | 0.1 | 0.0
20–34 | 13.9 | 5.2
35–44 | 23.8 | 13.4
45–54 | 23.8 | 23.3
55–64 | 18.7 | 23.9
65–74 | 11.2 | 16.5
75–84 | 5.8 | 11.2
>84 | 2.7 | 6.4

Table 3 SEER Average Age-Adjusted Annual Cervical Cancer Incidence and Mortality Rates per 100,000 Women by Race/Ethnicity, 2010–2014^32^

Race/Ethnicity | Incidence^*^ | Mortality^*^
All Races | 7.4 | 2.3
White | 7.4 | 2.1
Black | 8.7 | 3.8
American Indian/Alaska Native | 7.7 | 2.8
Asian/Pacific Islander | 6.1 | 1.7
Hispanic | 9.1 | 2.6

* Rates not adjusted for hysterectomy status.

Rates of incident cervical cancer in SEER 2013 data have decreased from 7.9 to 6.8 cases per 100,000 persons between 2004 and 2014, while overall cervical cancer mortality has declined only slightly in the same time frame, from 2.4 to 2.3 deaths per 100,000 women.^32^ The steady fatality rate primarily results from a large proportion of incident cases and deaths occurring with late presentation among unscreened women (i.e., those who have not been screened in the past 5 years), as well as those screened but lost to followup, highlighting the continued importance of improving access to cervical cancer screening and followup.^27,^ ^35–38^ A recent age-adjusted analysis of national cancer mortality by county identified particularly high rates of cervical cancer mortality in the southern United States along the Mississippi River, in southern Alabama, and a few counties in South Carolina, Georgia, and South Dakota.^39^

HPV is the most common sexually transmitted infection in the United States. The estimated prevalence of hrHPV among women in the United States ages 18 to 59 years was 20.4 percent based on data from the 2013 to 2014 National Health and Nutrition Examination Survey (NHANES).^40^ The prevalence has been shown to vary by age, race/ethnicity, and sexual history (Table 4).^40,^ ^41^ HPV infections were most common among young women ages 18 to 24 years (56.1%), black women (63.2%), women with an income-to-poverty ratio of less than 130 percent (55.3%), and women with a greater number of lifetime sexual partners (≥11 partners, 60.7%). Many infections regress within a few years; however, those that persist may lead to cervical cancer.^27^

Table 4 Weighted Prevalence of HPV Among Females Ages 18 to 59 Years, National Health and Nutrition Examination Survey, 2007–2010^41^ and 2013–2014^40^

Characteristic | Variable | Any HPV, % | High-Risk^*^ HPV (With or Without Low-Risk HPV), %
All women^40^ | -- | 39.9 | 20.4
Age, years^41^ | 18–24 | 56.1 | --
Age, years^41^ | 25–29 | 50.8 | --
Age, years^41^ | 30–34 | 40.1 | --
Age, years^41^ | 35–39 | 38.3 | --
Age, years^41^ | 40–44 | 34.5 | --
Age, years^41^ | 45–49 | 44.4 | --
Age, years^41^ | 50–54 | 33.4 | --
Age, years^41^ | 55–59 | 34.0 | --
Race/ethnicity^40^ | White, non-Hispanic | 36.5 | 18.7
Race/ethnicity^40^ | Black, non-Hispanic | 63.2 | 28.2
Race/ethnicity^40^ | Asian, non-Hispanic | 23.2 | 11.6
Race/ethnicity^40^ | Hispanic | 38.5 | 21.6
Education^41^ | Less than high school | 48.0 | --
Education^41^ | High school graduate | 47.5 | --
Education^41^ | Some college | 43.5 | --
Education^41^ | ≥ college graduate | 31.4 | --
Ratio of family income to poverty^41^ | ≥350% | 33.3 | --
Ratio of family income to poverty^41^ | 130–349% | 43.0 | --
Ratio of family income to poverty^41^ | <130% | 55.3 | --
Total lifetime sexual partners^41^ | 0–1 | 14.8 | --
Total lifetime sexual partners^41^ | 2–3 | 31.2 | --
Total lifetime sexual partners^41^ | 4–5 | 45.8 | --
Total lifetime sexual partners^41^ | 6–10 | 54.3 | --
Total lifetime sexual partners^41^ | 11+ | 60.7 | --
Total sexual partners within the past year^41^ | 0 | 33.7 | --
Total sexual partners within the past year^41^ | 1 | 37.3 | --
Total sexual partners within the past year^41^ | 2 | 74.8 | --
Total sexual partners within the past year^41^ | ≥ 3 | 85.2 | --

Note: 2007–2010 survey: n=3,738; 2013–2014 survey: n=NR.

* High-risk HPV types: 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 66, 68.

Abbreviations: HPV = human papillomavirus; NR = not reported

From 2004 to 2007, the estimated annual direct medical cost for routine cervical cancer screening was $5.4 billion, with an additional $1.2 billion in followup of abnormal results.^42^ The estimated annual direct medical cost of cervical cancer treatment was $441 million.^42^

## Risk Factors

The risk of acquiring hrHPV dramatically increases with the number of lifetime sexual partners.^21,^ ^33,^ ^41^ Coinfection with other sexually transmitted agents such as chlamydia trachomatis may also be associated with risk of hrHPV infection.^43,^ ^44^ Additional independent risk factors for cervical precancer and cancer include long-term use of oral contraception, high parity, and cigarette smoking.^33,^ ^45–47^ Smoking is significantly associated with an increased risk of SCC among current smokers compared with never-smokers, but not associated with the risk of cervical adenocarcinoma.^48^ Geographic and racial/ethnic disparities remain, with Southern states having higher rates of cervical cancer, and non-Hispanic black and Hispanic women having higher cervical cancer incidence and mortality. Women with lower socioeconomic status have higher rates of cervical cancer mortality.^49^ Cervical cancer incidence rises with age, and is believed to arise from persistent hrHPV infections from exposures earlier in life.^50^ Persistent early infection, later in life incident infections, and reactivation of earlier infections could contribute to cervical cancer, but interactions between hrHPV exposure timing, infections with multiple types, and aging are not fully understood.^51^

## Screening Strategies

Screening for cancerous or precancerous changes of the cervix in developed countries begins with two types of tests: cytology-based screening and hrHPV testing (Appendix A). Microscopic evaluation of cervical cells was the progenitor screening test, traditionally performed by scraping cells from the cervix and fixing them on a glass slide in a method developed by Georgios Papanicolaou. This test, commonly referred to as the Pap test, is used to identify abnormal cells (e.g., ASC-US, LSIL) immediately after collection. Liquid-based cytology (LBC), another cytology-based screening method, differs from conventional cytology in sample preparation. The cervical cells are first suspended in a liquid fixative by swirling the collection device in the fixative (ThinPrep, Hologic, Inc., Bedford, MA)^52^ or by placing the collection device in the fixative (SurePath, TriPath Imaging, Burlington, NC).^53^ Cells are then suspended, collected by filtration, and transferred onto a monolayer for microscopic evaluation. Conventional cytology and LBC have similar test performance characteristics (e.g., sensitivity, specificity) for the detection of CIN2+ and CIN3+.^54^ The effectiveness of cytology for cervical cancer screening is well established.^54^

This review addresses the benefits and harms of cervical cancer screening with primary hrHPV testing (testing with hrHPV alone) or as cotesting with cytology. Assay methods for detecting hrHPV include a variety of platforms used to detect hrHPV. Most use either signal or nucleic acid amplification methods.

### U.S. Food and Drug Administration–Approved hrHPV Tests

The U.S. Food and Drug Administration (FDA) has approved five different hrHPV tests (Hybrid Capture 2 [HC2],^55^ cobas hrHPV [Roche Molecular Systems, Inc., Pleasanton, CA],^56^ APTIMA hrHPV Assay [Gen-Probe, Inc., San Diego, CA],^57^ Cervista hrHPV 16/18,^58^ and Cervista high-risk hrHPV [Hologic, Inc., Bedford, MA])^59^ for testing patients with abnormal cytology results to determine the need for colposcopy referral and for use in women age 30 years or older in conjunction with cytology (cotesting) to assess absence or presence of hrHPV. In 2014, the cobas hrHPV test was the first to be approved by the FDA as a primary cervical cancer screening test for women age 25 years or older.^60^ Randomized trials of cotesting used the HC2 assay or the GP5+/6+ PCR enzyme immunoassay (not used in the United States), and the large Kaiser cohort reports on cotesting also used HC2. All four randomized trials of hrHPV testing alone (primary screening) used HC2, although this test has not been FDA-approved for primary screening. A recent systematic review compared HC2 and CP5+/6+ to newer hrHPV tests, including those listed above. Of tests approved in the United States, HC2 was considered a reference standard; similar test performance characteristics were found for the APTIMA and Cervista assays, but only cobas 4800 HPV was found to fully meet 2009 international expert committee equivalency criteria.^61^

Because of the high frequency of transient HPV infection in women younger than age 30 years leads to many positive hrHPV tests and subsequent diagnostic and treatment interventions (with potential to cause harm) for infections that are likely to resolve spontaneously,^62^ hrHPV cotesting has not been recommended for cervical cancer screening in women younger than age 30 years.^63,^ ^64^ However, the recent FDA approval of cobas hrHPV for primary screening in women age 25 years and older prompted the American College of Obstetrics and Gynecology to add primary hrHPV testing beginning at age 25 to its screening recommendations in 2016.^63^

### Self-Collection

Vaginal self-sampling—or self-collection—for hrHPV testing could improve screening rates among underscreened or unscreened women as it reduces some of the barriers to cervical cancer screening (e.g., discomfort, inconvenience, cost, and accessibility of a clinician visit). Self-collection has women collect cervical or vaginal material using swabs, brushes, tampons, or lavage devices and send their samples to a health care provider or laboratory for analysis. Clinical followup is required for abnormal results. This screening alternative has not been widely evaluated in the United States and is not FDA approved. Evidence from other settings has prompted interest in its potential to reach unscreened women if the test accuracy and followup of positive test results are comparable to office-based screening. Lower accuracy and followup adherence might be viewed as sufficient, however, if self-collection increases overall screening, followup, and treatment among high-risk, unscreened women who are not responsive to other screening opportunities.

### Followup Protocols

Whatever screening test is used, protocols for followup of abnormal test results will influence the frequency of both benefits and harms of cervical cancer screening. For cervical cancer screening to make a difference, once abnormal screening results are identified, followup with surveillance and/or treatment are required. Followup may include triage or subsequent testing with cytology or hrHPV testing, identification of the specific hrHPV type, and colposcopy (visualization of the cervix under magnification) with biopsy. Protocols vary depending on the severity of the abnormal result, and algorithms have been published,^65^ but there is no clear consensus across organizations on preferred diagnostic and followup strategies. Followup strategies employ repeat testing with hrHPV and/or cytology at variable intervals, and differ on at what point evaluation with colposcopy and biopsy is recommended.^66^ Early or more frequent use of colposcopy and biopsy leads to higher CIN detection rates but reduces opportunities for low-grade CIN to regress without intervention, and may lead to higher rates of treatment with potential for associated harms.

## Prevention of hrHPV Infection

HPV vaccination helps prevent disease by reducing individual- and population-level infection with hrHPV types. HPV vaccination is most effective when administered before exposure to hrHPV.^67,^ ^68^ Currently, three vaccines are approved in the United States that protect against hrHPV infection; however, as of late 2016, the GARDASIL® 9 vaccine was the only one being distributed.^69^ Licensed in 2006, the quadrivalent HPV vaccine GARDASIL® protects against hrHPV types 16 and 18, the cause of 70 percent of cervical cancers, and HPV types 6 and 11, which cause 90 percent of genital warts.^70–78^ In 2009, the bivalent hrHPV vaccine (2vHPV) CERVARIX® was also licensed to protect against hrHPV types 16 and 18.^70^ In 2014, the FDA approved GARDASIL® 9 (9vhrHPV), which protects against the same HPV types covered in the quadrivalent HPV vaccine (hrHPV types 16 and 18 and HPV types 6 and 11), and five additional high-risk oncogenic strains (31, 33, 45, 52, 58) that account for 15 percent of cervical cancers.^79^

Recommendations for routine vaccination against HPV have been issued by the Advisory Committee on Immunization Practices (ACIP), a subsidiary component of the Centers for Disease Control and Prevention’s national vaccine program, which recommends routine HPV vaccination for both sexes starting at age 11 or 12 years.^69^ Children as young as age 9 years may receive the vaccine. Additionally, the ACIP recommends that females and males who were not adequately vaccinated previously receive the vaccine through ages 26 and 21 years, respectively. For children younger than age 15 years, a two-dose schedule is now recommended based on evidence of sufficient immunogenicity for these ages, with the second dose administered 6 to 12 months after the first dose. For individuals who initiate the vaccine after the age of 15 years, a three-dose schedule is still recommended, with the second dose administered 1 to 2 months after the first and the third dose administered 6 months after the first dose.^69^ The recent introduction of a two-dose or alternative simplified dosing schedule increases convenience for providers, parents, and vaccine recipients; reduces costs; and facilitates implementation of vaccines (i.e., reduces logistical challenges, decreases resources).^80^ ^81^ The two-dose schedule is expected to result in an increased proportion of children younger than age 15 years who have completed the recommended series.

In 2015, the first U.S.-based cohort of vaccinated women reached 21 years of age and became eligible for cervical cancer screening. Low rates of vaccination uptake initially and the lead time needed to observe effects limit conclusions that can be drawn regarding the impact of vaccination on cervical cancer incidence in the United States, but recent studies documenting declines in hrHPV infection and high-risk lesions among vaccinated women are encouraging.^82–85^ A systematic review found that in countries with greater than 50 percent vaccination coverage, hrHPV type 16 and 18 infections decreased significantly by 68 percent (relative risk [RR], 0.32 [95% CI, 0.19 to 0.52]) in girls ages 13 to 19 years between prevaccination and postvaccination periods. There was also evidence of cross-protection against other types with higher rates of vaccine uptake.^83^ An Italian consensus conference recently addressed the potential need for changes to screening recommendation based on broad population coverage with the HPV vaccine, and recommended a tailored screening approach, with screening at age 30 years for women vaccinated by age 12 years.^84^ Based on data from 2008 to 2012, HPV was estimated to cause more than 90 percent of cervical cancers and over 24,600 hrHPV-associated cancers (e.g., cervical and oropharyngeal cancer) occur among women in the United States each year.^85,^ ^86^ Since the HPV vaccine was recommended for females ages 11 to 12 years through 26 years in 2006, NHANES data (2009-2012) demonstrates a 64 percent decrease in quadrivalent vaccine HPV-type prevalence among females ages 14 to 19 years and a 34 percent decrease among females ages 20 to 24 years.^87^

Although uptake of the HPV vaccine in the United States has been slow, results from the 2015 National Immunization Survey-Teen (NIS-Teen) revealed a steady increase in HPV vaccination coverage among adolescents since its introduction in 2006 for females and 2011 for males. Coverage with one or more doses of any HPV vaccine increased from 25.1 percent in 2007 to 62.8 percent in 2015 among adolescent girls, and from 8.3 percent in 2011 to 49.8 percent in 2015 among adolescent boys.^88,^ ^89^ Coverage with three or more doses increased from 5.9 percent in 2007 to 41.9 percent in 2015 among females, and from 1.3 percent in 2011 to 28.1 percent in 2015 among males.^88^

## Current Clinical Screening Practice in the United States

In 2012, the U.S. Preventive Services Task Force (USPSTF) recommended initiating cervical cancer screening at age 21 years, screening women every 3 years with cytology or, among women ages 30 to 65 years, cytology in combination with hrHPV testing every 5 years, and to stop screening women with a hysterectomy or those older than age 65 years with a history of regular screening with negative results. These recommendations applied to women at average risk of cervical cancer.^90^ At the same time, similar recommendations were released in a joint guideline by the American Society for Colposcopy and Cervical Pathology (ASCCP), the American Society for Clinical Pathology (ASCP), and the American Cancer Society (ACS). The recommendations of other organizations published since the 2012 USPSTF recommendation are in Appendix B; many endorse either the USPSTF recommendations or the joint recommendations by ASCCP/ASCP/ACS.

Interim guidance from an expert panel cosponsored by the Society of Gynecologic Oncology (SGO) and the ASCCP was published in 2015 for primary hrHPV screening, and discussed initiation of screening with hrHPV testing alone at age 25 years; this option was also included in an interim update to an ACOG Practice Bulletin in 2016.^63,^ ^66^ Evidence supporting these revisions came from the Addressing the Need for Advanced hrHPV Diagnostics (ATHENA) study, where 30 percent of CIN3+ cases were identified in women ages 25 to 29 years, and 37 percent of cases were identified in women ages 30 to 39 years.^91^ In that study, 44 percent of women between ages 25 and 29 years with CIN3+ had abnormal cytology and 57 percent had a positive cobas HPV test;^91^ however, the AGO/ASCCP panel issuing the interim guidance noted that progression to cancer is uncommon in this age group and detection of disease in the 25- to 29-year-old age group can be safely deferred until age 30 years and older.^66^ Age to stop screening was not specifically addressed.

Although cervical cancer screening programs have reduced the incidence and mortality of cervical cancer over the past 50 years, most screening in the United States is opportunistic, without population-based registries or regular invitations to screening. Organized cervical cancer screening programs are not widely available to women in the United States, and a sizeable proportion of the U.S.-based female population is not routinely screened. An estimated 8 million (11.4%) women in the United States ages 21 to 65 years had not been screened in the previous 5 years based on data from the 2012 Behavioral Risk Factor Surveillance System; these rates varied by age, race/ethnicity, and health insurance status.^92^ The highest proportions of unscreened women among screening-eligible women were in those of younger (ages 23 to 29 years) or older (ages 60 to 65 years) ages, Asian/Pacific Islanders (19.7%) or American Indian/Alaska Natives (16.5%) and those without insurance (23.1%) or no regular health care provider (25.5%). Among women diagnosed with ICC, less than half had received a Pap test in the 5 years before diagnosis even though they had the opportunity to be screened.^36^ Reasons for not being screened include a lack of access to health care (e.g., lack of insurance) and other barriers (e.g., discomfort with the examination, cultural or religious beliefs, or socioeconomic status limiting resources needed to access care).

Most disparities in cervical cancer incidence and mortality are postulated to be attributable to differential access to screening and inadequate followup after abnormal screening results.^93^ In an analysis of 10,000 women in the National Breast and Cervical Cancer Early Detection Program (NBCCEDP), 44 percent with low-grade abnormalities in the two sequential Pap tests were followed up with colposcopy, while 56 percent were followed up with a third Pap test or not at all.^93^ American Indian or Alaska Native women had the highest percentages of a third Pap test, and non-Hispanic black women had a higher percentage of no followup.^93^ More than half of the women studied were not followed up in accordance with established guidelines for management of abnormal cervical cytology.^93^ Even for women with access to services, clinician adherence to recommended screening varies by provider specialty, geographic location, personal characteristics, and knowledge, and can also be influenced by patient expectations and preferences. ^94–102^

## Previous USPSTF Recommendations

As mentioned previously, in 2012 the USPSTF recommended screening for cervical cancer in women ages 21 to 65 years with cytology (Pap test) every 3 years or screening with a combination of cytology and hrHPV testing every 5 years for women ages 30 to 65 years who want to lengthen the screening interval (A recommendation).^90^ It also recommended against screening for cervical cancer with hrHPV testing, alone or in combination with cytology, in women younger than age 30 years (D recommendation); screening for cervical cancer in women younger than age 21 years (D recommendation); screening for cervical cancer in women older than age 65 years who have had adequate prior screening and are not otherwise at high risk for cervical cancer (D recommendation); and screening for cervical cancer in women who have had a hysterectomy with removal of the cervix and who do not have a history of high-grade precancerous lesion (CIN grade 2 or 3) or cervical cancer (D recommendation).

In 2003, the USPSTF strongly recommended screening for cervical cancer in women who have been sexually active and have a cervix (A recommendation).^103^ It also recommended against routinely screening for cervical cancer in women older than age 65 years if they have had adequate recent screening with a normal Pap test and are not otherwise at high risk for cervical cancer (D recommendation), and against routine screening in women who have had a total hysterectomy for benign disease (D recommendation). At the time, the evidence was insufficient to recommend for or against the routine use of new technologies (such as LBC or automated screening) to screen for cervical cancer (I statement) and to recommend for or against the routine use of hrHPV testing as a primary screening test for cervical cancer (I statement).