# Appendix F Evidence Tables

Appendix F Table 1 Baseline Population Characteristics of Included Trials, Ordered by Screening Approach

Appendix F Table 2 Screening, Treatment, and Subsequent Testing Protocols in Included Trials, Ordered by Screening Approach

Appendix F Table 3 Intervention and Control Group Descriptions in Included Trials, Ordered by Screening Approach

Appendix F Table 4 Cumulative Incidence of CIN and Invasive Cervical Cancer in Screen-Negative Women From the Long-Term Followup of Two Randomized, Controlled Trials

Appendix F Table 5 Baseline Population Characteristics of Included Observational Studies

Appendix F Table 6 Intervention and Control Group Descriptions in Included Observational Studies

Appendix F Table 7 CIN and Invasive Cervical Cancer Among Screened Positive Women in Included Trials, All Participants

Appendix F Table 8 Colposcopies and Biopsies of Included Randomized, Controlled Trials

Appendix F Table 9 Invasive Cervical Cancer Among Screen-Negative Women in Included Trials, All Participants