# Appendix E Ongoing Studies

Study | Country | Population | Interventions | Relevant Outcomes | Anticipated Completion
Cervical cancer screening
Aoki, 2015^191^ (CITRUS Study) | Japan | Women aged 30–64 years (n=30,000) | LBC + HPV vs. LBC | CIN Colposcopy Invasive cancer | March 2020
Canfell & Saville, 2015^192^ (COMPASS) | Australia | Women aged 25–69 years (n=121,000) | HPV vs. LBC | CIN Invasive cancer | December 2022
Murphy, 2008^193,*^ | Canada | Women aged 18 years or older (n=1,712) | HPV vs. Pap test | Colposcopy | January 2011 (no publications)
Ngan, 2011^194,*^ | Hong Kong | Women aged 30–60 years (n=12,000) | HPV + Pap test vs. Pap test | CIN | June 2017
Self-collection methods for cervical cancer screening
Haguenoer, 2011 (APACHE-1)^195,^ ^196^ | France | Women age 20–65 years (n=734) | Self-collection vs. clinical-collected | Diagnostic accuracy | Completed
Haguenoer, 2014^197^ (APACHE-2) | France | Women age 30–65 years (n=5,998) | Self-collection vs. clinician-collected | Diagnostic accuracy | Completed December 2012
Haguenoer & Sengchanh, 2015^198^ (APACHE-3) | France | Women age 30–65 years (n=3,612) | At-home self-sample vs. usual care | HPV | September 2016
Kiviat, 2014^199^ | United States | Women age ≥ 21 years (n=2,000) | Home-based HPV screening vs. usual care | Diagnostic accuracy for CIN1+ | August 2016
Lytwyn, 2011^200^ | Canada | Women age 35–69 years overdue for a Pap test (n=1,440) | Self-collection vs. reminder letter for Pap test | CIN3 | Completed January 2013; no publications
Svanholm, 2008^201^ | Denmark | Women age ≥ 23 years (n=100) | Tampon self-test vs. routine Pap test | Diagnostic accuracy | Completed March 2008, no publications
Szarewski, 2011^202^ (Westminister Self-Sampling Study) | United Kingdom | Women age ≥ 25 years (n=3,000) | Self-collection vs. invitation letter | Positive test | Completed
Virtanen, 2011^203^ | Finland | Women age 30–65 who did not take part in a screening exam (n=8,699) | Self-collection vs. reminder letter | HPV | Completed
Winer, 2014^204^ | United States | Women age 30–64 years (n=17,600) | Mailed in-home HPV testing kit vs. usual care | CIN2+ | February 2018
Zehbe, 2013^205,^ ^206^ (Anishinaabek Cervical Cancer Screening Study [ACCSS]) | Canada | Women age 25–69 years (n=1,200) | At-home HPV test kits vs. routine Pap test | HPV | Completed 2014
Gage, 2015 | United States | Women age 26–65 years (n=1000) | Self-collection vs. clinical-collected | CIN 2+ Diagnostic accuracy | June 2015

* Identified as ongoing in the previous review

Abbreviations: CIN = cervical intraepithelial neoplasia; HPV = human papillomavirus; LBC = liquid-based cytology; vs = versus