# Appendix D Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1 Canfell K, Caruana M, Gebski V, Cervical screening with primary HPV testing or cytology in a population of women in which those aged 33 years or younger had previously been offered HPV vaccination: Results of the Compass pilot randomised trial. PLoS Med. 2017;14(9):e1002388. PMID: 28926579.28926579
2 Ibanez R, Autonell J, Sarda M, Protecting the underscreened women in developed countries: the value of HPV test. BMC Cancer. 2014;14:574. PMID: 25102758. http://dx.doi.org/10.1186/1471-2407-14-574.25102758
3 Katki HA, Kinney WK, Fetterman B, Cervical cancer risk for women undergoing concurrent testing for human papillomavirus and cervical cytology: a population-based study in routine clinical practice. Lancet Oncol. 2011;12(7):663–72. PMID: 21684207. http://dx.doi.org/10.1016/S1470-2045(11)70145-0.21684207
a Gage JC, Hunt WC, Schiffman M, Similar risk patters after cervical screening in two large U.S. populations. 2016;128(6):1248–57.
b Gage JC, Schiffman M, Katki HA, Reassurance against future risk of precancer and cancer conferred by a negative human papillomavirus test. J Natl Cancer Inst. 2014;106(8). PMID: 25038467. http://dx.doi.org/10.1093/jnci/dju153 25038467
c Katki HA, Schiffman M, Castle PE, Five-year risks of CIN 3+ and cervical cancer among women who test Pap-negative but are HPV-positive. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S56–63. PMID: 23519306. http://dx.doi.org/10.1097/LGT.0b013e318285437b 23519306
d Demarco M, Lorey TS, Fetterman B, Risks of CIN 2+, CIN 3+, and Cancer by Cytology and Human Papillomavirus Status: The Foundation of Risk-Based Cervical Screening Guidelines. J Low Genit Tract Dis. 2017;21(4):261–7. PMID: 28953116. 10.1097/LGT.0000000000000343 28953116
4 Kitchener HC, Almonte M, Thomson C, HPV testing in combination with liquid-based cytology in primary cervical screening (ARTISTIC): a randomised controlled trial. Lancet Oncol. 2009;10(7):672–82. PMID: 19540162. http://dx.doi.org/10.1016/S1470-2045(09)70156-1.19540162
a Kitchener HC, Almonte M, Gilham C, ARTISTIC: a randomised trial of human papillomavirus (HPV) testing in primary cervical screening. Health Technol Assess. 2009;13(51):1–150, iii–iv. PMID: 19891902. http://dx.doi.org/10.3310/hta13510 19891902
b Kitchener HC, Fletcher I, Roberts C, The psychosocial impact of human papillomavirus testing in primary cervical screening-a study within a randomized trial. Int J Gynecol Cancer. 2008;18(4):743–8. PMID: 17944916. http://dx.doi.org/10.1111/j.1525-1438.2007.01113.x 17944916
c Kitchener HC, Canfell K, Gilham C, The clinical effectiveness and cost-effectiveness of primary human papillomavirus cervical screening in England: extended follow-up of the ARTISTIC randomised trial cohort through three screening rounds. Health Technol Assess. 2014;18(22):1–196. PMID: 24762804.24762804
d Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252.24192252
5 Leinonen MK, Nieminen P, Lonnberg S, Detection rates of precancerous and cancerous cervical lesions within one screening round of primary human papillomavirus DNA testing: prospective randomised trial in Finland. BMJ. 2012;345:e7789. PMID: 23197596. http://dx.doi.org/10.1136/bmj.e7789.23197596
6 Luyten A, Buttmann-Schweiger N, Luyten K, Early detection of CIN3 and cervical cancer during long-term follow-up using HPV/Pap smear co-testing and risk-adapted follow-up in a locally organised screening programme. Int J Cancer. 2014;135(6):1408–16. PMID: 24519782. http://dx.doi.org/10.1002/ijc.28783 24519782
a Petry KU, Luyten A, Scherbring S. Accuracy of colposcopy management to detect CIN3 and invasive cancer in women with abnormal screening tests: results from a primary HPV screening project from 2006 to 2011 in Wolfsburg, Germany. Gynecol Oncol. 2013;128(2):282–7. PMID: 23088926. http://dx.doi.org/10.1016/j.ygyno.2012.10.017 23088926
7 McCaffery K, Waller J, Forrest S, Testing positive for human papillomavirus in routine cervical screening: examination of psychosocial impact. BJOG. 2004;111(12):1437–43. PMID: 15663132. http://dx.doi.org/10.1111/j.1471-0528.2004.00279.x.15663132
8 Naucler P, Ryd W, Tornberg S, Human papillomavirus and Papanicolaou tests to screen for cervical cancer. N Engl J Med. 2007;357(16):1589–97. PMID: 17942872. http://dx.doi.org/10.1056/NEJMoa073204.17942872
a Elfstrom KM, Smelov V, Johansson AL, Long term duration of protective effect for HPV negative women: follow-up of primary HPV screening randomised controlled trial. BMJ. 2014;348:g130. PMID: 24435414. http://dx.doi.org/10.1136/bmj.g130 24435414
b Naucler P, Ryd W, Tornberg S, Efficacy of HPV DNA testing with cytology triage and/or repeat HPV DNA testing in primary cervical cancer screening. J Natl Cancer Inst. 2009;101(2):88–99. PMID: 19141778. http://dx.doi.org/10.1093/jnci/djn444 19141778
c Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252.24192252
9 Ogilvie G, Krajden M, van Niekerk D, HPV for cervical cancer screening (HPV FOCAL): complete Round 1 results of a randomized trial comparing HPV-based primary screening to liquid-based cytology for cervical cancer. Int J Cancer. 2016. PMID: None.
a Ogilvie GS, van Niekerk DJ, Krajden M, A randomized controlled trial of Human Papillomavirus (HPV) testing for cervical cancer screening: trial design and preliminary results (HPV FOCAL Trial). BMC Cancer. 2010;10:111. PMID: 20334685. http://dx.doi.org/10.1186/1471-2407-10-111 20334685
b Cook DA, Mei W, Smith LW, Comparison of the Roche cobas 4800 and Digene Hybrid Capture 2 HPV tests for primary cervical cancer screening in the HPV FOCAL trial. BMC Cancer. 2015;15:968. PMID: 26674353. http://dx.doi.org/10.1186/s12885-015-1959-5 26674353
c Coldman A. Preliminary 48 month exit results from HPV FOCAL cervical cancer screening trial: outcomes in subjects negative at baseline. 2016. PMID. None.
d Coldman AJ, Gondara L, Smith LW, Disease detection and resource use in the safety and control arms of the HPV FOCAL cervical cancer screening trial. Br J Cancer. 2016;115(12):1487–94. PMID: 27855441. http://dx.doi.org/https://dx.doi.org/10.1038/bjc.2016.368 27855441
10 Ronco G, Giorgi-Rossi P, Carozzi F, Efficacy of human papillomavirus testing for the detection of invasive cervical cancers and cervical intraepithelial neoplasia: a randomised controlled trial. Lancet Oncol. 2010;11(3):249–57. PMID: 20089449. http://dx.doi.org/10.1016/S1470-2045(09)70360-2 (NTCC Phase I).20089449
a Ronco G, Giorgi-Rossi P, Carozzi F, Human papillomavirus testing and liquid-based cytology in primary screening of women younger than 35 years: results at recruitment for a randomised controlled trial. Lancet Oncol. 2006;7(7):547–55. PMID: 16814206. http://dx.doi.org/10.1016/S1470-2045(06)70731-8 16814206
b Ronco G, Segnan N, Giorgi-Rossi P, Human papillomavirus testing and liquid-based cytology: results at recruitment from the new technologies for cervical cancer randomized controlled trial. J Natl Cancer Inst. 2006;98(11):765–74. PMID: 16757701. http://dx.doi.org/10.1093/jnci/djj209 16757701
c Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252.24192252
11 Ronco G, Giorgi-Rossi P, Carozzi F, Efficacy of human papillomavirus testing for the detection of invasive cervical cancers and cervical intraepithelial neoplasia: a randomised controlled trial. Lancet Oncol. 2010;11(3):249–57. PMID: 20089449. http://dx.doi.org/10.1016/S1470-2045(09)70360-2 (NTCC Phase II).20089449
a Ronco G, Giorgi-Rossi P, Carozzi F, Results at recruitment from a randomized controlled trial comparing human papillomavirus testing alone with conventional cytology as the primary cervical cancer screening test. J Natl Cancer Inst. 2008;100(7):492–501. PMID: 18364502. http://dx.doi.org/10.1093/jnci/djn065 18364502
b Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252.24192252
12 Rijkaart DC, Berkhof J, Rozendaal L, Human papillomavirus testing for the detection of high-grade cervical intraepithelial neoplasia and cancer: final results of the POBASCAM randomised controlled trial. Lancet Oncol. 2012;13(1):78–88. PMID: 22177579. http://dx.doi.org/10.1016/S1470-2045(11)70296-0.22177579
a Bulkmans NW, Rozendaal L, Snijders PJ, POBASCAM, a population-based randomized controlled trial for implementation of high-risk HPV testing in cervical screening: design, methods and baseline data of 44,102 women. Int J Cancer. 2004;110(1):94–101. PMID: 15054873. http://dx.doi.org/10.1002/ijc.20076 15054873
b Dijkstra MG, van Zummeren M, Rozendaal L, Safety of extending screening intervals beyond five years in cervical screening programmes with testing for high risk human papillomavirus: 14 year follow-up of population based randomised cohort in the Netherlands. BMJ. 2016;355:i4924. PMID: 27702796. http://dx.doi.org/10.1136/bmj.i4924 27702796
c Ronco G, Dillner J, Elfstrom KM, Efficacy of HPV-based screening for prevention of invasive cervical cancer: follow-up of four European randomised controlled trials. Lancet. 2014;383(9916):524–32. PMID: 24192252.24192252
13 Zorzi M, Frayle H, Rizzi M, A 3-year interval is too short for re-screening HPV negative women: a population-based cohort study. BJOG. 2017. PMID: 28120382. http://dx.doi.org/https://dx.doi.org/10.1111/1471-0528.14575 28120382
a Zorzi M, Del Mistro A, Farruggio A, Use of a high-risk human papillomavirus DNA test as the primary test in a cervical cancer screening programme: a population-based cohort study. BJOG. 2013;120(10):1260–7; discussion 7-8. PMID: 23786222. http://dx.doi.org/10.1111/1471-0528.12272 23786222